# APPENDIX C Reproductive Tissue Evaluations

TABLE C1 Summary of Reproductive Tissue Evaluations for Male B6C3F_1_ Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide

Left Caudal Weight (g)

Pyrazinamide (mg/kg/day) | AZT (mg/kg/day)
Pyrazinamide (mg/kg/day) | 0 | 200 | 400
0 | 0.0171 ± 0.0003 (10)^a^ | 0.0176 ± 0.0007 (10) | 0.0168 ± 0.0007 (10)
1,000 | 0.0170 ± 0.0003 (10) | 0.0171 ± 0.0004 (10) | 0.0167 ± 0.0004 (10)
15,000 | 0.0155 ± 0.0006 (10) | 0.0167 ± 0.0005 (10) | 0.0159 ± 0.0004 (10)

Note: A two-way analysis of variance indicates a significant pyrazinamide effect at 1,500 mg/kg.

Left Epididymal Weight (g)

Pyrazinamide (mg/kg/day) | AZT (mg/kg/day)
Pyrazinamide (mg/kg/day) | 0 | 200 | 400
0 | 0.0429 ± 0.0006 (10)^a^ | 0.0420 ± 0.0007 (10) | 0.0417 ± 0.0010 (10)
1,000 | 0.0414 ± 0.0005 (10) | 0.0415 ± 0.0007 (10) | 0.0393 ± 0.0008 (10)
15,000 | 0.0387 ± 0.0010 (10) | 0.0390 ± 0.0009 (10) | 0.0379 ± 0.0008 (10)

Note: A two-way analysis of variance indicates a significant pyrazinamide effect at 1,000 and 1,500 mg/kg.

Left Testicular Weight (g)

Pyrazinamide (mg/kg/day) | AZT (mg/kg/day)
Pyrazinamide (mg/kg/day) | 0 | 200 | 400
0 | 0.1169 ± 0.0020 (10)^a^ | 0.1129 ± 0.0021 (10) | 0.1077 ± 0.0022 (10)
1,000 | 0.1073 ± 0.0013 (10) | 0.1054 ± 0.0030 (10) | 0.0964 ± 0.0026 (10)
15,000 | 0.0977 ± 0.0027 (10) | 0.0963 ± 0.0024 (10) | 0.0916 ± 0.0023 (10)

Note: A two-way analysis of variance indicates a significant AZT effect at 400 mg/kg and a significant pyrazinamide effect at 1,000 and 1,500 mg. There was no AZT/pyrazinamide interaction effect.

Epididymal Sperm Motility (%)

Pyrazinamide (mg/kg/day) | AZT (mg/kg/day)
Pyrazinamide (mg/kg/day) | 0 | 200 | 400
0 | 80.26 ± 2.41 (10)^a^ | 66.04 ± 2.74 (9)^b^ | 56.61 ± 6.00 (10)
1,000 | 73.15 ± 2.50 (10) | 49.40 ± 8.98 (10) | 69.80 ± 5.95 (10)
15,000 | 73.81 ± 6.31 (10) | 66.63 ± 4.27 (10) | 52.82 ± 9.31 (10)

Note: Results of a two-way analysis of variance indicate that the dose response to AZT differs across doses of pyrazinamide (P = 0.048), including a significant pyrazinamide interaction.

a Mean ± SE: number of animals providing the data is indicated in parentheses.

b For 1 out of 10 animals in the 200 + 0 mg/kg group. sperm motility counts were performed approximately 1.5 hours after death.

Epididymal Sperm Density (× 10^6^)

Pyrazinamide (mg/kg/day) | AZT (mg/kg/day)
Pyrazinamide (mg/kg/day) | 0 | 200 | 400
0 | 1,213.02 ± 61.70 (10)^a^ | 1,337.90 ± 101.54 (10) | 1,331.52 ± 103.40 (10)
1,000 | 1,248.23 ± 119.50 (10) | 1,380.79 ± 102.12 (10) | 1,328.51 ± 107.12 (10)
15,000 | 1,336.62 ± 103.68 (10) | 1,293.78 ± 124.50 (10) | 1,265.77 ± 55.73 (10)

Spermatid Heads per Testis (× 10^7^)^b^

Pyrazinamide (mg/kg/day) | AZT (mg/kg/day)
Pyrazinamide (mg/kg/day) | 0 | 200 | 400
0 | 1.67 ± 0.05 (10)^a^ | 1.51 ± 0.05 (10) | 1.62 ± 0.04 (10)
1,000 | 1.56 ± 0.05 (10) | 1.58 ± 0.05 (10) | 1.40 ± 0.08 (10)
15,000 | 1.42 ± 0.06 (10) | 1.46 ± 0.06 (10) | 1.36 ± 0.08 (10)

Note: A two-way analysis of variance indicates a significant pyrazinamide effect at 1,500 mg/kg.

Spermatid Heads per Gram of Testis (× 10^7^)^c^

Pyrazinamide (mg/kg/day) | AZT (mg/kg/day)
Pyrazinamide (mg/kg/day) | 0 | 200 | 400
0 | 14.30 ± 0.53 (10)^a^ | 13.37 ± 0.46 (10) | 15.09 ± 0.54 (10)
1,000 | 14.50 ± 0.38 (10) | 14.99 ± 0.45 (10) | 14.45 ± 0.52 (10)
15,000 | 14.46 ± 0.34 (10) | 15.16 ± 0.43 (10) | 14.91 ± 0.82 (10)

a Mean ± SE; number of animals providing the data is indicated in parentheses.

b X(10,000)Y; (X = average number of spermatid heads per tertiary square; Y=dilution factor)

c Total spermatid heads per testis/testicular weight in grams