# APPENDIX B Organ Weights and Organ-Weight-to-Body-Weight Ratios

TABLE B1 Organ Weights and Organ-Weight-to-Body-Weight Ratios for B6C3F_1_ Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide^a^

| Vehicle Control | 200 + 0 | 400 + 0 | 0 + 1,000 | 200 + 1,000 | 400 + 1,000 | 0 + 1,500 | 200 + 1,500 | 400 + 1,500
Male
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
Necropsy body wt | 36.1 | 35.3 | 33.8^*^ | 35.9 | 35.2 | 34.0^*^ | 35.3 | 34.6 | 35.0
Heart
Absolute | 0.147 ± 0.0116 | 0.139 ± 0.0120 | 0.140 ± 0.0105 | 0.147 ± 0.0067 | 0.146 ± 0.0084 | 0.150 ± 0.0094 | 0.151 ± 0.0110 | 0.146 ± 0.0117 | 0.154 ± 0.0135
Relative | 4.1 ± 0.3 | 4.0 ± 0.5 | 4.1 ± 0.2 | 4.1 ± 0.3 | 4.2 ± 0.3 | 4.4 ± 0.3^*^ | 4.3 ± 0.3 | 4.2 ± 0.2 | 4.4 ± 0.3^*^
R. Kidney
Absolute | 0.286 ± 0.0276 | 0.285 ± 0.0246 | 0.269 ± 0.0191 | 0.281 ± 0.0185 | 0.283 ± 0.0177 | 0.284 ± 0.0207 | 0.292 ± 0.0239 | 0.278 ± 0.0155 | 0.293 ± 0.0258
Relative | 7.9 ± 0.4 | 8.1 ± 09 | 8.0 ± 0.5 | 7.8 ± 0.5 | 8.1 ± 0.5 | 8.4 ± 0.5 | 8.3 ± 0.5 | 8.0 ± 0.5 | 8.4 ± 0.7
Liver
Absolute | 1.563 ± 0.1702 | 1.603 ± 0.1251 | 1.474 ± 0.0952 | 1.673 ± 0.1517^b^ | 1.720 ± 0.1883^*^ | 1.660 ± 0.1327 | 1.716 ± 0.1365^*^ | 1.666 ± 0.1188 | 1.681 ± 0.1314
Relative | 43.4 ± 2.8 | 45.6 ± 4.2 | 43.6 ± 2.8 | 46.5 ± 2.6^*^ | 48.8 ± 2.8^*^ | 48.9 ± 2.5^*^ | 48.7 ± 2.2^*^ | 48.2 ± 3.2^*^ | 48.1 ± 2.6^*^
Lung
Absolute | 0.183 ± 0.0255^b^ | 0.192 ± 0.0319 | 0.165 ± 0.0151 | 0.197 ± 0.0411 | 0.189 ± 0.0335 | 0.188 ± 0.0210 | 0.194 ± 0.0276 | 0.181 ± 0.0137 | 0.179 ± 0.0136^b^
Relative | 5.1 ±0.5^b^ | 5.5 ± 0.9 | 4.9 ± 0.5 | 5.5 ± 1.1 | 5.4 ± 0.9 | 5.6 ± 0.6 | 5.5 ± 0.7 | 5.2 ± 0.4 | 5.1 ± 0.5^b^
R. Testis
Absolute | 0.118 ± 0.0102 | 0.113 ± 0.0045 | 0.109 ± 0.0081^*^ | 0.109 ± 0.0080^*^ | 0.109 ± 0.0068^*^ | 0.101 ± 0.0080^*^,^b^ | 0.100 ± 0.0102^*^ | 0.098 ± 0.0096^*^ | 0.094 ± 0.0081^*^
Relative | 3.3 ± 0.2 | 3.2 ± 0.1 | 3.2 ± 0.2 | 3.0 ± 0.3^*^ | 3.1 ± 0.2 | 3.0 ± 0.2^*^,^b^ | 2.8 ± 0.2^*^ | 2.8 ± 0.2^*^ | 2.7 ± 0.2^*^
Thymus
Absolute | 0.031 ± 0.0041^b^ | 0.033 ± 0.0042^b^ | 0.030 ± 0.0037 | 0.038 ± 0.0044^*^ | 0.035 ± 0.0039 | 0.032 ± 0.0036 | 0.035 ± 0.0048^b^ | 0.037 ± 0.0055^*^ | 0.032 ± 0.0035
Relative | 0.9 ± 0.1^b^ | 0.9 ± 0.1^b^ | 0.9 ± 0.1 | 1.1 ± 0.1^*^ | 1.0 ± 0.1^*^ | 0.9 ± 0.1 | 1.0 ± 0.1^*^,^b^ | 1.1 ± 0.2^*^ | 0.9 ± 0.1
Female
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
Necropsy body wt | 28.4 | 26.9 | 27.1 | 27.5 | 28.3 | 27.6 | 29.8 | 28.9 | 28.0
Heart
Absolute | 0.113 ± 0.0082 | 0.116 ± 0.0070 | 0.116 ± 0.0107 | 0.120 ± 0.0050^b^ | 0.129 ± 0.0088^*^ | 0.128 ± 0.0114^*^ | 0.122 ± 0.0155 | 0.125 ± 0.0118^*^ | 0.125 ± 0.0093^*^,^c^
Relative | 4.0 ± 0.5 | 4.3 ± 0.3^*^ | 4.3 ± 0.4 | 4.4 ± 0.4^*^,^b^ | 4.6 ± 0.3^*^ | 4.6 ± 0.4^*^ | 4.1 ± 0.4 | 4.3 ± 0.3^*^ | 4.5 ± 0.3^*^,^c^
R. Kidney
Absolute | 0.174 ± 0.0135 | 0.174 ± 0.0126 | 0.173 ± 0.0142 | 0.184 ± 0.0178 | 0.190 ± 0.0149^*^ | 0.196 ± 0.0217^*^ | 0.196 ± 0.0165^*^ | 0.203 ± 0.0231^*^ | 0.199 ± 0.0125^*^,^c^
Relative | 6.1 ± 0.5 | 6.5 ± 0.5 | 6.5 ± 0.9 | 6.7 ± 0.5 | 6.7 ± 0.5^*^ | 7.1 ± 0.8^*^ | 6.6 ± 0.4 | 7.1 ± 0.9^*^ | 7.1 ± 0.4^*^,^c^
Liver
Absolute | 1.195 ± 0.1407 | 1.164 ± 0.1096 | 1.181 ± 0.1392 | 1.381 ± 0.1695^*^ | 1.402 ± 0.1122^*^ | 1.432 ± 0.1750^*^ | 1.509 ± 0.2121^*^ | 1.563 ± 0.1152^*^,^b^ | 1.426 ± 0.1211^*^,^c^
Relative | 42.0 ± 3.4 | 43.3 ± 3.0 | 43.7 ± 2.9 | 50.2 ± 4.7^*^ | 49.6 ± 3.0^*^ | 51.9 ± 5.5^*^ | 50.6 ± 3.4^*^ | 55.1 ± 5.6^*^,^b^ | 50.9 ± 2.7^*^,^c^
Lung
Absolute | 0.177 ± 0.0275 | 0.180 ± 0.0408 | 0.190 ± 0.0333 | 0.192 ± 0.0342^b^ | 0.208 ± 0.0444^b^ | 0.180 ± 0.0262 | 0.191 ± 0.0411^b^ | 0.200 ± 0.0422 | 0.181 ± 0.0135^d^
Relative | 6.3 ± 1.0 | 6.7 ± 1.4 | 7.0 ± 1.0 | 7.0 ± 1.1^b^ | 7.3 ± 1.6^b^ | 6.5 ± 1.0 | 6.4 ± 1.5^b^ | 6.9 ± 1.4 | 6.6 ± 0.6^d^
Thymus
Absolute | 0.042 ± 0.0073 | 0.041 ± 0.0048 | 0.042 ± 0.0046^b^ | 0.039 ± 0.0068 | 0.040 ± 0.0078 | 0.042 ± 0.0065 | 0.041 ± 0.0054 | 0.042 ± 0.0065 | 0.045 ± 0.0085^d^
Relative | 1.5 ± 0.2 | 1.5 ± 0.2 | 1.5 ± 0.2^b^ | 1.4 ± 0.2 | 1.4 ± 0.3 | 1.5 ± 0.2 | 1.4 ± 0.2 | 1.5 ± 0.3 | 1.6 ± 0.3^d^

* Significantly different (P≤;0.05) from the vehicle control group by Williams’ or Dunnett’s test

a Organ weights (absolute weights) and body weights are given in grams; organ-weight-to-body-weight ratios (relative weights) are given as mg organ weight/g body weight (mean ± standard error).

b n = 9

c n = 8

d n = 7