# APPENDIX A Hematology Results

TABLE A1 Hematology Data for Male B6C3F_1_ Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide^a^

| Vehicle Control | 200 + 0 | 400 + 0 | 0 + 1,000 | 200 + 1,000 | 400 + 1,000 | 0 + 1,500 | 200 + 1,500 | 400 + 1,500
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
Hematocrit (%)
Day 4 | 45.7 ± 1.8 | 44.0 ± 1.6 | 43.5 ± 3.3^**^ | 44.9 ± 1.7 | 43.9 ± 1.2 | 43.1 ± 1.1^**^ | 45.8 ± 0.6 | 43.5 ± 1.3^*^ | 43.2 ± 1.6^*^
Day 30 | 53.1 ± 2.1 | 48.6 ± 1.3^**^ | 47.0 ± 1.8^**^ | 53.8 ± 2.2 | 47.5 ± 1.8^**^ | 47.3 ± 1.2^**^ | 52.4 ± 2.1 | 47.9 ± 1.4^**^ | 45.4 ± 2.2^**^
Day 60 | 51.7 ± 1.6 | 47.2 ± 1.6^**^ | 46.5 ± 2.1^**^ | 53.0 ± 1.9 | 49.0 ± 2.4^*^ | 45.8 ± 1.6^**^,^b^ | 52.4 ± 1.9 | 46.6 ± 1.2^**^ | 44.6 ± 2.1^**^
Week 13 | 48.4 ± 1.8 | 46.1 ± 1.3 | 45.0 ± 2.4^**^ | 50.5 ± 2.4 | 47.3 ± 2.5 | 45.5 ± 1.9^**^ | 50.3 ± 1.9 | 46.4 ± 1.3 | 43.4 ± 1.2^**^
Hemoglobin (g/dL)
Day 4 | 14.9 ± 0.5 | 14.4 ± 0.4 | 14.3 ± 1.0^*^ | 14.7 ± 0.4 | 14.4 ± 0.5 | 14.2 ± 0.4^**^ | 14.9 ± 0.3 | 14.3 ± 0.4^*^ | 14.2 ± 0.4^**^
Day 30 | 16.7 ± 0.6 | 15.2 ± 0.4^**^ | 14.7 ± 0.5^**^ | 16.9 ± 0.6 | 14.8 ± 0.6^**^ | 14.7 ± 0.4^**^ | 16.6 ± 0.5 | 14.8 ± 0.5^**^ | 13.9 ± 0.6^**^
Day 60 | 17.7 ± 0.4 | 15.8 ± 4.4^**^ | 15.4 ± 0.5^**^ | 18.2 ± 0.7 | 16.2 ± 0.7^**^ | 15.2 ± 0.4^**^,^b^ | 18.1 ± 0.6 | 15.7 ± 0.5^**^ | 14.7 ± 0.7^**^
Week 13 | 16.3 ± 0.5 | 15.4 ± 0.5^*^ | 14.7 ± 0.8^**^ | 17.1 ± 0.9^*^ | 15.7 ± 0.9 | 14.9 ± 0.5^**^ | 16.9 ± 0.6 | 15.2 ± 0.6^**^ | 14.0 ± 0.2^**^
Erythrocytes (10^6^/μL)
Day 4 | 9.45 ± 0.32 | 9.02 ± 0.30^*^ | 8.90 ± 0.60^**^ | 9.17 ± 0.32 | 8.98 ± 0.25^*^ | 8.86 ± 0.18^**^ | 9.39 ± 0.23 | 8.89 ± 0.32^**^ | 8.85 ± 0.33^**^
Day 30 | 10.22 ± 0.42 | 8.47 ± 0.24^**^ | 7.89 ± 0.34^**^ | 10.30 ± 0.42 | 8.03 ± 0.34^**^ | 7.78 ± 0.25^**^ | 9.89 ± 0.37 | 7.95 ± 0.26^**^ | 7.40 ± 0.34^**^
Day 60 | 10.63 ± 0.29 | 8.38 ± 0.23^**^ | 7.81 ± 0.31^**^ | 10.76 ± 0.43 | 8.20 ± 0.46^**^ | 7.25 ± 0.26^**^,^b^ | 10.53 ± 0.41 | 7.66 ± 0.21^**^ | 6.84 ± 0.36^**^
Week 13 | 10.28 ± 0.31 | 8.44 ± 0.31^**^ | 7.83 ± 0.26^**^ | 10.58 ± 0.39 | 8.26 ± 0.33^**^ | 7.53 ± 0.41^**^ | 10.36 ± 0.31 | 7.76 ± 0.27^**^ | 6.89 ± 0.24^**^
Reticulocytes (10^5^/μL)
Day 4 | 4.7 ± 0.35 | 3.4 ± 0.77^**^,^b^ | 3.2 ± 0.32^**^ | 5.0 ± 0.54 | 3.6 ± 1.18^**^ | 3.0 ± 0.70^**^ | 5.3 ± 0.36 | 3.0 ± 0.26^**^ | 2.7 ± 0.47^**^
Day 30 | 4.0 ± 0.18 | 4.3 ± 0.40 | 5.1 ± 0.46^**^ | 4.0 ± 0.36 | 5.1 ± 0.55^**^ | 5.4 ± 0.35^**^ | 3.9 ± 0.28 | 5.3 ± 0.48^**^ | 5.6 ± 0.38^**^
Day 60 | 3.3 ± 0.19 | 4.0 ± 0.21^**^ | 5.1 ± 0.19^**^ | 3.1 ± 0.22 | 5.1 ± 0.40^**^ | 5.8 ± 0.28^**^,^b^ | 3.3 ± 0.15 | 5.6±0.19^**^ | 6.1 ± 0.31^**^
Week 13 | 4.3 ± 0.47 | 5.4 ± 0.46^**^ | 6.0 ± 0.56^**^ | 4.1 ± 0.43 | 6.2 ± 0.24^**^ | 7.0 ± 0.54^**^ | 4.5 ± 0.32 | 6.6 ± 0.29^**^ | 7.8 ± 0.91^**^
Mean cell volume (fL)
Day 4 | 48.4 ± 0.8 | 48.8 ± 0.8 | 48.9 ± 0.8 | 49.0 ± 0.8 | 48.9 ± 0.9 | 48.7 ± 0.9 | 48.8 ± 0.9 | 48.9 ± 1.0 | 48.8 ± 0.4
Day 30 | 52.0 ± 0.4 | 57.4 ± 0.6^**^ | 59.5 ± 1.5^**^ | 52.3 ± 0.7 | 59.2 ± 0.8^**^ | 60.8 ± 0.9 | 53.0 ± 0.4 | 60.3 ± 1.1^*^ | 61.4 ± 0.7^**^
Day 60 | 48.6 ± 1.1 | 56.3 ± 1.0^**^ | 59.6 ± 0.7^**^ | 49.3 ± 0.6 | 59.8 ± 1.3^**^ | 63.2 ± 1.1^**^,^b^ | 49.7 ± 0.3 | 60.8 ± 0.8^**^ | 65.3 ± 1.2^**^
Week 13 | 47.1 ± 1.6 | 54.6 ± 1.8^**^ | 57.5 ± 1.8^**^ | 47.7 ± 1.2 | 57.2 ± 1.6^**^ | 60.5 ± 2.5^**^ | 48.6 ± 1.2 | 59.9 ± 2.0^**^ | 63.1 ± 2.4^**^
Mean cell hemoglobin (pg)
Day 4 | 15.8 ± 0.2 | 16.0 ± 0.2 | 16.0 ± 0.2 | 16.0 ± 0.2 | 16.0 ± 0.3 | 16.0 ± 0.2 | 15.9 ± 0.2 | 16.1 ± 0.2 | 16.0 ± 0.2
Day 30 | 16.4 ± 0.2 | 17.9 ± 0.3^**^ | 18.6 ± 0.3^**^ | 16.4 ± 0.3 | 18.4 ± 0.1 ** | 18.8 ± 0.2^**^ | 16.8 ± 0.2^**^ | 18.7 ± 0.2^**^ | 18.8 ± 0.2^**^
Day 60 | 16.7 ± 0.2 | 18.9 ± 0.2^**^ | 19.7 ± 0.4^**^ | 16.8 ± 0.1 | 19.8 ± 0.3^**^ | 21.0 ± 0.2^**^,^b^ | 17.1 ± 0.1^**^ | 20.5 ± 0.2^**^ | 21.5 ± 0.4^**^
Week 13 | 15.8 ± 0.5 | 18.2 ± 0.4^**^ | 18.8 ± 0.5^**^ | 16.1 ± 0.4 | 19.0 ± 0.5^**^ | 19.8 ± 0.6^**^ | 16.4 ± 0.5 | 19.6 ± 0.6^**^ | 20.4 ± 0.6^**^
Mean cell hemoglobin concentration (g/dL)
Day 4 | 32.7 ± 0.6 | 32.7 ± 0.7 | 32.8 ± 0.6 | 32.7 ± 0.7 | 32.8 ± 0.8 | 32.9 ± 0.7 | 32.6 ± 0.6 | 32.9 ± 0.7 | 32.8 ± 0.5
Day 30 | 31.4 ± 0.4 | 31.2 ± 0.4 | 31.3 ± 0.4 | 31.4 ± 0.4 | 31.1 ± 0.4 | 31.0 ± 0.3 | 31.7 ± 0.5 | 31.0 ± 0.5 | 30.7 ± 0.3^**^
Day 60 | 34.3 ± 0.9 | 33.4 ± 0.4^**^ | 33.2 ± 0.6^**^ | 34.2 ± 0.5 | 33.1 ± 0.5^**^ | 33.2 ± 0.6^**^,^b^ | 34.5 ± 0.3 | 33.7 ± 0.5 | 32.9 ± 0.4^**^
Week 13 | 33.7 ± 0.8 | 33.3 ± 0.8 | 32.8 ± 0.8 | 33.9 ± 1.0 | 33.2 ± 1.0 | 32.8 ± 0.6 | 33.7 ± 0.8 | 32.7 ± 1.1 | 32.3 ± 0.9^**^
Platelets (10^3^/μL)
Day 4 | 1,271 ± 166.1 | 1,447 ± 129.8 | 1,411 ± 196.3 | 1,406 ± 207.3 | 1,294 ± 172.5 | 1,374 ± 215.3 | 1,311 ± 100.0 | 1,380 ± 116.0 | 1,401 ± 183.2
Day 30 | 1,150 ± 207.1 | 1,275 ± 113.0 | 1,293 ± 156.2 | 1,216 ± 236.0 | 1,337 ± 119.0 | 1,430 ± 145.4^**^ | 1,212 ± 173.6 | 1,418 ± 123.4^**^ | 1,637 ± 100.3^**^
Day 60 | 949 ± 190.2 | 1,259 ± 109.5^**^ | 1,305 ± 171.8^**^ | 1,019 ± 137.0 | 1,291 ± 170.2^**^ | 1,485 ± 179.0^**^,^b^ | 1,006 ± 164.3 | 1,379 ± 135.3^**^ | 1,510 ± 234.9^**^
Week 13 | 1,347 ± 119.6 | 1,520 ± 161.0 | 1,502 ± 116.2 | 1,347 ± 226.4 | 1,577 ± 151.7 | 1,730 ± 251.3 | 1,346 ± 124.8 | 1,645 ± 164.6^**^ | 1,770 ± 203.7^**^
Leukocytes (10^3^/μL)^c^
Day 4 | 6.87 ± 0.98 | 6.90 ± 0.80 | 7.82 ± 2.29 | 6.81 ± 0.86 | 6.10 ± 0.99 | 6.01 ± 1.27 | 7.13 ± 0.92 | 5.97 ± 0.66 | 5.15 ± 0.64^**^
Day 30 | 7.18 ± 0.76 | 6.67 ± 0.81 | 6.36 ± 0.46 | 7.17 ± 0.77 | 6.35 ± 0.83 | 6.22 ± 0.49 | 6.79 ± 0.93 | 6.34 ± 0.79 | 6.28 ± 0.75
Day 60 | 6.11 ± 0.42 | 5.88 ± 0.61 | 5.81 ± 0.66 | 6.26 ± 0.79 | 5.23 ± 0.72^*^ | 5.24 ± 0.64^**^,^b^ | 6.32 ± 0.44 | 5.60 ± 0.60 | 5.60 ± 0.48
Week 13 | 7.70 ± 1.03 | 7.01 ± 1.49 | 6.46 ± 1.13 | 7.08 ± 0.94 | 6.76 ± 1.00 | 6.21 ± 1.41 | 7.37 ± 1.16 | 6.89 ± 1.21 | 6.19 ± 0.64
Segmented neutrnphils (10^3^/μL)
Day 4 | 0.83 ± 0.20 | 0.78 ± 0.12 | 1.09 ± 1.10 | 0.94 ± 0.19 | 0.77 ± 0.22 | 0.66 ± 0.14 | 0.95 ± 0.14 | 0.67 ± 0.15 | 0.65 ± 0.12
Day 30 | 0.67 ± 0.09 | 0.71 ± 0.11 | 0.62 ± 0.09 | 0.91 ± 0.21^**^ | 0.71 ± 0.12 | 0.60 ± 0.09 | 0.93 ± 0.22^**^ | 0.75 ± 0.13 | 0.59 ± 0.07
Day 60 | 0.65 ± 0.10 | 0.60 ± 0.11 | 0.47 ± 0.07^*^ | 0.71 ± 0.19 | 0.52 ± 0.21 | 0.51 ± 0.12^b^ | 0.78 ± 0.14 | 0.63 ± 0.13 | 0.53 ± 0.13
Week 13 | 0.95 ± 0.19 | 0.85 ± 0.17 | 0.79 ± 0.30 | 1.04 ± 0.34 | 0.86 ± 0.18 | 0.83 ± 0.13 | 1.08 ± 0.16 | 0.88 ± 0.19 | 0.85 ± 0.15
Lymphocytes (10^3^/μL)
Day 4 | 5.71 ± 0.82 | 5.81 ± 0.78 | 6.37 ± 1.21 | 5.49 ± 0.75 | 4.97 ± 1.06 | 5.04 ± 1.09 | 5.76 ± 0.79 | 4.98 ± 0.51 | 4.20 ± 0.60^**^
Day 30 | 6.21 ± 0.72 | 5.71 ± 0.77 | 5.53 ± 0.46 | 5.94 ± 0.56 | 5.42 ± 0.78 | 5.38 ± 0.45 | 5.56 ± 0.82 | 5.34 ± 0.71 | 5.50 ± 0.66
Day 60 | 5.16 ± 0.37 | 5.03 ± 0.51 | 5.07 ± 0.59 | 5.25 ± 0.63 | 4.50 ± 0.64^*^ | 4.49 ± 0.60^*^,^b^ | 5.23 ± 0.36 | 4.72 ± 0.53 | 4.83 ± 0.35
Week 13 | 6.30 ± 0.75 | 5.79 ± 1.33 | 5.37 ± 0.85 | 5.64 ± 0.88 | 5.54 ± 0.84 | 5.08 ± 1.27 | 5.93 ± 1.05 | 5.64 ± 1.06 | 4.96 ± 0.64
Monocytes (10^3^/μL)
Day 4 | 0.17 ± 0.04 | 0.15 ± 0.02 | 0.18 ± 0.06 | 0.21 ± 0.05 | 0.20 ± 0.05 | 0.18 ± 0.05 | 0.23 ± 0.04^**^ | 0.17 ± 0.03 | 0.15 ± 0.03
Day 30 | 0.11 ± 0.02 | 0.09 ± 0.02 | 0.07 ± 0.02^**^ | 0.17 ± 0.05^**^ | 0.10 ± 0.05 | 0.11 ± 0.02 | 0.17 ± 0.01^**^ | 0.11 ± 0.01 | 0.08 ± 0.02
Day 60 | 0.12 ± 0.03 | 0.08 ± 0.02^**^ | 0.07 ± 0.03^**^ | 0.12 ± 0.02 | 0.08 ± 0.03^**^ | 0.08 ± 0.02^**^,^b^ | 0.15 ± 0.03 | 0.10 ± 0.03 | 0.10 ± 0.02
Week 13 | 0.17 ± 0.04 | 0.16 ± 0.03 | 0.13 ± 0.05 | 0.21 ± 0.11 | 0.17 ± 0.04 | 0.15 ± 0.04 | 0.20 ± 0.04 | 0.18 ± 0.05 | 0.19 ± 0.03
Basophils (10^3^/μL)
Day 4 | 0.02 ± 0.007 | 0.02 ± 0.006 | 0.03 ± 0.014 | 0.02 ± 0.007 | 0.02 ± 0.008 | 0.02 ± 0.006 | 0.02 ± 0.010 | 0.02 ± 0.008 | 0.02 ± 0.007
Day 30 | 0.02 ± 0.008 | 0.02 ± 0.009 | 0.02 ± 0.010 | 0.03 ± 0.012 | 0.02 ± 0.011 | 0.02 ± 0.007 | 0.02 ± 0.006 | 0.02 ± 0.007 | 0.01 ± 0.007
Day 60 | 0.02 ± 0.007 | 0.02 ± 0.022 | 0.02 ± 0.007 | 0.02 ± 0.009 | 0.02 ± 0.013 | 0.02 ± 0.009^b^ | 0.02 ± 0.009 | 0.02 ± 0.007 | 0.01 ± 0.008
Week 13 | 0.02 ± 0.010 | 0.02 ± 0.012 | 0.01 ± 0.004 | 0.02 ± 0.008 | 0.02 ± 0.009 | 0.01 ± 0.007 | 0.02 ± 0.012 | 0.02 ± 0.006 | 0.02 ± 0.007
Eosinophils (10^3^/μL)
Day 4 | 0.13 ± 0.04 | 0.11 ± 0.03 | 0.13 ± 0.01 | 0.13 ± 0.03 | 0.11 ± 0.04 | 0.10 ± 0.03 | 0.14 ± 0.05 | 0.12 ± 0.05 | 0.11 ± 0.03
Day 30 | 0.15 ± 0.06 | 0.13 ± 0.03 | 0.11 ± 0.05 | 0.11 ± 0.05 | 0.09 ± 0.04^*^ | 0.10 ± 0.03 | 0.10 ± 0.02^*^ | 0.11 ± 0.03 | 0.08 ± 0.03^**^
Day 60 | 0.14 ± 0.05 | 0.13 ± 0.07 | 0.18 ± 0.11 | 0.13 ± 0.04 | 0.10 ± 0.05 | 0.12 ± 0.04^b^ | 0.14 ± 0.05 | 0.11 ± 0.03 | 0.12 ± 0.05
Week 13 | 0.24 ± 0.16 | 0.16 ± 0.05 | 0.14 ± 0.08^*^ | 0.14 ± 0.03^*^ | 0.15 ± 0.05 | 0.12 ± 0.05^**^ | 0.12 ± 0.04^**^ | 0.14 ± 0.08^*^ | 0.14 ± 0.07^*^
Large unstained cells (10^3^/μL)
Day 4 | 0.03 ± 0.01 | 0.03 ± 0.01 | 0.03 ± 0.01 | 0.03 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01
Day 30 | 0.01 ± 0.01 | 0.02 ± 0.00 | 0.01 ± 0.01 | 0.02 ± 0.01 | 0.01 ± 0.01^b^ | 0.01 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.01 ± 0.01
Day 60 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.01 ± 0.01 | 0.02 ± 0.01 | 0.01 ± 0.01^b^ | 0.02 ± 0.01^b^ | 0.02 ± 0.01 | 0.01 ± 0.01 | 0.02 ± 0.01
Week 13 | 0.03 ± 0.01 | 0.03 ± 0.01 | 0.02 ± 1.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01

* Significantly different (P≤0.05) from the vehicle control group by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + pyrazinamide (mg/kg per day). Data are given as mean ± standard error. Statistical tests were performed on unrounded data.

b n = 9

c Leukocyte counts corrected for nucleated erythrocyte counts greater than 10 per 100 leukocytes

TABLE A2 Hematology Data for Female B6C3F_1_ Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide^a^

| Vehicle Control | 200 + 0 | 400 + 0 | 0 + 1,000 | 200 + 1,000 | 400 + 1,000 | 0 + 1,500 | 200 + 1,500 | 400 + 1,500
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
Hematocrit (%)
Day 4 | 46.2 ± 1.5 | 47.5 ± 1.6 | 44.4 ± 6.1 | 46.6 ± 1.4 | 46.2 ± 1.6 | 46.0 ± 2.0 | 47.5 ± 0.8 | 45.8 ± 1.3 | 45.9 ± 1.2
Day 30 | 46.1 ± 1.2 | 44.0 ± 1.2 | 43.0 ± 0.7 | 48.4 ± 2.4 | 44.8 ± 1.5 | 43.8 ± 2.8 | 47.8 ± 1.1 | 44.4 ± 1.5 | 38.4 ± 10.1^**^
Day 60 | 49.2 ± 2.7 | 44.2 ± 1.8^**^ | 44.8 ± 3.0^**^,^b^ | 49.0 ± 0.8^b^ | 45.8 ± 1.3^**^ | 42.6 ± 1.8^**^ | 49.6 ± 2.1 | 45.5 ± 1.9^**^ | 40.8 ± 2.3^**^,^b^
Week 13 | 45.2 ± 1.4 | 43.7 ± 2.2 | 42.2 ± 3.1 | 47.8 ± 3.1 | 46.1 ± 3.4 | 42.6 ± 2.7 | 48.7 ± 5.1 | 44.3 ± 3.1 | 43.0 ± 1.9^d^
Hemoglobin (g/dL)
Day 4 | 15.1 ± 0.4 | 15.6 ± 0.7 | 14.4 ± 2.0 | 15.3 ± 0.4 | 15.1 ± 0.4 | 15.1 ± 0.5 | 15.6 ± 0.4 | 15.1 ± 0.4 | 15.0 ± 0.4
Day 30 | 15.4 ± 0.3 | 14.2 ± 0.4 | 13.8 ± 0.2^*^ | 16.1 ± 0.7 | 14.6 ± 0.4 | 14.1 ± 0.8 | 15.9 ± 0.4 | 14.4 ± 0.4 | 12.4 ± 3.2^**^
Day 60 | 16.0 ± 0.6 | 14.0 ± 0.5^**^ | 14.0 ± 1.0^**^,^b^ | 16.2 ± 0.3^b^ | 14.7 ± 0.4^**^ | 13.3 ± 0.6^**^ | 16.5 ± 0.7 | 14.7 ± 0.5^**^ | 12.8 ± 0.7^**^,^b^
Week 13 | 15.5 ± 0.5 | 14.7 ± 0.5 | 14.0 ± 0.8^**^ | 16.6 ± 0.9^*^ | 15.5 ± 0.8 | 13.9 ± 0.6^**^ | 16.8 ± 1.5^**^ | 14.9 ± 0.9 | 14.1 ± 0.4^**^,^d^
Erythrocytes (10^6^/μL)
Day 4 | 8.99 ± 0.26 | 9.34 ± 0.42 | 8.55 ± 1.25 | 9.15 ± 0.34 | 9.02 ± 0.26 | 9.02 ± 0.30 | 9.31 ± 0.25 | 9.00 ± 0.23 | 8.90 ± 0.21
Day 30 | 9.45 ± 0.26 | 7.92 ± 0.21^**^ | 7.46 ± 0.16^**^ | 9.89 ± 0.50 | 7.97 ± 0.24^**^ | 7.47 ± 0.47^**^ | 9.71 ± 0.23 | 7.87 ± 0.30^**^ | 6.70 ± 1.60^**^
Day 60 | 9.98 ± 0.51 | 7.55 ± 0.34^**^ | 7.19 ± 0.56^**^,^b^ | 9.92 ± 0.16^b^ | 7.89 ± 0.31^**^ | 6.50 ± 0.29^**^ | 10.03 ± 0.41 | 7.53 ± 0.31^**^ | 6.34 ± 0.33^**^,^b^
Week 13 | 9.65 ± 0.40 | 7.85 ± 0.32^**^ | 7.13 ± 0.44^**^ | 10.08 ± 0.38 | 7.98 ± 0.46^**^ | 6.92 ± 0.40^**^ | 10.06 ± 0.86 | 7.51 ± 0.44^**^ | 6.76 ± 0.39^**^,^d^
Reticulocytes (10^5^/μL)
Day 4 | 4.1 ± 0.61 | 3.3 ± 0.79^*^ | 3.0 ± 0.65^**^ | 4.4 ± 0.47 | 3.3 ± 0.61^*^ | 2.5 ± 0.41^**^ | 4.6 ± 0.39 | 3.4 ± 0.63^*^ | 2.6 ± 0.52^**^
Day 30 | 3.1 ± 0.50 | 4.1 ± 0.44^*^ | 4.7 ± 0.36^**^ | 3.3 ± 0.69 | 4.5 ± 0.85^**^ | 5.4 ± 0.69^**^ | 3.4 ± 0.66 | 5.2 ± 0.76^**^ | 4.6 ± 1.40^**^
Day 60 | 3.5 ± 0.51 | 4.9 ± 0.54^**^ | 5.9 ± 0.82^**^,^b^ | 3.3 ± 0.60^b^ | 4.7 ± 0.98^*^ | 6.1 ± 1.06^**^ | 3.2 ± 0.82 | 5.6 ± 0.77^**^ | 5.6 ± 1.34^**^,^b^
Week 13 | 4.3 ± 1.17 | 4.9 ± 0.82 | 6.0 ± 0.91^**^ | 4.0 ± 0.91^b^ | 6.1 ± 0.91^**^ | 6.9 ± 1.08^**^ | 4.4 ± 1.26 | 5.6 ± 1.08^*^ | 8.0 ± 0.89^**^,^d^
Mean cell volume (fL)
Day 4 | 51.4 ± 1.0 | 50.9 ± 0.9 | 52.1 ± 1.2 | 51.0 ± 1.0 | 51.2 ± 0.9 | 51.0 ± 0.7 | 51.1 ± 0.7 | 50.9 ± 0.7 | 51.6 ± 1.5
Day 30 | 48.9 ± 0.8 | 55.6 ± 0.5^**^ | 57.7 ± 0.9^**^ | 48.9 ± 0.4 | 56.2 ± 0.7^**^ | 58.6 ± 1.4^**^ | 49.2 ± 0.9 | 56.4 ± 1.1^**^ | 56.5 ± 4.4^**^
Day 60 | 49.3 ± 0.6 | 58.5 ± 1.1^**^ | 62.4 ± 0.5^**^,^b^ | 49.3 ± 0.5^b^ | 58.1 ± 1.0^**^ | 65.5 ± 1.1^**^ | 49.5 ± 0.5 | 60.5 ± 1.4^**^ | 64.3 ± 1.8^**^,^b^
Week 13 | 46.9 ± 1.4 | 55.7 ± 2.2^**^ | 59.3 ± 2.8^**^ | 47.4 ± 1.6 | 57.8 ± 1.9^**^ | 61.5 ± 2.6^**^ | 48.4 ± 1.8 | 59.0 ± 1.6^**^ | 63.6 ± 3.3^**^,^d^
Mean cell hemoglobin (pg)
Day 4 | 16.8 ± 0.1 | 16.7 ± 0.2 | 16.9 ± 0.5 | 16.7 ± 0.4 | 16.8 ± 0.4 | 16.7 ± 0.2 | 16.7 ± 0.3 | 16.7 ± 0.2 | 16.8 ± 0.2
Day 30 | 16.3 ± 0.2 | 18.0 ± 0.1^**^ | 18.5 ± 0.2^**^ | 16.3 ± 0.3 | 18.3 ± 0.2^**^ | 18.9 ± 0.3^**^ | 16.4 ± 0.4 | 18.3 ± 0.3^**^ | 18.3 ± 1.1^**^
Day 60 | 16.0 ± 0.2 | 18.6 ± 0.2^**^ | 19.5 ± 0.3^**^,^b^ | 16.3 ± 0.2^b^ | 18.6 ± 0.3^**^ | 20.5 ± 0.1^**^ | 16.4 ± 0.2^**^ | 19.5 ± 0.2^**^ | 20.3 ± 0.4^**^,^b^
Week 13 | 16.1 ± 0.4 | 18.7 ± 0.5^**^ | 19.7 ± 0.5^**^ | 16.5 ± 0.4 | 19.5 ± 0.5^**^ | 20.1 ± 0.6^**^ | 16.7 ± 0.4^*^ | 19.8 ± 0.2^**^ | 20.9 ± 0.9^**^,^d^
Mean cell hemoglobin concentration (g/dL)
Day 4 | 32.7 ± 0.6 | 32.7 ± 0.6 | 32.5 ± 0.7 | 32.8 ± 0.8 | 32.8 ± 0.9 | 32.7 ± 0.6 | 32.8 ± 0.6 | 33.0 ± 0.6 | 32.6 ± 0.8
Day 30 | 33.3 ± 0.5 | 32.3 ± 0.3^**^ | 32.1 ± 0.5^**^ | 33.3 ± 0.4 | 32.5 ± 0.3^**^ | 32.2 ± 0.5^**^ | 33.2 ± 0.4 | 32.5 ± 0.4^**^ | 32.4 ± 0.7^**^
Day 60 | 32.5 ± 0.7 | 31.7 ± 0.6^**^ | 31.3 ± 0.4^**^,^b^ | 32.9 ± 0.5^b^ | 32.1 ± 0.3 | 31.3 ± 0.5^**^ | 33.3 ± 0.4^**^ | 32.3 ± 0.5 | 31.6 ± 0.4^**^,^b^
Week 13 | 34.3 ± 0.7 | 33.6 ± 0.8 | 33.2 ± 1.0 | 34.8 ± 1.0 | 33.7 ± 0.9 | 32.7 ± 1.0^**^ | 34.5 ± 1.0 | 33.6 ± 0.9 | 32.8 ± 0.9^**^,^c^
Platelets (10^3^/μL)
Day 4 | 1,144 ± 75.3 | 1,066 ± 118.9 | 1,245 ± 139.3 | 1,124 ± 61.6 | 1,233 ± 63.4 | 1,263 ± 70.6^*^ | 1,239 ± 108.2 | 1,275 ± 109.4^*^ | 1,187 ± 75.4
Day 30 | 1,044 ± 82.9 | 1,171 ± 154.3 | 1,209 ± 111.1^*^ | 988 ± 153.8 | 1,228 ± 134.1^*^ | 1,422 ± 154.6^**^ | 1,020 ± 109.4 | 1,219 ± 109.1^*^ | 1,561 ± 186.1^**^
Day 60 | 1,010 ± 203.8 | 1,276 ± 206.3^**^ | 1,292 ± 116.5^**^,^b^ | 1,179 ± 165.5^b^ | 1,403 ± 106.2^**^ | 1,493 ± 198.8^**^ | 1,133 ± 209.8 | 1,402 ± 134.0^**^ | 1,515 ± 233.7^**^,^b^
Week 13 | 1,176 ± 94.9 | 1,275 ± 168.0 | 1,319 ± 197.7 | 1,197 ± 162.2 | 1,455 ± 252.0^*^ | 1,529 ± 187.1^**^ | 1,170 ± 234.1 | 1,428 ± 197.1^*^ | 1.609 ± 325.4^**^,^d^
Leukocytes (10^3^/μL)^c^
Day 4 | 8.11 ± 1.33 | 5.77 ± 2.18^**^ | 5.64 ± 1.66^**^ | 5.92 ± 0.71^*^ | 6.18 ± 2.28^*^ | 5.22 ± 1.40^**^ | 6.47 ± 1.46 | 5.84 ± 1.24^**^ | 5.43 ± 1.00^**^
Day 30 | 5.24 ± 0.98 | 4.47 ± 1.66 | 3.58 ± 0.53^**^ | 4.15 ± 0.71 | 4.27 ± 1.07 | 4.00 ± 0.51^*^ | 4.79 ± 1.43 | 3.71 ± 0.65^**^ | 3.48 ± 0.51^**^
Day 60 | 5.18 ± 0.90 | 4.30 ± 1.03 | 4.28 ± 1.06^b^ | 4.62 ± 0.84^b^ | 5.23 ± 0.94 | 4.18 ± 0.75 | 4.98 ± 1.37 | 4.31 ± 1.09 | 4.00 ± 0.79^b^
Week 13 | 4.90 ± 1.5 | 4.50 ± 1.74 | 3.77 ± 0.99 | 4.67 ± 1.37 | 3.82 ± 1.00 | 4.41 ± 1.41 | 4.33 ± 1.25 | 3.80 ± 1.18 | 3.16 ± 0.65^d^
Segmented neutrophils (10^3^/μL)
Day 4 | 0.90 ± 0.24 | 0.66 ± 0.23 | 0.73 ± 0.26 | 0.72 ± 0.22 | 0.61 ± 0.31^*^ | 0.65 ± 0.19 | 0.89 ± 0.30 | 0.67 ± 0.12 | 0.61 ± 0.20
Day 30 | 0.62 ± 0.22 | 0.48 ± 0.28 | 0.30 ± 0.09^*^ | 0.47 ± 0.16 | 0.42 ± 0.17 | 0.43 ± 0.07 | 0.80 ± 0.56 | 0.38 ± 0.11 | 0.42 ± 0.08
Day 60 | 0.52 ± 0.17 | 0.38 ± 0.10 | 0.32 ± 0.10^*^,^b^ | 0.45 ± 0.14^b^ | 0.47 ± 0.09 | 0.41 ± 0.11 | 0.67 ± 0.30 | 0.47 ± 0.12 | 0.43 ± 0.13^b^
Week 13 | 0.59 ± 0.18 | 0.57 ± 0.27 | 0.38 ± 0.19 | 0.61 ± 0.19^b^ | 0.47 ± 0.21 | 0.47 ± 0.09 | 0.50 ± 0.15 | 0.45 ± 0.14 | 0.39 ± 0.15^d^
Lymphocytes (10^3^/μL)
Day 4 | 6.78 ± 1.19 | 4.77 ± 1.91^**^ | 4.66 ± 1.47^**^ | 4.89 ± 0.71^*^ | 5.28 ± 1.96 | 4.31 ± 1.29^**^ | 5.18 ± 1.26 | 4.83 ± 1.08^*^ | 4.56 ± 0.80^**^
Day 30 | 4.35 ± 0.78 | 3.81 ± 1.43 | 3.12 ± 0.47^**^ | 3.48 ± 0.57 | 3.63 ± 0.89 | 3.38 ± 0.48^*^ | 3.74 ± 0.99 | 3.13 ± 0.53^**^ | 2.91 ± 0.44^**^
Day 60 | 4.44 ± 0.81 | 3.74 ± 0.98 | 3.79 ± 0.96^b^ | 3.96 ± 0.75^b^ | 4.54 ± 0.85 | 3.61 ± 0.67 | 4.08 ± 1.06 | 3.64 ± 0.97 | 3.37 ± 0.73^b^
Week 13 | 4.09 ± 0.97 | 3.73 ± 1.45 | 3.20 ± 0.76 | 3.82 ± 1.16^b^ | 3.09 ± 0.69 | 3.72 ± 1.35 | 3.58 ± 1.03 | 3.13 ± 1.08 | 2.59 ± 0.55^d^
Monocytes (10^3^/μL)
Day 4 | 0.20 ± 0.05 | 0.14 ± 0.07^*^ | 0.13 ± 0.04^*^ | 0.17 ± 0.05 | 0.14 ± 0.06^*^ | 0.14 ± 0.04^*^ | 0.20 ± 0.06 | 0.16 ± 0.05 | 0.13 ± 0.03^*^
Day 30 | 0.10 ± 0.03 | 0.06 ± 0.02 | 0.06 ± 0.02^*^ | 0.09 ± 0.03 | 0.09 ± 0.03 | 0.07 ± 0.03 | 0.13 ± 0.08 | 0.07 ± 0.02 | 0.06 ± 0.03
Day 60 | 0.09 ± 0.02 | 0.06 ± 0.03 | 0.05 ± 0.03^*^,^b^ | 0.08 ± 0.02^b^ | 0.08 ± 0.03 | 0.07 ± 0.03 | 0.10 ± 0.04 | 0.09 ± 0.03 | 0.08 ± 0.02^b^
Week 13 | 0.11 ± 0.04 | 0.08 ± 0.03 | 0.07 ± 0.03 | 0.12 ± 0.04^b^ | 0.11 ± 0.04 | 0.10 ± 0.04 | 0.11 ± 0.04 | 0.10 ± 0.04 | 0.09 ± 0.04^d^
Basophils (10^3^/μL
Day 4 | 0.03 ± 0.012 | 0.02 ± 0.009 | 0.02 ± 0.007^*^ | 0.02 ± 0.005 | 0.02 ± 0.012^*^ | 0.02 ± 0.005^*^ | 0.02 ± 0.007 | 0.02 ± 0.011^*^ | 0.01 ± 0.005^**^
Day 30 | 0.01 ± 0.008 | 0.01 ± 0.005 | 0.01 ± 0.004 | 0.01 ± 0.006 | 0.01 ± 0.004 | 0.01 ± 0.005 | 0.01 ± 0.005 | 0.01 ± 0.005 | 0.01 ± 0.008
Day 60 | 0.01 ± 0.007 | 0.01 ± 0.003 | 0.01 ± 0.007^b^ | 0.01 ± 0.006^b^ | 0.02 ± 0.007 | 0.01 ± 0.008 | 0.01 ± 0.005 | 0.01 ± 0.006 | 0.01 ± 0.004^b^
Week 13 | 0.01 ± 0.007 | 0.01 ± 0.006 | 0.01 ± 0.007 | 0.01 ± 0.006^b^ | 0.01 ± 0.006 | 0.01 ± 0.007 | 0.01 ± 0.011 | 0.01 ± 0.009 | 0.01 ± 0.005^d^
Eosinophils (10^3^/μL)
Day 4 | 0.17 ± 0.05 | 0.16 ± 0.05 | 0.08 ± 0.04^*^ | 0.09 ± 0.05^*^ | 0.12 ± 0.04 | 0.09 ± 0.05^*^ | 0.17 ± 0.12 | 0.14 ± 0.08 | 0.09 ± 0.03^*^
Day 30 | 0.15 ± 0.06 | 0.10 ± 0.05 | 0.10 ± 0.03 | 0.10 ± 0.04 | 0.11 ± 0.04 | 0.09 ± 0.04^*^ | 0.11 ± 0.05 | 0.12 ± 0.06 | 0.07 ± 0.03^**^
Day 60 | 0.09 ± 0.05 | 0.10 ± 0.03 | 0.10 ± 0.05^b^ | 0.11 ± 0.07^b^ | 0.11 ± 0.05 | 0.08 ± 0.03 | 0.11 ± 0.07 | 0.11 ± 0.05 | 0.09 ± 0.03^b^
Week 13 | 0.10 ± 0.03 | 0.10 ± 0.03 | 0.10 ± 0.06 | 0.10 ± 0.07^b^ | 0.14 ± 0.10 | 0.10 ± 0.03 | 0.11 ± 0.08 | 0.10 ± 0.06 | 0.07 ± 0.03^d^
Large unstained cells (10^3^/μL)
Day 4 | 0.03 ± 0.02 | 0.02 ± 0.02 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01
Day 30 | 0.01 ± 0.01 | 0.01 ± 0.01 | 0.01 ± 0.01 | 0.01 ± 0.01 | 0.01 ± 0.01 | 0.01 ± 0.01 | 0.01 ± 0.01 | 0.01 ± 0.01 | 0.01 ± 0.00
Day 60 | 0.01 ± 0.01 | 0.01 ± 0.01 | 0.01 ± 1.01^d^ | 0.01 ± 0.00^b^ | 0.02 ± 0.01 | 0.01 ± 0.00^b^ | 0.01 ± 0.01 | 0.01 ± 0.01^b^ | 0.01 ± 0.01^b^
Week 13 | 0.01 ± 0.00 | 0.01 ± 0.01 | 0.01 ± 0.01 | 0.01 ± 0.01^b^ | 0.01 ± 0.01 | 0.01 ± 0.01^b^ | 0.01 ± 0.01 | 0.01 ± 0.01 | 0.01 ± 0.01^d^

* Significantly different (P≤0.05) from the vehicle control group by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + pyrazinamide (mg/kg per day). Data are given as mean ± standard error. Statistical tests were performed on unrounded data

b n = 9

c Leukocyte counts corrected for nucleated erythrocyte counts greater than 10 per 100 leukocytes

d n = 8