# References

Amin, N.M. (1989). Zidovudine for treating AIDS: What physicians need to know. Postgrad. Med. 86, 195–208.2662155
Ayers, K.M. (1988). Preclinical toxicology of Zidovudine: An overview. Am. J. Med. 85, 186–188.3044084
Battaglia, R., Salgarollo, G., Zini, G., Montesanti, L., and Benedetti, M.S. (1991). Absorption, distribution, and urinary metabolism of ^14^C-rifabutin in rats. Antimicrob. Agents Chemother. 35, 1391–1396.1656861
Chaisson, R.E., Moore, R.D., Richman, D.D., Keruly, J., and Creagh, T. (1992). Incidence and natural history of Mycobacterium avium-complex infections in patients with advanced human immunodeficiency virus disease treated with zidovudine. Am. Rev. Respir. Dis. 146, 285–289.1362634
Coffin, J.M. (1986). Genetic variation in AIDS viruses. Cell 46, 1–4.3013415
Dunn, O.J. (1964). Multiple comparisons using rank sums. Technometrics 6, 241–252.
Dunnett, C.W. (1955). A multiple comparison procedure for comparing several treatments with a control. J. Am. Stat. Assoc. 50, 1095–1121.
Freireich, E.J., Gehan, E.A., Rall, D.P., Schmidt, L.H., and Skipper, H.E. (1966). Quantitative comparison of toxicity of anticancer agents in mouse, rat, hamster, dog, monkey, and man. Cancer Chemother. Rep. 50, 219–244.4957125
Gottlieb, M.S., Schroff, R., Schanker, H.M., Weisman, J.D., Fan, P.T., Wolf, R.A., and Saxon, A. (1981). Pneumocystis carinii pneumonia and mucosal candidiasis in previously healthy homosexual men: Evidence of a new acquired cellular immunodeficiency. N. Engl. J. Med. 305, 1425–1431.6272109
Greene, J.A., Ayers, K.M., deMiranda, P., and Tucker, W.E. (1990). Postnatal survival in Wistar rats following oral dosage with zidovudine on gestation day 10. Fundam. Appl. Toxicol. 15, 201–206.2373299
Harada, T., Enomoto, A., Boorman, G.A., and Maronpot, R.R. (1999). Liver and gallbladder. In Pathology of the Mouse (R.R. Maronpot, Ed.), pp. 129–130. Cache River Press, Vienna, IL.
Harris, M.W., Chapin, R.E., Lockhart, A.C., and Jokinen, M.P. (1992). Assessment of short-term reproductive and developmental toxicity screen. Fundam. Appl. Toxicol. 19, 186–196.1516774
Herzlich, B.C., Ranginwala, M., Nawabi, I., and Herbert, V. (1990). Synergy of inhibition of DNA synthesis in human bone marrow by azidothymidine plus deficiency of folate and/or vitamin B^12^? Am. J. Hematol. 33, 177–183.2301378
Jain, N.C. (1986). Schalm’s Veterinary Hematology. 4th ed., p. 549. Lea and Febiger, Philadelphia.
Jeffries, D.J. (1989). Targets for antiviral therapy of human immunodeficiency virus infection. J. Infect. 18 (Suppl. 1), 5–13.2464649
Jonckheere, A.R. (1954). A distribution-free k-sample test against ordered alternatives. Biometrika 41, 133–145.
Mansuri, M.M., Hitchcock, M.J., Buroker, R.A., Bregman, C.L., Ghazzouli, I., Desiderio, J.V., Starrett, J.E., Sterzycki, R.Z., and Martin, J.C. (1990). Comparison of in vitro biological properties and mouse toxicities of three thymidine analogs active against human immunodeficiency virus. Antimicrob. Agents Chemother. 34, 637–641.1693057
Masur, H. (1993). Recommendations on prophylaxis and therapy for disseminated Mycobacterium avium complex disease in patients infected with the human immunodeficiency virus. N. Engl. J. Med. 329, 898–904.8395019
Masur, H., Michelis, M A., Greene, J.B., Onorato, I., Stouwe, R.A., Holzman, R.S., Wormser, G., Brettman, L., Lange, M., Murray, H. W., and Cunningham-Rundles, S. (1981). An outbreak of community-acquired Pneumocystis carinii pneumonia: Initial manifestations of cellular immune dysfunction. J. Immunol. 135, 3151–3162.
National Toxicology Program (NTP) (1999). Toxicology and Carcinogenesis Studies of AZT (CAS No. 30516-87-1) and AZT/α-Interferon A/D in B6C3F_1_ Mice (Gavage Studies). Technical Report Series No. 469. NIH Publication No. 99-3959. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, Research Triangle Park, NC.
Nightingale, S.D., Cameron, D.W., Gordin, F.M., Sullam, P.M., Cohn, D.L., Chaisson, R.E., Eron, L.J., Sparti, P.D., Bihari, B., Kaufman, D.L., Stern, J.J., Pearce, D.D., Weinberg, W.G., LaMarca, A., and Siegal, F.P. (1993). Two controlled trials of rifabutin prophylaxis against Mycobacterium avium complex infection in AIDS. N. Engl. J. Med. 329, 828–833.8179648
O’Brien, R.J., Lyle, M.A., and Snider, D.E., Jr. (1987). Rifabutin (Ansamycin LM 427): A new rifamycin-S derivative for treatment of mycobacterial diseases. Rev. Infect. Dis. 9, 519–530.3037676
Orme, I.M. (1988). Antimycobacterial activity in vivo of LM427 (rifabutin). Am. Rev. Respir. Dis. 138, 1254–1257.2849349
Physician’s Desk Reference (PDR) (1995). 49th ed., pp. 1893–1895. Medical Economics Data, Medical Economics Company Inc., Montvale, N.J.
Richman, D.D. (1988). The treatment of HIV infection. Azidothymidine (AZT) and other new antiviral drugs. Infec. Dis. Clin. North Am. 2, 397–497.2462584
Saito, H., Sato, K., and Tomioka, H. (1988). Comparative in vitro and in vivo activity of rifabutin and rifampicin against Mycobacterium avium complex. Tubercle 69, 187–192.2855458
Scampini, G., Nava, A., Newman, A.J., Della Torre, P., and Mazue, G. (1993). Multinucleated hepatocytes induced by rifabutin in rats. Toxicol. Pathol. 21, 369–376.8290868
Scheffe, H. (1953). A method for judging all contrasts in the analysis of variance. Biometrika 40, 87–104.
Siegal, F.P., Lopez, C., Hammer, C.S., Brown, A.E., Kornfeld, S.J., Gold., J., Hassett, J., Hirschman, S.Z., Cunningham-Rundles, C., Adelsburg, B.R., Parham, D.M., Siegal, M., Cunningham-Rundles, S., and Armstrong, D. (1981). Severe acquired immunodeficiency in male homosexuals manifested by chronic perianal ulcerative herpes simplex lesions. N. Engl. J. Med. 305, 1439–1444.6272110
Siegal, F.P., Eilbott, D.J., Burger, H., Gehan, K., Davidson, B., Kaell, A.T., and Weiser, B. (1990). Dose-limiting toxicity of rifabutin in AIDS-related complex: Syndrome of arthralgia/arthritis. AIDS 4, 433–441.2164820
Siegel, S. (1956). Nonparametric Statistics for the Behavioral Sciences, pp. 96–104. McGraw-Hill, New York.
Skinner, M.H., Hsieh, M., Torseth, J., Pauloin, D., Bhatia, G., Harkonen, S., Merigan, T.C., and Blaschke, T.F. (1989). Pharmacokinetics of rifabutin. Antimicrob. Agents Chemother. 33, 1237–1241.2552902
Snedecor, G.W., and Cochran, W.G., Eds. (1967a). Analysis of variance. In Statistical Methods, 6th ed., pp. 258–275. Iowa State University Press, Ames, IA.
Snedecor, G.W., and Cochran, W.G., Eds. (1967b). Analysis of covariance. In Statistical Methods, 6th ed., pp. 419–431. Iowa State University Press, Ames, IA.
Snedecor, G.W., and Cochran, W.G., Eds. (1967c). Test for a linear trend in proportions. In Statistical Methods, 6th ed., pp. 246–248. Iowa State University Press, Ames, IA.
Snower, D.P., and Well, S.C. (1993). Changing etiology of macrocytosis. Zidovudine as a frequent causative factor. Am. J. Clin. Pathol. 99, 57–60.8422018
Sokal, R.R., and Rohlf, F.J. (1969). Kruskal-Wallis Test. In Biometry, pp. 370–371, 388–389. W.H. Freeman and Co., San Francisco.
Toltzis, P., Marx, C.M., Kleinman, N., Levine, E.M., and Schmidt, E.V. (1991). Zidovudine-associated embryonic toxicity in mice. J. Infect. Dis. 163, 1212–1218.2037787
Trang, J.M., Prejean, J.D., James, R.H., Irwin, R.D., Goehl, T.J., and Page, J.G. (1993). Zidovudine bioavailability and linear pharmacokinetics in female B6C3F1 mice. Drug Metab. Dispos. 21, 189–193.8095218
Vince, R., Hua, M., Brownell, J., Daluge, S., Lee, F.C., Shannon, W.M., Lavelle, G.C., Qualls, J., Weislow, O.S., Kiser, R., Canonico, C.G., Schultz, R.H., Narayanan, V.L., Mayo, L.G., Shoemaker, R.H., and Boyd, M.R. (1988). Potent and selective activity of a new carbocyclic nucleoside analog (Carbovir: NSC 614846) against human immunodeficiency virus in vitro. Biochem. Biophys. Res. Commun. 156, 1046–1053.2847711
Volpe, D.A., Du, D.L., Verhoef, V., and Murphy, M.J. (1993). Myelotoxicity ofrifabutin and 3′-azido-3′-deoxythymidine, alone and in combination, to human hematopoietic progenitor cells in vitro. Pathobiology 61, 77–82.8216829
Wilcoxon, F. (1945). Individual comparison by ranking methods. Biometrics 1, 80–83.
Williams, D.A. (1971). A test for differences between treatment means when several dose levels are compared with a zero dose control. Biometrics 27, 103–117.5547548
Williams, D.A. (1972). The comparison of several dose levels with a zero dose control. Biometrics 28, 519–531.5037867