# Peer Review

The draft report on the reproductive, developmental, and general toxicity studies of 3′-azido-3′-deoxythymidme (AZT) and rifabutm combinations was evaluated by the reviewers listed below. These reviewers serve as independent scientists, not as representatives of any institution, company, or governmental agency. In this capacity, reviewers determine if the design and conditions of these studies are appropriate and ensure that this reproductive, developmental, and general toxicity study report presents the experimental results and conclusions fully and clearly. The comments of the reviewers were received and reviewed prior to the finalization of this document. Changes were made such that the concerns of the reviewers have been addressed to the extent possible.

- Warren W. Ku, Ph.D.
  Pfizer, Inc
  Drug Safety Evaluation
  Eastern Point Road
  Groton, CT
- Michael J. Brabec, Ph.D.
  Eastern Michigan University
  Department of Chemistry
  Ypsilanti,MI