# Results and Discussion

## Survival and Clinical Findings

### Male Mice

No male mice died before scheduled sacrifice. All male mice that received 320 or 640 mg/kg rifabutin alone or in combination with 200 or 400 mg/kg 3′-azido-3′-deoxythymidine (AZT) had red-colored urine; five of ten male mice in these groups had swollen faces. Piloerection was noted in male mice administered 0 + 640 mg/kg (5 of 10),200 + 640 (5 of 10), or 400 + 640 mg/kg (6 of 10). The only other clinical finding noted in any male mice was red-colored urine in two mice each in the 0 + 80 and 200 + 80 mg/kg groups.

### Female-A Mice

Fifty-five female-A mice died prior to scheduled sacrifice (Table 3). Five were administered 200 + 320 mg/kg, 20 were administered 200 + 640 mg/kg, 10 were administered 400 + 320 mg/kg, and the remaining 20 were administered 400 + 640 mg/kg. These mice died on study days 4 through 27. In general, mice considered moribund had one or more of the following signs: coldness to the touch, decreased motor activity, labored breathing, tremors, pallor, and hindlimb dragging.

Red-colored urine occurred in all female-A mice administered 320 or 640 mg/kg rifabutin alone or in combination with 200 or 400 mg/kg AZT, three mice administered 200 or 400 mg/kg AZT + 80 mg/kg rifabutin, and all mice administered 80 mg/kg rifabutin alone. Piloerection occurred in 11 of 20 mice administered 200 + 320 mg/kg, all mice administered 400 + 320 mg/kg, and all mice administered 640 mg/kg rifabutin alone or in combination with 200 or 400 mg/kg AZT. Swollen faces were observed in 10 of 20 mice in each of the groups administered 80, 320, or 640 mg/kg rifabutin alone or 320 or 640 mg/kg rifabutin in combination with 200 or 400 mg/kg AZT.

TABLE 3 Early Deaths in Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Dose^a^ | Number of Deaths | Day of Death | Type of Death | Clinical Findings
200 + 320 | 4 | 4-26 | Moribund | Swollen face, red-colored urine, dragging hindlimbs, piloerection, decreased motor activity, coldness to the touch, pallor, labored breathing
200 + 320 | 1 | 27 | Found dead | Swollen face, red-colored urine
200 + 640 | 20 | 14-22 | Moribund | Swollen face, red-colored urine, piloerection, decreased motor activity, coldness to the touch, labored breathing
400 + 320 | 10 | 19-27 | Moribund | Swollen face, red-colored urine, piloerection, decreased motor activity, coldness to the touch, pallor, labored breathing
400 + 640 | 19 | 6-22 | Moribund | Swollen face, red-colored urine, piloerection, decreased motor activity, coldness to the touch, pallor, labored breathing, tremors
400 + 640 | 1 | 11 | Found dead | Swollen face, red-colored urine, piloerection

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

### Female-B Mice

No female-B mice died before the scheduled sacrifice. Red-colored urine was observed during gestation and lactation in almost all mice administered 320 or 640 mg/kg rifabutin alone or in combination with 200 or 400 mg/kg AZT. Red-colored urine also occurred in one mouse that received 400 + 80 mg/kg. Swollen faces were observed during gestation in six mice administered 320 mg/kg rifabutin alone; in three mice administered 640 mg/kg rifabutin alone; in four and three mice administered 200 mg/kg AZT + 320 or 640 mg/kg rifabutin, respectively; and in three and four mice administered 400 mg/kg AZT + 320 or 640 mg/kg rifabutin, respectively.

## Body and Organ Weights

### Male Mice

Administration of 400 + 640 mg/kg caused a significant decrease (P≤0.01) in mean body weight gain (Figure 1) for the entire dosing period (days 5 to 23). AZT alone (200 or 400 mg/kg), rifabutin alone (80, 320, or 640 mg/kg), or 200 or 400 mg/kg AZT + 80 or 320 mg/kg rifabutin did not affect mean body weights or body weight gains during the dosing period. No other statistically significant differences (P≤0.05) occurred.

In males, significant dose-related elevations in absolute liver weights were noted (Figure 2 and Table B1). Male mice treated with 640 mg/kg rifabutin alone, 200 mg/kg AZT + 320 or 640 mg/kg rifabutin, or 400 + 320 mg/kg had increased (P≤0.05) absolute liver weights. These elevations correlated well with histopathologic and clinical chemistry alterations indicative of liver toxicity.

### Female-A Mice

Mice administered 200 or 400 mg/kg AZT alone had mean body weights (Figure 3) significantly reduced (P≤0.05 or P≤0.01) compared to the vehicle control group mean on study day 26 and at termination. Mean body weight gains were significantly reduced (P≤0.05 or P≤0.01) for the 200 and 400 mg/kg AZT groups on study days 0 to 26 compared to the vehicle control group. These decreased mean body weights resulted from reduced gravid uterine weights (P≤0.01) in the 200 and 400 mg/kg AZT groups. When gravid uterine weights were subtracted, the final mean body weights were comparable to the vehicle control group value.

Administration of rifabutin alone at doses as high as 640 mg/kg did not affect mean body weights, mean body weight gains, final mean body weights, or gravid uterine weights of female-A mice. No significant (P≤0.05) differences in mean body weights occurred between this group and the vehicle control group. A significant decrease (P≤0.01) in mean body weight gain occurred in the 640 mg/kg rifabutin group on study days 23 to 26.

Female-A mice administered 200 mg/kg AZT + 320 or 640 mg/kg rifabutin had reduced and/or significantly reduced (P≤0.05 or P≤0.01) mean body weights on study days 16 (200 + 640 mg/kg group only), 20, 23, 26, and at termination (for surviving mice). A similar pattern occurred in groups treated with 400 mg/kg AZT + 80, 320, or 640 mg/kg rifabutin. These differences reflected reduced gravid uterine weights that occurred in all groups administered both test articles and that survived to caesarean section. The mean corrected final body weights (final body weight minus gravid uterine weight) were comparable among all groups with surviving mice administered both test articles. The exception was reduced body weight of the one mouse in the 400 + 320 mg/kg group that was pregnant and subjected to caesarean section on presumed day 19 of gestation. (All other mice in this group were not pregnant or were sacrificed before day 19 of gestation.)

FIGURE 1 Mean Body Weights of Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations (TSAC=terminal sacrifice)

FIGURE 2 Mean Absolute Liver Weights for Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations (*=data not available due to mortality. For variance and statistically significant differences, see Table B1.)

FIGURE 3 Mean Body Weights of Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

(Plots A, C, and E show body weights from day 0 through terminal sacrifice [TSAC]. Plots B, D, and F show the identical data except body weights at TSAC are after gravid uterine weights have been subtracted. Group fmal mean body weights and corrected body weights include only values for dams that were actually pregnant and were sacrificed and caesarean-sectioned as scheduled on presumed day 19 of gestation.)

Mean body weight gains were significantly reduced (P≤0.01) for the female-A mice administered 200 + 80 mg/kg for study days 23 to 26, 200 + 320 mg/kg on study days 0 to 26, or 200 + 640 mg/kg on study days 0 to 20. Mean body weight gains were also significantly reduced (P≤0.05 or P≤0.01) for the female-A mice administered 400 mg/kg AZT in combination with 80 or 320 mg/kg rifabutin on study days 0 to 26 and in combination with 640 mg/kg rifabutin on study days 0 to 20.

Significantly increased (P≤0.05) absolute liver weights were noted (Figure 2 and Table B1) in female-A mice receiving 640 mg/kg rifabutin alone.

### Female-B Mice

Mean gestational body weights (Figure 4) were comparable among the groups administered AZT alone, rifabutin alone, or AZT in combination with rifabutin. The exception was the 400 + 640 mg/kg group, which had significantly reduced (P≤0.01) mean body weights on gestation day 15 compared to the vehicle control group. Mean gestational body weight gains were significantly reduced (P≤0.05 or P≤0.01) for the groups receiving 200 + 640 mg/kg or 400 + 320 mg/kg on days 12 to 15 of gestation and 400 + 640 mg/kg on days 8 to 15 of gestation.

Mean body weights and body weight gains of the treated groups during the lactation period did not significantly (P>0.05) differ from any of the vehicle control group values, although these values tended to be reduced in the group that received 200 + 640 mg/kg. However, this group had only one mouse that delivered pups and the dam and pups survived to lactation day 4.

FIGURE 4 Mean Body Weights of Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations (GD=gestation day; LD=lactation day)

Note: data include only values for those dams that were actually pregnant, that survived to lactation day 4, and that delivered pups that survived to lactation day 4.

## Clinical Pathology

### Hematology

#### AZT Alone

##### Male Mice

Slight decreases in erythrocyte parameter values [erythrocyte (RBC) counts, hemoglobin concentrations (Hgb), hematocrit (Hct) values] were observed in both the 200 and 400 mg/kg AZT groups. Respective mean RBC counts (Figure 5 and Table A1) of both these groups were 12% lower (8.36 × 10^6^/mm^3^ and 8.33 × 10^6^/mm^3^, P≤0.05) than the mean RBC count of the vehicle control group (9.47 × 10^6^/mm^3^). Hgb concentrations and Hct values paralleled the slight decreases in RBC counts. While only statistically significant at 400 mg/kg AZT, the slight decreases in RBC counts observed with AZT administration alone were considered biologically significant due to concurrent increases in mean cell volume (MCV). Respective MCVs for male mice treated with 200 or 400 mg/kg AZT were 7% (51.6 fL) or 7% (51.7 fL) greater than the MCV of the vehicle control group (48.3 fL), While not statistically significant, these increases in MCVs were considered treatment related. These changes in erythrocyte parameters occurred with no biologically significant changes in mean reticulocyte counts.

Slightly higher mean platelet counts (Figure 6 and Table A1) were observed in both groups treated with AZT; the mean platelet count of male mice treated with 400 mg/kg AZT was 1.5 times (1,469 × 10^3^/mm^3^) that of the mean platelet count (992 × 10^3^/mm^3^) of the vehicle control group. Although not statistically significant, these increased platelet counts were considered biologically significant.

Administration of AZT alone was associated with lower leukocyte (WBC) counts (Figure 7 and Table A1), which could be attributed to slight decreases in both segmented neutrophil counts (Figure 8 and Table A1) and lymphocyte counts (Figure 9 and Table A1). These changes were not statistically significant but were considered biologically significant in the 400 mg/kg AZT group. Mean WBC, neutrophil, and lymphocyte counts of mice treated with 400 mg/kg AZT were, respectively, 31% (4.81 × 10^3^/mm^3^), 32% (0.68 × 10^3^/mm^3^), and 31% (3.82 × 10^3^/mm^3^) lower than the respective counts in the male vehicle control group (6.97, 1.00, and 5.53 × 10^3^/mm^3^).

FIGURE 5 Mean Red Blood Cell Values for Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations (*=data not available due to mortality. For variance and statistically significant differences, see Tables A1 and A2.)

FIGURE 6 Mean Platelet Values for Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations (* = data not available due to mortality. For variance and statistically significant differences, see Tables A1 and A2.)

FIGURE 7 Mean Leukocyte Values for Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations (* = data not available due to mortality. For variance and statistically significant differences, see Tables A1 and A2.)

FIGURE 8 Mean Segmented Neutrophil Values for Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations (*=data not available due to mortality. For variance and statistically significant differences; see Tables A1 and A2.)

FIGURE 9 Mean Lymphocyte Values for Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations (*=data not available due to mortality. For variance and statistically significant differences, see Tables A1 and A2.)

##### Female-A Mice

AZT administration resulted in hematologic alterations in female mice similar to those observed in male mice. RBC counts (Figure 5 and Table A2) were slightly decreased in female-A mice treated with 200 and 400 mg/kg AZT alone, with respective mean RBC counts 14% (7.51 × 10^6^/mm^3^, P≤0.01) and 12% (7.71 × 10^6^/mm^3^, P≤0.01) lower than the mean RBC count of the vehicle control group (8.74 × 10^6^/mm^3^). Hgb concentrations and Hct values paralleled RBC counts. These slight but biologically significant decreases in RBC counts were accompanied by statistically significant (P≤0.01) increases in MCV. The respective MCVs of mice treated with 200 and 400 mg/kg AZT were 14% (55.9 fL) and 16% (56.8 fL) greater than the vehicle control MCV (49.1 fL). In general, alterations in mean cell hemoglobin (MCH) paralleled the changes in MCV.

An increased mean platelet count was observed only in the 200 mg/kg AZT group, although it was not statistically significant. The mean platelet count (Figure 6 and Table A2) of the female-A mice group treated with 200 mg/kg AZT was approximately 1.2 times (1,672 × 10^3^/mm^3^) the mean platelet count (1,382 × 10^3^/mm^3^) of the vehicle control group.

WBC counts (Figure 7 and Table A2) were slightly decreased in female-A mice treated with AZT alone. WBC counts of the 200 and 400 mg/kg AZT groups were, respectively, 26% (5.69 × 10^3^/mm^3^, P≤0.05) and 24% (5.86 × 10^3^/mm^3^) lower than the mean WBC count of the corresponding vehicle control group (7.68 × 10^3^/mm^3^). These slight decreases in mean WBC counts observed in AZT-treatment groups were predominantly due to decreases in neutrophil counts (Figure 8 and Table A2). Corresponding mean neutrophil counts were respectively, 58% (1.10 × 10^3^/mm^3^, P≤0.01) and 55% (1.19 × 10^3^/mm^3^, P≤0.01) lower than the mean count (2.62 × 10^3^/mm^3^) of the vehicle control group. No appreciable alterations in lymphocyte counts were observed in these groups (Figure 9 and Table A2).

##### Female-B Mice

Values for hematology parameters with variance and statistically significant differences are listed in Table A3. Although slight decreases in RBC counts occurred in the female-B groups administered AZT alone, these were not statistically or biologically significant. Slight increases in MCVs of mice treated with 200 and 400 mg/kg AZT of 5% (53.8 fL) and 4% (53.3 fL) above that observed in the vehicle control group (51.4 fL) suggest that altered erythropoiesis may have occurred even with only 10 days of administration of AZT. Reticulocyte counts were also slightly increased, with counts of the 200 and 400 mg/kg AZT groups 1.2 times (5.5 × 10^5^/mm^3^) and 1.3 times (6.1 × 10^5^/mm^3^) higher than the mean reticulocyte count of the corresponding vehicle control group (4.6 × 10^5^/mm^3^). These data also suggest that AZT had a hematopoietic effect even with 10 days of treatment.

Platelet count was increased in only the 200 mg/kg AZT group, although the difference was not statistically significant. The mean platelet count of the 200 mg/kg AZT group was 1.2 times (1,522 × 10^3^/mm^3^) that of the vehicle control group (1,262 × 10^3^/mm^3^).

#### Rifabutin Alone

##### Male Mice

Administration of 320 or 640 mg/kg rifabutin alone to male mice resulted in slight decreases in RBC counts and slight increases in reticulocyte, WBC, and neutrophil counts.

Respective mean RBC counts (Figure 5 and Table A1) of male mice treated with 320 and 640 mg/kg rifabutin were approximately 11% (8.47 × 10^6^/mm^3^ and 9% (8.65 × 10^6^/mm^3^) lower than the mean RBC count (9.47 × 10^6^/mm^3^) of the vehicle control group. Slight declines in Hgb concentrations (P≤0.05) and Hct values accompanied the decreases in RBC counts. While not all of the decreases in RBC parameters were statistically significant, these were considered biologically significant because they were accompanied by increases in reticulocyte counts. The MCV of the 640 mg/kg group was 5% lower (45.9 fL) than the MCV of the vehicle control group (48.3 fL), and this was considered biologically significant. Reticulocyte counts were increased in both the 320 and 640 mg/kg rifabutin groups, with the maximum increase in the 640 mg/kg group. While not statistically significant, these increases were considered treatment related. The mean reticulocyte counts of these groups were 1.5 times (6.6 × 10^5^/mm^3^) and 1.8 times (8.1 × 10^5^/mm^3^) the mean reticulocyte count of the vehicle control group (4.5 × 10^5^/mm^3^).

Platelet counts (Figure 6 and Table A1) were also increased in male mice administered 320 or 640 mg/kg rifabutin, with respective mean platelet counts 1.3 times (1,300 × 10^3^/mm^3^) and 1.4 times (1,357 × 10^3^/mm^3^) the mean platelet count of vehicle controls (992 × 10^3^/mm^3^).

The mean WBC counts (Figure 7 and Table A1) were slightly increased in both the 320 and 640 mg/kg rifabutin groups, with mean WBC counts 1.2 times (8.24 × 10^3^/mm^3^, 8.26 × 10^3^/mm^3^) the mean WBC count in the vehicle control group (6.97 × 10^3^/mm^3^). Corresponding segmented neutrophil counts (Figure 8 and Table A1) were 1.8 times (1.75 × 10^3^/mm^3^) and 2.0 times (2.04 × 10^3^/mm^3^, P≤0.01) the mean neutrophil count of the vehicle controls (1.00 × 10^3^/mm^3^).

##### Female-A Mice

Administration of rifabutin alone to female-A mice had no impact on RBC, reticulocyte, or platelet counts. The MCV of the 640 mg/kg rifabutin group was 4% less (47.0 fL) than the mean MCV value of the vehicle control group (49.1 fL); however, this decrease in MCV was not by itself considered biologically significant.

There was a marked increase in the WBC count (Figure 7 and Table A2) of the 640 mg/kg rifabutin group. The mean WBC count of female-A mice administered 640 mg/kg rifabutin was 1.5 times (11.18 × 10^3^/mm^3^, P≤0.01) the mean in the vehicle controls (7.68 × 10^3^/mm^3^). Evaluation of the differential data revealed increases in both neutrophil and lymphocyte counts. The mean segmented neutrophil count (Figure 8 and Table A2) and lymphocyte count (Figure 9 and Table A2) of the 640 mg/kg group were, respectively, 1.5 times (3.85 × 10^3^/mm^3^, P≤0.05) and 1.4 times (6.70 × 10^3^/mm^3^) the corresponding counts of the vehicle control group. An increase in the number of large undifferentiated cells (LUC) was also observed in the 640 mg/kg group (0.25 × 10^3^/mm^3^, P≤0.01) compared to the vehicle control group (0.05 × 10^3^/mm^3^; Table A2). This increase in LUC may have occurred secondarily to the mild hematopoietic regenerative response with release of undifferentiated precursors or may have been associated with an atypical lymphoid or monocytoid population.

##### Female-B Mice

Administration of 80, 320, or 640 mg/kg rifabutin alone to female-B mice had no effect on any of the erythrocyte parameters evaluated with the exception of the reticulocyte count of the 640 mg/kg group (Table A3). The mean reticulocyte count of mice receiving 640 mg/kg rifabutin was 1.5 times (7.0 × 10^5^/mm^3^) that observed in the vehicle control group (4.6 × 10^5^/mm^3^). Although not statistically significant, this increase was considered biologically significant.

Platelet count also appeared to be increased in the 640 mg/kg group, with the mean platelet count for this group 1.3 times (1,644 × 10^3^/mm^3^) that of the vehicle control group (1,262 × 10^3^/mm^3^).

No effects on WBC counts or differentials were apparent in female-B groups treated with rifabutin alone.

#### AZT and Rifabutin Combinations

##### Male Mice

Administration of 200 or 400 mg/kg AZT + 80, 320, or 640 mg/kg rifabutin resulted in a treatment-related anemia of far greater severity than due to treatment with AZT alone. Respective mean RBC counts (Figure 5 and Table A1) of male mice treated with 200 mg/kg AZT + 80, 320, or 640 mg rifabutin were 14% (8.15 × 10^6^/mm^3^, P≤0.05), 26% (6.99 × 10^6^/mm^3^, P≤0.01), and 56% (4.13 × 10^6^/mm^3^, P≤0.01) lower than the mean RBC count of the vehicle control group (9.47 × 10^6^/mm^3^). For the groups treated with 400 mg/kg AZT + 80, 320, or 640 mg/kg rifabutin, the mean RBC counts were 22% (7.43 × 10^6^/mm^3^, P≤0.01), 36% (6.09 × 10^6^/mm^3^, P≤0.01), and 76% (2.31 × 10^6^/mm^3^, P≤0.01) lower than the mean count of the vehicle control group (9.47 × 10^6^/mm^3^). Hgb concentrations and Hct values paralleled the decreased RBC counts (Table A1).

With the exception of the 400 mg/kg AZT + 640 mg/kg rifabutin groups, macrocytic changes in erythrocytes were greater with administration of both AZT and rifabutin than with AZT alone. Increases in MCVs were apparent with 200 mg/kg AZT + 80 or 320 mg/kg rifabutin, with lesser increases apparent with 400 mg/kg AZT + 80 or 320 mg/kg rifabutin. Decreases in MCVs were apparent in the 400 mg/kg AZT + 640 mg/kg rifabutin groups. Mice treated with 200 mg/kg AZT + 80 or 320 mg/kg rifabutin had respective MCVs that were 6% (51.3 fL) and 13% (54.6 fL, P≤0.01) higher than the value of the vehicle controls (48.3 fL). The MCVs of the corresponding 400 mg/kg AZT + 80 or 320 mg/kg rifabutin groups had smaller changes in MCV with volumes 7% (51.8 fL) and 8% (52.2 fL) higher than that of the vehicle controls (48.3 fL). The high dose combination group had decreased MCVs compared to the increased MCVs observed in lower dose combination groups. The MCV for the 400 mg/kg AZT + 640 mg/kg rifabutin group was 18% lower (39.7 fL, P≤0.01) than that of the vehicle controls (48.3 fL). The marked decrease in MCVs of the 400 + 640 mg/kg group was also associated with a marked decrease in reticulocyte count, which was 76% lower (1.1 × 10^5^/mm^3^) than the mean for the vehicle control group (4.5 × 10^5^/mm^3^). Reticulocyte counts of other combination treatment groups tended to be increased above those observed in the vehicle controls. Counts of the 200 + 640 mg/kg group were 1.4 times (6.3 × 10^5^/mm^3^) that of the vehicle controls (4.5 × 10^5^/mm^3^), and counts of the 400 + 320 mg/kg group were 1.6 times (7.3 × 10^5^/mm^3^) that of the vehicle controls (4.5 × 10^5^/mm^3^). An additional change of a markedly increased mean cell hemoglobin concentration (MCRC) was evident in the group treated with the highest doses of both compounds, which was suggestive of hemolysis. The MCHC value was 1.5 times (40.1 g/dL, P≤0.01) the MCHC (34.9 g/dL) of the vehicle controls.

Combination administration of AZT and rifabutin caused treatment-related thrombocytosis. Respective mean platelet counts (Figure 6 and Table A1) of male mice administered 200 mg/kg AZT + 80, 320, or 640 mg/kg rifabutin were 1.5 times (1,439 × 10^3^/mm^3^), 1.5 times (1,497 × 10^3^/mm^3^, P≤0.05), and 1.9 times (1,921 × 10^3^/mm^3^, P≤0.01) the mean observed in the corresponding vehicle control group (992 × 10^3^/mm^3^). For the groups receiving 400 mg/kg AZT + 80, 320, or 640 mg/kg rifabutin, respective mean platelet counts were 1.7 times (1,693 × 10^3^/mm^3^, P≤0.01), 1.6 times (1,562 × 10^3^/mm^3^, P≤0.05), and 2.2 times (2,135 × 10^3^/mm^3^ P≤0.01) times the mean platelet count of the vehicle control group (992 × 10^3^/mm^3^).

No biologically significant changes in differential WBC counts occurred with administration of 200 mg/kg AZT + 80, 320, or 640 mg/kg rifabutin. Treatment-related decreases in WBC, neutrophil, and lymphocyte counts were observed in male mice treated with 400 mg/kg AZT + 320 or 640 mg/kg rifabutin. Respective mean WBC counts (Figure 7 and Table A1) of male mice receiving 400 mg/kg AZT + 320 or 640 mg/kg were 28% (5.04 × 10^3^/mm^3^) and 58% (2.92 × 10^3^/mm^3^) lower than the mean of the vehicle controls (6.97 × 10^3^/mm^3^). Neutrophil counts (Figure 8 and Table A1) of these same two groups were 7% (0.93 × 10^3^/mm^3^) and 26% (0.74 × 10^3^/mm^3^) lower than the vehicle control group mean (1.00 × 10^3^/mm^3^). Lymphocyte counts (Figure 9 and Table A1) of male mice administered 400 mg/kg AZT + 320 or 640 mg/kg rifabutin were, respectively, 32% (3.77 × 10^3^/mm^3^) and 63% (2.05 × 10^3^/mm^3^) lower than the mean lymphocyte count in the vehicle controls (5.53 × 10^3^/mm^3^). Significant alterations were not evident in other WBC differentials.

##### Female-A Mice

Administration of AZT and rifabutin to female-A mice resulted in severe anemia far greater than that subsequent to the administration of AZT alone. Respective mean RBC counts (Figure 5 and Table A2) of female mice receiving 200 mg/kg AZT + 80 or 320 mg/kg rifabutin were 19% (7.11 × 10^6^/mm^3^, P≤0.01) and 31% (5.99 × 10^6^/mm^3^, P≤0.01) lower than the vehicle controls (8.74 × 10^6^/mm^3^). Respective mean RBC counts of female-A mice administered 400 mg/kg AZT + 80 or 320 mg/kg rifabutin were 20% (6.96 × 10^6^/mm^3^, P≤0.01) and 67% (2.85 × 10^6^/mm^3^, P≤0.01) lower than the mean of the vehicle controls (8.74 × 10^6^/mm^3^). Female-A mice that received 200 or 400 mg/kg AZT + 640 mg/kg rifabutin did not survive, apparently because of the severity of the anemia. In general, Hgb concentrations and Hct values decreased in a manner similar to the decreasing RBC counts. Marked increases in MCV (greater than that observed with AZT alone) were observed in female-A mice administered 200 mg/kg AZT + 80 or 320 mg/kg rifabutin and in those administered 400 mg/kg AZT + 80 mg/kg rifabutin with respective MCVs 17% (57.3 fL, P≤0.01), 18% (58.0 fL, P≤0.01), and 16% (57.1 fL, P≤0.01) higher than the MCV of the vehicle control group (49.1 fL). This macrocytosis occurred without appreciable increases in reticulocyte counts of these groups, although a slightly increased count (1.3 times the vehicle control group count) was observed in the group administered 400 mg/kg AZT + 80 mg/kg rifabutin (5.4 × 10^5^/mm^3^). The MCV observed in the female-A mice administered 400 + 320 mg/kg had decreased towards a volume near normal. This group also had a marked decrease in reticulocyte count with the mean reticulocyte count 41% lower (2.4 × 10^5^/mm^3^) than that observed in the vehicle control group (4.1 × 10^5^/mm^3^). The MCHC of mice administered 400 + 320 mg/kg was slightly higher (36.3 g/dL) than the vehicle control group MCHC (34.1 g/dL), with two of three mice analyzed having MCHCs greater than the range observed in the vehicle control mice. In general, alterations in MCH values paralleled the changes in MCV.

Mild thrombocytosis (Figure 6 and Table A2) was present only in female-A mice administered 400 mg/kg AZT + 320 mg/kg rifabutin, with the mean platelet count 1.6 times (2,279 × 10^3^/mm^3^) that of the vehicle control group (1,382 × 10^3^/mm^3^).

WBC counts (Figure 7 and Table A2) were not appreciably different from the vehicle control group in female-A mice administered 200 mg/kg AZT + 80 or 320 mg/kg rifabutin. In mice administered 400 mg/kg AZT + 80 or 320 mg/kg rifabutin, WBC counts were moderately decreased, with respective mean WBC counts 31% (5.32 × 10^3^/mm^3^, P≤0.05) and 43% (4.34 × 10^3^/mm^3^) lower than in the vehicle controls (7.68 × 10^3^/mm^3^). Decreases in segmented neutrophil counts (Figure 8 and Table A2) were observed in all combination treatment groups of female-A mice, with respective neutrophil counts for the groups administered 200 mg/kg AZT + 80 or 320 mg/kg rifabutin and 400 mg/kg AZT + 80 or 320 mg/kg rifabutin, 55% (1.19 × 10^3^/mm^3^, P≤0.01), 37% (1.66 × 10^3^/mm^3^), 59% (1.07 × 10^3^/mm^3^, P≤0.01), and 65% (0.91 × 10^3^/mm^3^) lower than the mean count of the vehicle control group (2.62 × 10^3^/mm^3^). Biologically significant differences in other WBC differentials were not observed (Table A2).

##### Female-B Mice

Values for hematology parameters with variance and statistically significant differences are listed in Table A3. Slight decreases in RBC count were observed only in female-B mice administered 200 or 400 mg/kg AZT + 640 mg/kg rifabutin, with the respective mean RBC counts of these groups 10% (7.63 × 10^6^/mm^3^, P≤0.05) and 13% (7.33 × 10^6^/mm^3^, P≤0.01) lower than that of the corresponding vehicle controls (8.44 × 10^6^/mm^3^). While the other combination treatment groups of female-B mice did not exhibit significant changes in mean RBC counts, low individual RBC counts were present in all combination treatment groups, with the exception of 200 + 80 mg/kg. when counts were compared to the range of counts observed in the vehicle control group. In general, Hgb concentrations and Hct values paralleled RBC counts. In addition to low incidences of anemia in all combination treatment groups, MCVs were increased in all combination treatment groups in an apparent dose-related manner. The MCVs of female-B mice treated with 200 mg/kg AZT + 80, 320, or 640 mg/kg rifabutin were, respectively. 5% (54.0 fL), 6% (54.7 fL, P≤0.01). and 10% (56.6 fL, P≤0.01) higher than the vehicle control MCV (51.4 fL). The MCVs of mice treated with 400 mg/kg AZT + 80, 320, or 640 mg/kg rifabutin were 4% (53.4 fL), 6% (54.4 fL, P≤0.05), and 12% (57.4 fL, P≤0.01) higher than that of the vehicle control group (51.4 fL). In general, a slight increase in reticulocyte numbers paralleled the increase in MCV. In female-B mice administered 200 mg/kg AZT + 320 or 640 mg/kg rifabutin, mean reticulocyte counts were 1.2 times (5.7 × 10^5^/mm^3^) and 1.6 times (7.3 × 10^5^/mm^3^) that of the vehicle controls (4.6 × 10^5^/mm^3^). In mice administered 400 mg/kg AZT + 80, 320, or 640 mg/kg rifabutin, mean reticulocyte counts were, respectively, 1.2 times (5.5 × 10^5^/mm^3^), 1.6 times (7.4 × 10^5^/mm^3^), and 2.0 times (9.0 × 10^5^/mm^3^) that of the vehicle controls (4.6 × 10^5^/mm^3^). There were marginal changes in MCHC in some of the combination treatment groups, and they were not considered biologically significant.

Platelet counts were appreciably increased only in combination treatment groups treated with 200 or 400 mg/kg AZT + 640 mg/kg rifabutin, with respective mean platelet counts 1.3 times (1,608 × 10^3^/mm^3^) and 1.4 times (1,786 × 10^3^/mm^3^) the vehicle controls (1,262 × 10^3^/mm^3^).

Increases in mean WBC count were observed in female-B mice administered 200 + 640 mg/kg and in groups administered 400 mg/kg AZT + 320 or 640 mg/kg rifabutin, and were 1.3 times (6.40 × 10^3^/mm^3^), 1.4 times (6.71 × 10^3^/mm^3^), and 1.7 times (8.46 × 10^3^/mm^3^) higher than counts of the vehicle control group (4.92 × 10^3^/mm^3^). Slight increases in segmented neutrophil count and lymphocyte count accompanied increases in WBC count, with the maximum change observed in the 400 + 640 mg/kg group. Mean neutrophil and lymphocyte counts in this group were 2.1 times (2.27 × 10^3^/mm^3^) and 1.6 times (5.63 × 10^3^/mm^3^) higher than the corresponding counts observed in vehicle control group (1.06 × 10^3^/mm^3^, 3.54 × 10^3^/mm^3^). Other differential counts were either unchanged (basophils, LUC) or slightly increased (monocytes, eosinophils).

#### Hematology Summary

Treatment with AZT alone resulted in mild anemia in both male and female mice with macrocytic changes of the erythrocytes and no appreciable changes in reticulocyte numbers. The changes in erythrocyte parameters were most prominent in the female-A mice and less prominent in the males with few changes in the female-B mice. This pattern of response parallels the duration of treatment with the female-A mice having received AZT for the longest period (28 to 32 days) of time and the female-B mice having received AZT for the shortest period (10 days). The greater effect of prolonged treatment on RBC counts is due to both the short life span (approximately 30 days) of erythrocytes in mice (Jain, 1986) and possibly also due to a cumulative effect of AZT. Macrocytosis, as observed in this study, is a common observation in humans treated with AZT (Snower and Weil, 1993). The etiology for this macrocytosis is uncertain, but AZT may cause a drug-induced macrocytosis by inhibition of thymidylate kinase (via AZT monophosphate) with decreased levels of thymidine triphosphate available for DNA synthesis, or by inhibition of mammalian DNA polymerase which occurs at a 100-fold greater concentration of AZT than that necessary to inhibit reverse transcriptase (Herzlich et al., 1990; Snower and Weil, 1993). In male mice, the mild anemia observed with AZT was accompanied by histopathologic observations of splenic hematopoietic cell proliferation in both the 200 and 400 mg/kg AZT treatment groups. This indicates a mild regenerative stimulus is present, even though reticulocytosis was not evident.

The sporadic mild thrombocytosis observed in all three groups is probably due to the overall mild regenerative response present and probably indicates a lesser effect of AZT alone on platelet production than on RBC production. The decreases in WBC, neutrophil, and lymphocyte counts observed in males and female-A mice and the lack of such an effect in the female-B mice suggest a mild duration of treatment-related cumulative effect of AZT on production of neutrophils and lymphocytes.

In evaluating the results from all three groups of mice treated with rifabutin alone, rifabutin was associated with slightly decreasing RBC counts (male mice only) and increasing reticulocyte counts (male and female-B mice), and decreasing mean cell volumes (male and female-A mice) at the high doses of rifabutin only. These results suggest that rifabutin alone causes a mild normocytic regenerative anemia at lower doses; however, at 640 mg/kg, either peripheral destruction of erythrocytes or altered hematopoiesis leads to production of smaller erythrocytes. The sporadic increases in platelet counts observed in male and female-B mice administered rifabutin alone are compatible with an overall nonspecific response to a regenerative stimulus. Splenic hematopoietic cell hyperplasia was observed in all three rifabutin groups in male mice, indicating that a regenerative stimulus was present.

The mild leukocytosis and neutrophilia observed in male and female-B mice groups administered rifabutin alone may have been due to the overall regenerative stimulus; however, they may also have been due to an inflammatory stimulus. Bone marrow myeloid hyperplasia was observed in a small number of male mice and is consistent with lung and sporadic liver mixed cell infiltrates observed in male mice in the 320 and 640 mg/kg rifabutin groups. These inflammatory foci may have been associated with the leukocyte responses. In female-A mice administered rifabutin alone, mixed cell infiltrates in the liver were also present in a majority of the 640 mg/kg group, and some of the mice in the 320 mg/kg rifabutin group. Additionally, chronic active inflammation observed histopathologically in the stomach in 11 of 17 female mice in the 640 mg/kg group may also have contributed to an inflammatory response.

The hematologic changes that occurred with the combination of AZT and rifabutin indicated a more severe anemia with the combination therapy than with either compound alone. The hematopoietic toxicity observed with combination therapy was both dose- and duration-of-treatment-dependent. The female-A mice, which were administered AZT and rifabutin for the longest period (28 to 32 days), exhibited the most severe anemia. The female-B mice, which were administered the combination of AZT and rifabutin for only 10 days, exhibited the smallest changes in erythrocyte counts. The MCV increased early in lower dose combination groups and decreased late in higher dose combination groups. These changes indicate that dysplastic erythropoiesis was occurring, with a regenerative stimulus present at early time points and at low dose combinations, but not at high dose combination treatments. This and the decrease in reticulocyte count observed with time and increased dose suggest a cumulative effect of the combination of AZT and rifabutin. At the higher dose combinations, the microcytic erythrocytic changes observed could also indicate a hemolytic component, which is also suggested by the increased MCHCs; however, the primary component was considered to be erythroid hypoplasia. Splenic hematopoietic cell proliferation and erythroid depletion of the bone marrow was observed in male mice administered 200 or 400 mg/kg AZT + 320 or 640 mg/kg rifabutin, further indicating more severe hematopoietic toxicity.

The mild leukopenia and decreases in neutrophil and lymphocyte counts observed in male mice treated with AZT and rifabutin occurred in spite of the presence of mixed cell infiltrates in the lung, liver, and stomach observed histologically. This suggests that the mice were not able to mount an appropriate response to the inflammatory stimulus due to hematopoietic cell damage. In female-A mice, mixed cell infiltrates were also prominent in the liver and stomach of some of the combination therapy groups, concurrent with leukopenia.

### Clinical Chemistry

#### AZT Alone

Values for clinical chemistry parameters with variance and statistically significant differences are listed in Tables A4 and A5. Evidence of liver toxicity was not observed with administration of 200 or 400 mg/kg AZT in male mice. Slight nonspecific increases in mean alkaline phosphatase (ALP) activities were observed in female-A mice, with mean ALP activities of 200 and 400 mg/kg AZT groups both 1.4 times (71 IU/L, 74 IU/L) the ALP activity of the vehicle control group (52 IU/L). This was not considered to be treatment related due to the lack of a dose-related effect and the lack of consistent corresponding hepatic lesions in these mice.

#### Rifabutin Alone

No evidence of liver toxicity was observed with 80 mg/kg rifabutin in either male or female mice. Treatment-related increases in mean alanine aminotransferase (ALT) activity were observed in male and female-A mice treated with 320 or 640 mg/kg rifabutin. The mean ALT activities of male mice in the 320 and 640 mg/kg rifabutin groups were 1.3 times (35 IU/L) and 2.5 times (65 IU/L) the mean ALT activity of the corresponding vehicle control group (26 IU/L). In female-A mice, the ALT activities for the 320 and 640 mg/kg rifabutin groups were 1.9 times (75 IU/L, P≤0.05) and 4.1 times (159 IU/L, P≤0.01) the mean ALT activity of the vehicle control group (39 IU/L). Accompanying these changes in female-A mice were increases in mean aspartate aminotransferase (AST) activity and mean bile acid concentration (Figure 10 and Table A5) of the 640 mg/kg rifabutin group, with values 1.7 (200 IU/L) and 2.1 (31 μM/L, P≤0.01) times the corresponding vehicle control values (118 IU/L, 15 μM/L).

In mice administered rifabutin alone, changes in ALT and AST activities and mean bile acid concentrations were considered to be related to the histopathologic changes of mixed cell inflammation and possibly focal necrosis in the liver, even though not all mice with histopathologic changes had alterations in clinical chemistry parameters. The slight decreases in Hct concentration observed in mice administered rifabutin alone were not sufficient to lead to tissue anoxia and contribute to the changes in liver enzyme activity or bile acid concentrations.

#### AZT and Rifabutin Combinations

No evidence of liver toxicity was observed in the 200 + 80 mg/kg groups of male and female-A mice. Male mice in the 400 + 80 mg/kg group had a mean sorbitol dehydrogenase (SDH) activity 1.4 times the mean SDH activity of the vehicle control group; however, this was not considered biologically significant as only one of nine mice had increased SDH values as compared to the range observed in vehicle controls. Female mice in the 400 + 80 mg/kg group had no changes in clinical chemistry parameters suggestive of liver toxicity.

Male mice receiving 200 or 400 mg/kg AZT + 320 mg/kg rifabutin had mean ALT activities 1.4 times (36 IU/L) and 1.6 times (41 IU/L) the vehicle control group (26 IU/L). SDH activity was also increased in the 400 + 320 mg/kg group, with mean SDH activity 1.5 times (30 IU/L) the mean SDH activity observed in vehicle controls (20 IU/L). In female-A mice in the 200 + 320 mg/kg group, the mean ALT activity was 2.5 times (97 IU/L, P≤0.01) that of vehicle control group (39 IU/L), and the total bile acid concentration (Figure 10) was 1.7 times (25 μM/L) that of the vehicle control group (15 μM/L). Two of three female mice in the 400 + 320 mg/kg group, which had survived to hematology sampling, had increased ALP activities and total bile acid concentrations (Figure 10 and Table A5) when compared to the ranges in the vehicle control group. Mean values for ALP activity and total bile acid concentration in this group were 1.6 times (82 IU/L) and 4.0 times (60 μM/L, P≤0.01) that of the vehicle control group (52 IU/L, 15 μM/L).

FIGURE 10 Mean Bile Acid Values for Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations (*=data not available due to mortality. For variance and statistically significant differences, see Tables A4 and A5.)

Male mice in the 200 or 400 mg/kg AZT + 640 mg/kg rifabutin groups had increases in total bile acid concentration (Figure 10 and Table A4). Mean total bile acid concentrations of these two groups were 3.6 times (54 μM/L, P≤0.01) and 3.2 times (48 μM/L, P≤0.05) that of the vehicle control group (15 μM/L). Data were not available from female-A mice treated with AZT + 640 mg/kg rifabutin because of early mortality.

Administration of 200 or 400 mg/kg AZT + 80 mg/kg rifabutin was not associated with any significant changes in liver enzyme activity or bile acid concentration. Administration of 200 mg/kg AZT + 320 or 640 mg/kg rifabutin was associated with similar or lower increases in ALT activity than observed with rifabutin alone. The reason for this is not clear. Male mice, but not female mice, had increases in SDH activities with combination treatment. Consistent increases in bile acid concentration were observed in males treated with 200 or 400 mg/kg AZT + 640 mg/kg rifabutin and in female mice treated with 200 or 400 mg/kg AZT + 320 mg/kg rifabutin. The increases in liver enzyme activity were consistent with histopathologically observed liver pathology of mixed cell infiltration and possibly focal necrosis. The increases in mean bile acid concentration in AZT/rifabutin groups may have been due to greater incidences of severe anemia in these groups. Severe anemia could have led to tissue anoxia, which would correspond with the centrilobular atrophy observed histopathologically in the higher dose combination treatment groups. Since an increase in mean bile acid concentration was also observed with administration of rifabutin alone in females in the 640 mg/kg rifabutin group, and other enzyme activity values were affected, the anemia does not account for all of the changes in hepatic enzyme and bile acid activities observed in AZT/rifabutin combination treatment or rifabutin alone.

### Plasma AZT, GAZT, and Rifabutin Concentrations

Plasma concentrations of AZT, AZT-β-D-glucuronide (GAZT), and rifabutin in male and female-A mice determined at 15 to 90 minutes after the last dose are listed in Table 4. In male mice that received AZT at 400 mg/kg with rifabutin at 320 or 640 mg/kg, plasma concentrations of AZT and GAZT appeared to have increased when coadministered with 640 mg/kg of rifabutin as compared to the concentrations when coadministered with 320 mg/kg of rifabutin (Figure 11). In male mice that received rifabutin at 320 mg/kg, the plasma concentrations of rifabutin appeared to be similar with or without AZT coadministration. However, at 640 mg/kg of rifabutin, the plasma concentrations of rifabutin appeared to have increased when coadministered with AZT (Figure 13). Thus, in male mice there appear to be an interaction between AZT at 400 mg/kg and rifabutin at 640 mg/kg causing increases in plasma concentrations of both compounds. In female-A mice coadministration of 400 mg/kg of AZT with 80 and 320 mg/kg of rifabutin did not appear to affect the plasma concentrations of AZT, GAZT (Figure 12) or rifabutin (Figure 14). Results on the effect of coadministration of AZT at 400 mg/kg with rifabutin at 640 mg/kg are not available due to early mortality of female-A mice.

TABLE 4 Mean Concentrations of AZT, GAZT, and Rifabutin (μg/mL) in Plasma for Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

| AZT Sample Time (minutes) | | | | GAZT Sample Time (minutes) | | | | Rifabutin Sample Time (minutes)
Dose^a^ | 15 | 30 | 60 | 90 | 15 | 30 | 60 | 90 | 15 | 30 | 60 | 90
Male
0 + 320 | 0.153 | ND^b^ | 0.089 | ND | ND | ND | ND | ND | 11.1 | 12.8 | 15.9 | 15.7
0 + 640 | 0.121^c^ | ND | 0.102^c^ | ND | ND | ND | ND | ND | 9.5 | 13.8 | 15.2 | 26.5
400 + 320 | 71.8 | 68.7 | 38.1 | 14.2 | 1.03 | 1.63 | 0.740 | 0.161 | 10.9 | 12.1 | 19.8 | 14.1
400 + 640 | 91.5 | 77.1 | 62.5 | 27.9 | 1.55 | 1.62 | 1.29 | 0.398 | 15.3 | 27.6 | 29.5 | 24.0
Female-A
0 + 80 | 0.088 | ND | 0.994^c^ | ND | ND | ND | ND | ND | 4.57 | 5.06 | 5.62 | 5.65
0 + 320 | ND | 0.204 | 0.817^c^ | ND | ND | ND | ND | ND | 10.2 | 11.0 | 14.6 | 20.8
0 + 640 | 0.152 | 0.152^c^ | 0.696 | 0.155^c^ | ND | ND | ND | ND | 9.67 | 12.3 | 18.7 | 14.5
400 + 80 | 101.7 | 74.9 | 86.4 | 37.4 | 0.598 | 0.719 | 1.27 | 0.273 | 4.56 | 5.31 | 8.01 | 7.37
400 + 320 | 83.5 | 82.3 | 78.8 | 52.4 | 0.587 | 0.766 | 1.24 | 0.462 | 8.57 | 11.8 | 15.7 | 20.1

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b ND=Not detected; estimated detection limit for AZT=0.042; estimated detection limit for GAZT=0.078

c AZT concentration is based upon the value for one animal/time point; AZT was not detected in the sample from the other animal at the same time point.

FIGURE 11 Plasma Concentrations of AZT and GAZT for Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

FIGURE 12 Plasma Concentrations of AZT and GAZT for Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

FIGURE 13 Plasma Concentrations of Rifabutin for Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

FIGURE 14 Plasma Concentrations of Rifabutin for Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

## Necropsy Observations

Gross lesions attributed to treatment with AZT, rifabutin, and AZT + rifabutin were seen in male, female-A, and female-B mice. Treatment-related lesions in male mice consisted of red carcass, small thymus, small spleen, enlarged spleen, mottled stomach, and foci in the stomach. Treatment-related lesions in female-A mice consisted of red carcass, small thymus, small spleen, enlarged spleen, mottled stomach, foci in the stomach, thick stomach, red stomach, and dilatation of the gallbladder. Red carcass was found only in male and female-A mice treated with rifabutin alone or AZT + rifabutin. Treatment-related lesions in female-B mice consisted of small thymus, enlarged spleen, and thick stomach. Nodular bone lesions, which involved the ventral aspect of the thoracic vertebrae or ribs near their junction with the vertebrae, were observed in most male and female-A mice and a few female-B mice. This lesion was attributed to mechanical irritation caused by the gavage needle during dosing. The remaining gross lesions were considered to be incidental or spontaneous.

## Histopathologic Observations

Photomicrographs of representative treatment-related lesions in adult mice (with accompanying summary, Table 5) are shown in Plates 1 through 17.

TABLE 5 Summary of Microscopic Examinations of Compound-Related Lesions in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Dose and Treatment Group^a^ | Tissue | Magnification | Plate Number | Treatment-Related Lesions
0 + 0, male | Liver | 160× | 1 | None
400 + 640, male | Liver | 160× | 2 | Hepatocellular cytoplasmic alteration, centrilobular atrophy
0 + 640, female-A | Liver | 400× | 3 | Mixed cellular infiltration
0 + 0, male | Spleen | 160× | 4 | None
400 + 640, male | Spleen | 160× | 5 | Hematopoietic cell proliferation
400 + 640, male | Spleen | 160× | 6 | Atrophy of red pulp and lymphoid follicles
0 + 0, male | Thymus | 160× | 7 | None
400 + 640, male | Thymus | 160× | 8 | Thymic atrophy
0 + 0, male | Mesenteric lymph node | 160× | 9 | None
400 + 640, male | Mesenteric lymph node | 160× | 10 | Atrophy of lymphoid cells
0 + 0, male | Bone marrow | 160× | 11 | None
0 + 640, male | Bone marrow | 160× | 12 | Myeloid cell hyperplasia
400 + 640, male | Bone marrow | 160× | 13 | Depletion of erythroid cells
0 + 0, male | Glandular stomach | 160× | 14 | None
0 + 640, male | Glandular stomach | 160× | 15 | Cystic degeneration
0 + 0, male | Forestomach | 160× | 16 | None
400 + 640, male | Forestomach | 160× | 17 | Epithelial hyperplasia, chronic active inflammation

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

### Treatment-Related Lesions

#### AZT

Treatment-related lesions were seen in the liver of male and female-A mice and in the spleen of male mice. The treatment-related liver change (Tables 6 and 7) observed in male and female mice was designated “cytoplasmic alteration, hepatocyte.” This consisted of a homogeneous, eosinophilic appearance of the hepatocellular cytoplasm and was suggestive of the absence of normally occurring glycogen. This morphologic alteration evident in hepatocytes likely represents a physiological response to diminished food intake (Harada et al., 1999) and weight loss as opposed to a direct cellular response to the test article. The change was present primarily in the centrilobular areas. Hepatocellular cytoplasmic alteration was graded for severity based on the following criteria:

- Minimal - approximately 15% or less of hepatocytes with cytoplasmic alteration
- Mild - approximately 16% to 50% of hepatocytes with cytoplasmic alteration
- Moderate - approximately 51% to 90% of hepatocytes with cytoplasmic alteration
- Marked - approximately 91% to 100% of hepatocytes with cytoplasmic alteration

PLATE 1 Liver of a vehicle control male Swiss (CD-1®) mouse showing no lesions. H&E; 160 x

PLATE 2 Liver of a male Swiss (CD-1®) mouse given 400 mg AZT + 640 mg rifabutin per kg body weight per day by gavage for 3 weeks showing hepatocellular cytoplasmic alteration and centrilobular atrophy. H&E; 160x

PLATE 3 Liver of a female Swiss (CD-1®) mouse given 640 mg rifabutin per kg body weight per day by gavage for 4 weeks showing mixed cellular infiltration around central vein. Phagocytic cells contain intracytoplasmic pigment (arrow). H&E; 400 x

PLATE 4 Spleen of a vehicle control male Swiss (CD-1®) mouse showing no lesions. H&E; 160 X

PLATE 5 Spleen of a male Swiss (CD-1®) mouse given 400 mg AZT + 640 mg rifabutin per kg body weight per day by gavage for 3 weeks showing hematopoietic cell proliferation. H&E; 160 x

PLATE 6 Spleen of a male Swiss (CD-1®) mouse given 400 mg AZT + 640 mg rifabutin per kg body weight per day by gavage for 3 weeks showing atrophy of red pulp and lymphoid follicles. H&E; 160 x

PLATE 7 Thymus of a vehicle control male Swiss (CD-1®) mouse showing no lesions. H&E; 160 x

PLATE 8 Thymus of a male Swiss (CD-1®) mouse given 400 mg AZT + 640 mg rifabutin per kg body weight per day by gavage for 3 weeks showing thymic atrophy. H&E; 160 x

PLATE 9 Mesenteric lymph node of a vehicle control male Swiss (CD-1®) mouse showing no lesions. H&E; 160 x

PLATE 10 Mesenteric lymph node of a male Swiss (CD-1®) mouse given 400 mg AZT + 640 mg rifabutin per kg body weight per day by gavage for 3 weeks showing atrophy of lymphoid cells. H&E; 160 x

PLATE 11 Bone marrow of a vehicle control male Swiss (CD-1®) mouse showing no lesions. H&E; 160 x

PLATE 12 Bone marrow of a male Swiss (CD-1®) mouse given 640 mg rifabutin per kg body weight per day by gavage for 3 weeks showing myeloid cell hyperplasia. H&E; 160 x

PLATE 13 Bone marrow of a male Swiss (CD-1®) mouse given 400 mg AZT + 640 mg rifabutin per kg body weight per day by gavage for 3 weeks showing depletion of erythroid cells. H&E; 160 x

PLATE 14 Glandular stomach of a vehicle control male Swiss (CD-1®) mouse showing no lesions. H&E; 160 x

PLATE 15 Glandular stomach of a male Swiss (CD-1®) mouse given 640 mg rifabutin per kg body weight per day by gavage for 3 weeks showing cystic degeneration. H&E; 160 x

PLATE 16 Forestomach of a vehicle control male Swiss (CD-1®) mouse showing no lesions. H&E; 160 x

PLATE 17 Forestomach of a male Swiss (CD-1®) mouse given 400 mg AZT + 640 mg rifabutin per kg body weight per day by gavage for 3 weeks showing epithelial hyperplasia and chronic active inflammation. H&E; 160 x

Although hepatocellular cytoplasmic alteration was seen in male and female vehicle control mice, the incidences were increased in male and female mice receiving 200 or 400 mg/kg AZT. The increased incidences of hepatocellular cytoplasmic alteration were not dose related in male or female mice.

A treatment-related increase in the incidences of splenic hematopoietic cell proliferation was seen in male mice (spleen was not examined histopathologically in the female-A mice), although the incidences were not dose related. Splenic hematopoietic cell proliferation was graded for severity based on the following criteria:

- Minimal - approximately 15% or less of red pulp occupied by hematopoietic cells
- Mild - approximately 16% to 50% of red pulp occupied by hematopoietic cells
- Moderate - approximately 51% to 90% of red pulp occupied by hematopoietic cells
- Marked - approximately 91% to 100% of red pulp occupied by hematopoietic cells

TABLE 6 Incidence and Mean Severity of Histopathologic Alterations in the Liver of Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

| Lesion^b^
| Cytoplasmic Alteration | | Mixed Cellular Infiltration | | Centrilobular Atrophy
Dose^a^ | Male^c^ | Female-A^d^ | Male^c^ | Female-A^d^ | Male^c^ | Female-A^d^
0 + 0 | 1 (2.0) | 3 (2.0) | 0 | 0 | 0 | 0
0 + 80 | 5 (2.6) | 8 (2.3) | 0 | 0 | 0 | 0
0 + 320 | 5 (2.8) | 9 (2.6) | 1 (2.0) | 7 (1.0) | 0 | 0
0 + 640 | 7 (2.4) | 4 (2.5) | 9 (1.2) | 16 (1.5) | 0 | 0
200 + 0 | 7 (2.1) | 8 (2.1) | 0 | 0 | 0 | 0
200 + 80 | 4 (2.3) | 12 (2.3) | 0 | 0 | 0 | 0
200 + 320 | 6 (2.7) | 6 (3.2) | 0 | 10 (1.0) | 0 | 5 (1.8)
200 + 640 | 8 (2.3) | 20 (3.0) | 5 (1.2) | 0 | 0 | 17 (1.5)
400 + 0 | 5 (2.2) | 5 (2.6) | 0 | 0 | 0 | 0
400 + 80 | 6 (2.3) | 7 (2.9) | 0 | 1 (1.0) | 0 | 0
400 + 320 | 6 (2.3) | 15 (3.0) | 1 (1.0) | 0 | 0 | 13 (1.8)
400 + 640 | 10 (3.0) | 16 (3.0) | 10 (1.3) | 2 (1.0) | 5 (1.8) | 14 (1.9)

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b Incidence (number of animals with lesion) followed by the mean severity (which is based on the numeric scale of 1 = minimal, 2=mild, 3= moderate, 4=marked) for the animals with the lesion

c n= 10

d n=20

TABLE 7 Statistical Analysis of Mean Severity of Hepatocyte Cytoplasmic Alteration in the Liver of Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

| Mean Severity^b^
Dose^a^ | Male^c^ | Female-A^d^
0 + 0 | 0.20 ± 0.20 | 0.30 ± 0.16
0 + 80 | 1.30 ± 0.47 | 0.90 ± 0.26
0 + 320 | 1.40 + 0.50 | 1.15 ± 0.31^*^
0 + 640 | 1.70 ± 0.40^*^ | 0.50 ± 0.24
200 + 0 | 1.50 ± 0.34 | 0.85 ± 0.24
200 + 80 | 0.90 ± 0.38 | 1.35 ± 0.26
200 + 320 | 1.60 ± 0.48 | 0.95 ± 0.34
200 + 640 | 1.80 ± 0.33 | 2.95 + 0.15^**^
400 + 0 | 1.10 ± 0.38 | 0.65 ± 0.26
400 + 80 | 1.40 ± 0.40 | 1.00 ± 0.32
400 + 320 | 1.40 ± 0.43 | 2.25 ± 0.33^**^
400 + 640 | 3.00 + 0.15^**^ | 2.40 ± 0.32^**^

* Significantly different (P≤0.05) from the vehicle control group by Jonckheere’s, Williams’, or Dunnett’s tests

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b Data are presented as mean ± standard error for all animals in the dose group; mean severity is based on the numeric scale of 1=minimal, 2= mild, 3 =moderate, 4=marked

c n= 10

d n=20

The splenic hematopoiesis involved primarily the erythropoietic cells and may have been a compensatory response to mild anemia in the AZT-treated mice. Incidences of the splenic alterations are listed in Table 8, and results of statistical analysis are presented in Table 9 and illustrated graphically in Figure 15.

#### Rifabutin Alone

Treatment-related lesions were seen in the liver, glandular stomach, bone marrow, spleen, and lung of male mice and in the liver, forestomach, glandular stomach, and thymus of female-A mice (bone marrow, spleen, and lung were not examined histopathologically in female mice).

Treatment-related liver alterations consisted of hepatocellular cytoplasmic alteration and mixed inflammatory cell infiltrate in male and female-A mice (Tables 6 and 7). The morphologic appearance and the criteria for severity grading of cytoplasmic alteration were similar to those described for mice treated with AZT. Although hepatocellular cytoplasmic alteration was seen in male and female vehicle control mice, the incidences of this lesion were increased in all three rifabutin-treated groups compared with the vehicle control groups. The incidences ofcytoplasmic alteration were dose related in male mice but not in female-A mice. As with the mice treated with AZT alone, this morphologic alteration in the cytoplasm of hepatocytes likely represents a physiologic response to decreased feed consumption and concurrent body weight loss instead of a direct toxic response to rifabutin.

TABLE 8 Incidence and Mean Severity of Histopathologic Alterations in the Spleen of Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

| Lesion^b^
Dose^a^ | Hematopoietic Cell Proliferation | Lymphoid Follicle Atrophy | Red Pulp Atrophy | Pigmentation
0 + 0 | 0 | 0 | 0 | 0
0 + 80 | 3 (1.7) | 0 | 0 | 0
0 + 320 | 10 (2.5) | 0 | 0 | 0
0 + 640 | 10 (2.7) | 0 | 0 | 0
200 + 0 | 8 (2.0) | 0 | 0 | 0
200 + 80 | 8 (1.8) | 0 | 0 | 0
200 + 320 | 10 (2.6) | 0 | 0 | 5 (2.0)
200 + 640 | 6 (3.2) | 2 (1.5) | 3 (2.0) | 4 (2.3)
400 + 0 | 7 (1.9) | 0 | 0 | 0
400 + 80 | 9 (2.3) | 0 | 0 | 0
400 + 320 | 7 (3.0) | 0 | 2 (2.0) | 2 (2.5)
400 + 640 | 2 (4.0) | 5 (2.2) | 8 (2.1) | 8 (2.6)

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b Incidence (number of animals with lesion; n=10) followed by the mean severity (which is based on the numeric scale of 1=minimal; 2=mild; 3=moderate; 4=marked) for the animals with the lesion

TABLE 9 Statistical Analysis of Mean Severity of Splenic Hematopoietic Cell Proliferation in Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Dose^a^ | Mean Severity^b^
0 + 0 | 0.00
0 + 80 | 0.50 ± 0.27
0 + 320 | 2.50 ± 0.17^**^
0 + 640 | 2.70 ± 0.15^**^
200 + 0 | 1.60 ± 0.34
200 + 80 | 1.40 ± 0.31
200 + 320 | 2.60 ± 0.16
200 + 640 | 1.90 ± 0.59
400 + 0 | 1.30 ± 0.34
400 + 80 | 2.10 ± 0.31
400 + 320 | 2.10 ± 0.50
400 + 640 | 0.80 ± 0.53

** Significantly different from the control group (P≤0.01) by Jonckheere’s and Williams’ or Dunnett’s tests

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b Data are presented as mean ± standard error for all animals in the dose group; mean severity is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked; n=10

FIGURE 15 Severity of Splenic Hematopoietic Cell Proliferation Versus Dose in Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Mixed cellular infiltration in the liver consisted of macrophages, small mononuclear cells, and occasional neutrophils within the liver parenchyma, with the heaviest aggregations often occurring adjacent to the interlobular and central veins. Mixed cellular infiltration was graded for severity based on the following criteria:

- Minimal - up to approximately 20 mixed inflammatory cells in any 100× magnification field with inflammatory cells confined almost exclusively to perivascular areas
- Mild - approximately 21 to 50 mixed inflammatory cells in any 100× magnification field with inflammatory cells primarily bordering blood vessels but occasionally occurring throughout liver parenchyma
- Moderate - approximately 51 to 150 mixed inflammatory cells in any 100× magnification field with inflammatory cells occurring in significant numbers throughout the liver parenchyma as well as in perivascular areas.

The infiltrating macrophages frequently contained a reddish-brown homogeneous to finely granular intracytoplasmic pigment. The pigment was not identified, but it may have represented macrophage-sequestered rifabutin or a metabolite. The hepatic mixed cellular infiltration may have represented a host defense mechanism whereby rifabutin and/or metabolites were phagocytized and eliminated by inflammatory cells.

A compound-related glandular stomach lesion seen in male and female mice was designated “cystic degeneration” (Table 10), which consisted of varying numbers of dilated mucosal glands appearing as mucosal cysts. The mucosal cysts often contained cellular detritus and amorphous proteinaceous material, and the surrounding glandular epithelium varied in appearance from hyperplastic or hypertrophied to flattened or squamous.

TABLE 10 Incidence and Mean Severity of Histopathologic Alterations in the Glandular Stomach of Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

| Lesion^b^
Dose^a^ | Cystic Degeneration | | Chronic Active Inflammation
| Male | Female-A | Male | Female-A
0 + 0 | 0/10 | NA | 0/10 | NA
0 + 640 | 10/10 (2.6) | 16/17 (2.5) | 1/10 (2.0) | 11/17 (2.2)
200 + 320 | 1/1 (3.0) | NA | 0/1 | NA
200 + 640 | 10/10 (2.8) | 20/20 (3.3) | 3/10 (2.0) | 4/20 (2.0)
400 + 320 | 1/1 (2.0) | NA | 0/1 | NA
400 + 640 | 10/10 (3.0) | 20/20 (3.2) | 1/10 (3.0) | 7/20 (2.0)

NA=Not examined (tissues were not required to be examined unless gross lesions were present)

a Daily gavage doses of AZT + rifabutin (mg/kg per day); AZT alone, other doses of rifabutin alone, and AZT + 80 mg/kg rifabutin did not cause histopathologic alterations in the stomach

b Incidence (number of animals with lesion) followed by the mean severity (which is based on the numeric scale of 1=minimal; 2=mild; 3=moderate; 4=marked) for the animals with the lesion

Cystic degeneration of the glandular stomach was graded for severity based on the following criteria:

- Minimal - a few dilated mucosal glands that do not exceed approximately 50 μm in diameter
- Mild - dilatation of approximately 50 to 100 μm involving up to approximately 5% of mucosal glands
- Moderate - dilatation of approximately 101 to 300 μm involving up to approximately 10% of mucosal glands
- Marked - dilatation of approximately 301 to 500 μm or greater involving up to approximately 30% of mucosal glands

In the female mice, and less frequently in the males, chronic active inflammation (Table 10), characterized by infiltration of neutrophils, lymphocytes, and macrophages, was present within the mucosa and submucosa of the glandular stomach. Chronic active inflammation of the glandular stomach was graded for severity based on the following criteria:

- Minimal - up to approximately 20 inflammatory cells in any 100× magnification field (considered background change and not diagnosed)
- Mild - approximately 21 to 100 inflammatory cells in any 100× magnification field
- Moderate - approximately 101 to 500 inflammatory cells in any 100× magnification field

Faintly staining, reddish-brown pigment similar to that seen in liver macrophages was occasionally visible within the cytoplasm of the infiltrating macrophages.

Compound-related forestomach epithelial hyperplasia (Table 11) was observed in both male and female mice but was more prominent in females. Epithelial hyperplasia of the forestomach was graded for severity based on the following criteria:

- Minimal - mucosal thickness (including keratin layer) of approximately 60 to 200 μm
- Mild - mucosal thickness of approximately 201 to 500 μm
- Moderate - mucosal thickness of approximately 501 to 1,000 μm
- Marked - mucosal thickness of approximately 1,001 μm or greater

The forestomach hyperplasia in one female mouse that received 640 mg/kg rifabutin was accompanied by chronic active inflammation (Table 11), which was also considered to be compound related. Criteria for severity grading were similar to those used for inflammation of the glandular stomach.

TABLE 11 Incidence and Mean Severity of Histopathologic Alterations in the Forestomach of Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin

| Lesion^b^
Dose^a^ | Epithelial Hyperplasia | | Ulcer | | Chronic Active Inflammation
| Male | Female-A | Male | Female-A | Male | Female-A
0 + 0 | 0/10 | NA | 0/10 | NA | 0/10 | NA
0 + 640 | 0/10 | 4/17 (1.8) | 0/10 | 0/17 | 0/10 | 1/17 (2.0)
200 + 320 | NA | NA | NA | NA | NA | NA
200 + 640 | 2/10 (2.0) | 17/20 (3.2) | 0/10 | 12/20 (3.5) | 1/10 (2.0) | 6/20 (2.7)
400 + 320 | 1/2 (3.0) | NA | 1/2 (2.0) | NA | 0/2 | NA
400 + 640 | 6/10 (2.7) | 16/20 (3.1) | 1/10 (4.0) | 11/20 (3.5) | 4/10 (2.3) | 4/20 (2.3)

NA=Not examined (tissues were not required to be examined unless gross lesions were present)

a Daily gavage doses of AZT + rifabutin (mg/kg per day); AZT alone, other doses of rifabutin alone, and AZT + 80 mg/kg rifabutin did not cause histopathologic alterations in the stomach

b Incidence (number of animals with lesion) followed by the mean severity (which is based on the numeric scale of 1=minimal; 2=mild; 3=moderate; 4=marked) for the animals with the lesion

Hematopoietic cell proliferation in the spleen (Table 8), myeloid cell hyperplasia in the bone marrow (Table 12), and mixed cellular infiltration in the lung (Table 13) were seen in male mice (spleen, bone marrow, and lung were not evaluated in female mice). The criteria for severity grading of splenic hematopoietic cell proliferation (Table 9, Figure 15) were similar to that described for mice treated with AZT. The splenic hematopoietic cell proliferation may have been a compensatory response to a mild anemia. Bone marrow myeloid cell hyperplasia (Table 12, Figure 16) was graded for severity based on the following:

- Minimal - up to an approximate 10% increase over normal in numbers of myeloid cells
- Mild - an approximate 11% to 20% increase over normal in numbers of myeloid cells

Mixed cell infiltration of the lung was graded for severity based on the following criteria:

- Minimal - up to approximately 20 inflammatory cells in any 100× magnification field
- Mild - approximately 21 to 50 inflammatory cells in any 100× magnification field
- Moderate - approximately 51 to 150 inflammatory cells in any 100× magnification field

TABLE 12 Incidence, Mean Severity, and Statistical Analysis of Mean Severity of Histopathologic Alterations in the Bone Marrow of Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

| Lesion^b^
Dose^a^ | Myeloid Hyperplasia | Erythroid Cell Depletion
0 + 320 | 1 (1.0) | 0 | 0.00
0 + 640 | 6 (2.0) | 0 | 0.00
200 + 320 | 1 (1.0) | 3 (1.0) | 0.30 ± 0.15
200 + 640 | 3 (2.0) | 5 (2.4) | 1.20 ± 0.42^**^
400 + 320 | 0 | 2 (2.0) | 0.40 ± 0.27
400 + 640 | 1 (3.0) | 9 (2.4) | 2.20 ± 0.33^**^

** Significantly different (P≤0.01) from the control group by Jonckheere’s and Williams’ or Dunnett’s tests

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b Incidence (number of animals with lesion; n=10) followed by the mean severity (which is based on the numeric scale of 1=minimal; 2=mild; 3=moderate; 4=marked) for the animals with the lesion; data in the last column are presented as mean ± standard error, with mean severity for all animals in the dose group

TABLE 13 Incidence and Mean Severity of Mixed Cellular Infiltration in the Lung of Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Dose^a^ | Mixed Cellular Infiltration^b^
0 + 0 | 0
0 + 80 | 0
0 + 320 | 10 (1.6)
0 + 640 | 10 (2.1)
200 + 0 | 0
200 + 80 | 1 (1.0)
200 + 320 | 10 (1.8)
200 + 640 | 10 (2.1)
400 + 0 | 0
400 + 80 | 0
400 + 320 | 10 (1.7)
400 + 640 | 10 (1.5)

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b Incidence (number of animals with lesion; n=10) followed by the mean severity (which is based on the numeric scale of 1=minimal; 2=mild; 3=moderate; 4=marked) for the animals with the lesion

FIGURE 16 Severity of Bone Marrow Erythroid Cell Depletion Versus Dose in Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Mixed cell infiltration of the lung consisted of the presence of macrophages with fewer numbers of small mononuclear cells and neutrophils occurring singularly or in aggregates within the alveolar spaces. Most of the infiltrating macrophages contained a reddish-brown, amorphous, intracytoplasmic pigment similar in appearance to that observed within macrophages in the liver and stomach. Mixed cellular infiltration of the lung may have been a host defense mechanism against rifabutin and/or metabolites.

Thymic atrophy (Table 14) was observed consistently in female-A mice but not in males and was considered to be treatment related. The lesion was graded for severity based on the following criteria:

- Minimal - depletion of approximately 5% or less of cortical lymphocytes
- Mild - depletion of approximately 6% to 20% of cortical lymphocytes
- Moderate - depletion of approximately 21% to 50% of cortical lymphocytes
- Marked - depletion of approximately 51% or greater of cortical lymphocytes

Although thymic atrophy was considered to be treatment related in female-A mice, the possibility that some of the effect may have been secondary to stress factors such as pregnancy was not discounted.

With the exception of hepatocellular cytoplasmic alteration in female mice, the incidences of all lesions attributed to rifabutin administration were dose related.

#### AZT and Rifabutin

Treatment-related lesions were seen in the liver (Tables 6, 7, and 14), spleen (Tables 8 and 9), glandular stomach (Table 10), forestomach (Table 11), bone marrow (Figure 16 and Table 12), lung (Table 13), thymus (Table 15), and mesenteric lymph node of male mice. Treatment-related lesions in female mice were seen in the liver (Tables 6, 7, and 14), glandular stomach (Table 10), forestomach (Table 11), and thymus (Table 15). Spleen, bone marrow, lung, and lymph nodes were not evaluated in female mice. In male mice, coadministration of 400 mg of AZT with rifabutin at 640 mg and not at 320 mg appeared to have markedly increased the bone marrow erythroid cell depletion (Figure 16). Since rifabutin alone had no effect on bone marrow erythroid cell depletion, there appears to be an interaction to enhance the bone marrow toxicity of AZT by rifabutin at higher doses. In general, the lesions caused by combination treatment with AZT and rifabutin in various tissues were similar to but more pronounced than those caused by treatment with AZT or rifabutin alone.

TABLE 14 Statistical Analysis of Mean Severity of Hepatocellular Centrilobular Atrophy in Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin in Combinations

| Mean Severity^b^
Dose^a^ | Male^c^ | Female-A^d^
0 + 0 | 0 00 | 0.00
200 + 80 | 0 00 | 0.00
200 + 320 | 0 00 | 0.45 ± 0 19^*^
200 + 640 | 0.00 | 1.30 ± 0 16^**^
400 + 80 | 0 00 | 0.00
400 + 320 | 0.00 | 1.20 ± 0 23^**^
400 + 640 | 0.90 ± 0.31^**^ | 1.30 ± 0 23^**^

* Significantly different (P≤0.05) from the vehicle control group by Jonckheere’s and Williams’ or Dunnett’s tests

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day), AZT alone or rifabutin alone did not cause centrilobular atrophy

b Data are presented as mean ± standard error for all animals in the dose group; mean severity is based on the numeric scale of 1 = minimal, 2=mild, 3=moderate, 4=marked

c n=10

d n=20

TABLE 15 Incidence, Mean Severity, and Statistical Analysis of Mean Severity of Thymic Atrophy in Male and Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

| Atrophy^b^
Dose^a^ | Male | | | Female-A
0 + 320 | 1/10 (1.0) | 0.10 ± 0.10 | 10 | N/A | 0 00 | 20
0 + 640 | 0/10 | 0 00 | 9 | 10/16 (2.5) | 1.25 ± 0.31^**^ | 20
200 + 320 | 4/10 (1.5) | 0.60 ± 0.31 | 10 | N/A | 0.00 | 20
200 + 640 | 6/9 (1.5) | 0.90 ± 0.31^**^ | 10 | 20/20 (3.0) | 3.00 ± 0.07^**^ | 20
400 + 320 | 6/9 (1.0) | 0.60 ± 0.16 | 10 | N/A | 0.00 | 20
400 + 640 | 6/6 (2.5) | 1.50 ± 0.43^**^ | 10 | 20/20 (3.2) | 3.20 ± 0.12^**^ | 20

NA=Not examined (tissue was not saved unless a gross lesion was present)

** Significantly different (P≤0.01) from the control group by Jonckheere’s and Williams’ or Dunnett’s tests

a Daily gavage doses of AZT + rifabutin (mg/kg per day); AZT alone and rifabutin at 80 mg/kg alone or in combination with AZT did not cause thymic atrophy

b Incidence (number of animals with lesion/number of animals examined) followed by the mean severity (which is based on the numeric scale of 1 = minimal; 2 = mild; 3 = moderate; 4 = marked) for the animals with the lesion (second and fifth columns); data in the third and sixth columns are presented as mean ± standard error, with mean severity for all animals in the dose group; data in the fourth and seventh columns are the number of animals examined

Compound-related liver lesions seen in male and female-A mice included hepatocellular cytoplasmic alteration, mixed cellular infiltration, and centrilobular atrophy. Compound-related liver lesions seen in female mice only consisted of centrilobular necrosis. Cytoplasmic alteration and mixed cellular infiltration were graded for severity using the same criteria as that used in evaluating tissues from mice treated with AZT or rifabutin alone. Centrilobular atrophy was graded for severity based on the following criteria:

- Minimal - atrophy or necrosis of approximately 5% or less of centrilobular hepatocytes
- Mild - atrophy or necrosis of approximately 6% to 15% of centrilobular hepatocytes
- Moderate - atrophy or necrosis of approximately 16% to 50% of centrilobular hepatocytes

Although hepatocellular cytoplasmic alteration was seen in male and female vehicle control mice, incidences were increased in the AZT + rifabutin-treated groups (Tables 6 and 7). Incidences of cytoplasmic alteration in hepatocytes were not statistically significant in male or female mice treated with AZT alone. Rifabutin alone at 640 mg/kg in male mice resulted in a significant increase (P≤0.05) in the mean severity of cytoplasmic alteration. Female mice administered 320 mg/kg rifabutin alone had a significant increase in the incidence (P≤0.05) of hepatocyte cytoplasmic alteration, but this effect was not evident in the females treated with 640 mg/kg rifabutin alone. For male mice that received 400 + 640 mg/kg, severity of cytoplasmic alteration was enhanced (P≤0.01). Significant elevations (P≤0.01) in the severity grades of cytoplasmic alteration also occurred in female groups treated with 200 + 320 mg/kg or 400 + 640 mg/kg. The degree of severity of cytoplasmic alteration in the high dose combination female group may have been low because of early deaths occurring prior to the development of the lesion. As previously discussed in groups receiving AZT and rifabutin alone, hepatocyte cytoplasmic alteration likely represents a physiologic response to decreased food intake with concurrent loss of body weight instead of a direct cellular response to the test compounds.

Liver mixed cellular infiltration, which consisted of infiltration of small mononuclear cells, pigmented macrophages, and occasional neutrophils, was dose related in male but not in female mice. The absence of a dose-related pattern for liver mixed cell infiltration in female mice resulted from the fact that the lesion was infrequently seen in the female mice from the higher dose combination treatment groups that died early or were euthanatized moribund; it occurred primarily in mice that survived until terminal sacrifice.

Liver centrilobular atrophy, which consisted of a paucity of hepatocytes in the centrilobular areas and which was probably a sequential change that followed centrilobular necrosis, was dose related in male and female mice; the incidences in females were higher than in males, and in females, it occurred primarily in those that died or were sacrificed moribund (Table 14). Centrilobular atrophy of hepatocytes may have been a secondary response to severe anemia instead of a direct effect of the compounds on the liver parenchyma. A significant elevation (P≤0.01) occurred in the mean severity grade of centrilobular atrophy in male mice treated with 400 + 640 mg/kg (Table 14). This morphologic alteration did not occur in any of the other male groups that received AZT or rifabutin alone or in any combination. Female mice were affected to a greater degree than males as increased incidences of centrilobular atrophy were evident in the group administered 200 + 320 mg/kg (P≤0.05) as well as the group administered 200 + 640 mg/kg (P≤0.01). Increased incidences of centrilobular atrophy also occurred in both female groups receiving 400 mg/kg AZT + 320 or 640 mg/kg rifabutin (P≤0.01). The degree of severity appeared to reach a plateau around 1.3 in the high dose combination group because of the early deaths in this group. Centrilobular atrophy did not occur in female groups treated with AZT or rifabutin alone. Treatment-related centrilobular necrosis was seen in a few female mice, although the incidence was not dose related.

Treatment-related forestomach lesions seen in male and female-A mice consisted of epithelial hyperplasia, ulcer, and chronic active inflammation (Table 11). Female mice treated with 200 or 400 mg/kg AZT + 640 mg/kg rifabutin had significant elevations (P≤0.01) in severities of epithelial hyperplasia of the forestomach. The incidence of epithelial hyperplasia was also significant (P≤0.01) in the male group administered 400 + 640 mg/kg. Compound-related glandular stomach lesions seen in male and female mice consisted of cystic degeneration and chronic active inflammation (Table 10). The morphologic appearance and criteria for severity grading of the forestomach and glandular stomach lesions seen in AZT + rifabutin-treated mice were similar to those described for mice treated with rifabutin alone. Forestomach ulcer was graded for severity based on the following criteria:

- Minimal - area of mucosal ulceration up to approximately 300 μm in diameter
- Mild - area of mucosal ulceration approximately 301 to 600 μm in diameter
- Moderate - area of mucosal ulceration approximately 601 to 1,200 μm in diameter
- Marked - area of mucosal ulceration approximately 1,201 μm or greater in diameter

Treatment-related thymic atrophy occurred in male and female-A mice (Table 15), whereas the following lesions were seen in male mice only (the tissues involved were not evaluated in female mice): bone marrow erythroid cell depletion, bone marrow myeloid cell hyperplasia, mesenteric lymph node atrophy, splenic lymphoid follicle atrophy, splenic red pulp atrophy, splenic hematopoietic cell proliferation, splenic pigmentation, and lung mixed cell infiltration. The morphologic appearance and criteria for severity grading of the thymic atrophy, bone marrow myeloid hyperplasia, splenic hematopoietic cell proliferation, and lung mixed cellular infiltration seen in AZT + rifabutin-treated mice were similar to those described for mice treated with rifabutin alone.

Erythroid cell depletion in the bone marrow corresponding with severe anemia was evident in male mice receiving 200 or 400 mg/kg AZT + 640 mg/kg rifabutin (Table 12, Figure 16). Bone marrow erythroid cell depletion was graded for severity based on the following criteria:

- Minimal - depletion of approximately 5% or less of erythroid cells
- Mild - depletion of approximately 6% to 20% of erythroid cells
- Moderate - depletion of approximately 21% to 50% of erythroid cells

Atrophy of the mesenteric lymph node was evident in 40% of male mice treated with 200 or 400 mg/kg AZT + 640 mg/kg rifabutin.

Splenic hematopoiesis, which may have been a compensatory response to anemia, was apparently negated in the higher dose combination groups by the atrophic effect of treatment on the splenic red pulp. The splenic pigmentation consisted of coarse, golden-brown granules that resembled hemosiderin within macrophages in the red pulp. Most of the macrophages that contributed to the mixed cell infiltration in the lung contained a reddish-brown, amorphous pigment, which may have represented rifabutin or a metabolite of rifabutin.

### Other Lesions

Lesions not attributed to administration of either compound were seen in the liver of male and female mice and in the bone, kidney, mandibular lymph node, heart, lung, glandular stomach, urethra, and skin of male mice. Liver focal necrosis was seen in male and female-A mice from the vehicle control group and various treatment groups. Although the incidences were increased in some of the treatment groups over the vehicle control, a dose-related pattern was not evident, and the increase was considered to be incidental. Liver diffuse necrosis of marked severity was seen in one female-A mouse that received 400 mg/kg AZT alone; this probably occurred as a result of an incidental torsion of the affected liver lobe. Cartilaginous metaplasia, fibrosis, and/or necrosis involving bone were seen in several male mice. These lesions, which occurred sporadically in various groups including the control group, involved the thoracic vertebrae and ribs near their junction with the vertebrae. The bone sections were examined microscopically as a result of nodules or other lesions observed on the vertebrae or ribs at necropsy, and the lesions were attributed to mechanical irritation caused by the gavage needle during dosing. Kidney lesions seen in male mice that were considered incidental included protein casts, cyst, hydronephrosis, chronic inflammation, and renal tubular regeneration. Other lesions in male mice considered to be incidental included liver hemorrhage, mandibular lymph node hemorrhage, heart mineralization, lung hemorrhage, glandular stomach hemorrhage, glandular stomach edema, urethral inflammation, urethral cyst, and skin hemorrhage.

## Sperm Endpoints

Epididymal sperm motility was affected by the interaction of AZT and rifabutin. There was a statistically significant interaction between both compounds, indicating that the dose-response relationship of AZT differs across doses of rifabutin (P≤0.01; Table 16). Left caudal weights were significantly decreased (P≤0.01) at 640 mg/kg rifabutin (Table 17).

TABLE 16 Effect of Oral Administration of AZT and Rifabutin on Epididymal Sperm Motility and Spermatid Heads per Testis in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

| Epididymal Sperm Motility (%) | | Spermatid Heads/Testis × 10^7^
Dose^a^ | Number | Mean ± Standard Error | Number | Mean ± Standard Error
0 + 0 | 10 | 75.13 ± 5.12 | 10 | 1.82 ± 0.07
0 + 80 | 10 | 69.79 ± 4.69 | 10 | 1.86 ± 0.07
0 + 320 | 10 | 62.08 ± 7.63 | 10 | 1.86 ± 0.06
0 + 640 | 10 | 74.31 ± 2.69 | 10 | 1.78 ± 0.06
200 + 0 | 9 | 49.98 ± 7.35^*^ | 10 | 1.98 ± 0.05
200 + 80 | 9 | 70.36 ± 4.54 | 10 | 2.04 ± 0.08
200 + 320 | 9 | 57.57 ± 8.06 | 10 | 1.81 ± 0.10
200 + 640 | 9 | 20.71 ± 9.51^**^ | 10 | 1.96 ± 0.08
400 + 0 | 9 | 50.71 ± 8.05 | 10 | 1.87 ± 0.09
400 + 80 | 10 | 55.70 ± 7.72 | 10 | 1.83 ± 0.10
400 + 320 | 8 | 44.74 ± 5.58^*^ | 10 | 1.96 ± 0.05
400 + 640 | 9 | 3.87 ± 1.14^**^ | 10 | 1.93 ± 0.06

* Significantly different (P≤0.05) from the vehicle control group by the Wilcoxon rank sum test

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

TABLE 17 Effect of Oral Administration of AZT and Rifabutin on Left Caudal Epididymal and Left Testicular Weights in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Dose^a^ | Left Caudal Weight (g); (Mean + Standard Error) | Left Testicular Weight (g); (Mean ± Standard Error)
0 + 0 | 0.0197 ± 0.0010 | 0.1217 ± 0.0054
0 + 80 | 0.0183 ± 0.0006 | 0.1196 ± 0.0044
0 + 320 | 0.0194 ± 0.0009 | 0.1193 ± 0.0038
0 + 640 | 0.0184 ± 0.0010^**^ | 0.1203 ± 0.0046
200 + 0 | 0.0214 ± 0.0005 | 0.1174 ± 0.0042
200 + 80 | 0.0202 ± 0.0010 | 0.1278 ± 0.0065
200 + 320 | 0.0179 ± 0.0010 | 0.1189 ± 0.0042
200 + 640 | 0.0177 ± 0.0011^**^ | 0.1233 ± 0.0048
400 + 0 | 0.0199 ± 0.0006 | 0.1213 ± 0.0029
400 + 80 | 0.0209 ± 0.0009 | 0.1202 ± 0.0037
400 + 320 | 0.0195 ± 0.0008 | 0.1156 ± 0.0040
400 + 640 | 0.0171 ± 0.0011^**^ | 0.1241 ± 0.0041

** Significantly different (P≤0.01) from the vehicle control group by Jonckheere’s and Williams’ or Dunnett’s tests

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

## Natural Delivery Data

The administration of AZT or rifabutin alone or in combination did not affect the incidence of pregnancy in the female-B mice (Table 18). Administration of 200 + 640, 400 + 320, or 400 + 640 mg/kg AZT and rifabutin significantly (P≤0.05 or P≤0.01) decreased the number of delivered litters (Table 18). The 200 + 640 and 400 + 320 mg/kg doses significantly (P≤0.05) increased the duration of gestation.

The number of implantation sites was not affected by administration of any test article alone or in combination. The number of dams with stillborn pups, the number of dams with no liveborn pups, and the number of dams with all pups dying were increased or significantly (P≤0.05) increased in the 200 + 640 and 400 + 320 mg/kg groups.

TABLE 18 Occurrence of Pregnancy in Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Dose^a^ | Number | Number Pregnant^b^ (% of total) | Number Delivered (% of number pregnant)
0 + 0 | 15 | 15 (100) | 15 (100)
0 + 80 | 15 | 11 (73.3) | 11 (100)
0 + 320 | 17 | 15 (88.2) | 12 (80.0)
0 + 640 | 16 | 16 (100) | 16 (100)
200 + 0 | 15 | 14 (93.3) | 14 (100)
200 + 80 | 15 | 14 (93.3) | 14 (100)
200 + 320 | 16 | 16 (100) | 14 (87.5)
200 + 640 | 16 | 14 (87.5) | 4 (28.6)^**^
400 + 0 | 16 | 13 (81.2) | 13 (100)
400 + 80 | 16 | 12 (75.0) | 12 (100)
400 + 320 | 16 | 12 (75.0) | 6 (50.0)^**^
400 + 640 | 16 | 13 (81.2) | 0^**^

** Significantly different (P≤0.05 or P≤0.01) from the vehicle control group value by the Kruskal-Wallis test

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b Number of animals presumed pregnant by presence of a vaginal plug

Delivered litter size was decreased in the 200 + 320, 200 + 640, and 400 + 320 mg/kg groups (Table 19). The number of stillborn pups was significantly (P≤0.01) increased in the 200 + 640 mg/kg group. The number of pups found dead or missing and presumed cannibalized was significantly (P≤0.01) increased in the 200 + 640 and 400 + 320 mg/kg groups.

Cumulative survival per litter and live litter size at weighing was decreased in the 200 + 320, 200 + 640, and 400 + 320 mg/kg groups. Pup mean body weight per litter (Figure 17) was significantly (P≤0.05) decreased or decreased in the 400 mg/kg AZT + 80 or 320 mg/kg rifabutin groups.

TABLE 19 Summary of Natural Delivery Litter Data for Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Dose^a^ | Dams with Stillborn Pups (% of Dams that Delivered) | Dams with All Pups Dying on Days 0-4 (% of Dams with Liveborn Pups) | Mean Live Litter Size | Pups Dying on Days 1-4/Total Alive on Day 1 (%) | Survival/Live Litter Size^b^ on Day 4 Postpartum
0 + 0 | 1 (6.7) | 0 | 11.2 | 3/157 (1.9) | 11.0/11.2
0 + 80 | 0 | 0 | 11.1 | 7/122 (5.7) | 10.4/11.1
0 + 320 | 0 | 0 | 10.7 | 2/125 (1.6) | 10.2/10.7
0 + 640 | 0 | 1 (6.2) | 11.9 | 15/190 (7.9)^*^ | 10.9/11.9
200 + 0 | 0 | 0 | 12.0 | 0/163 | 11.6/12.0
200 + 80 | 1 (7.1) | 0 | 10.1 | 5/130 (3.8) | 9.6/10.1
200 + 320 | 1 (7.1) | 2 (15.4) | 8.0 | 7/102 (6.9) | 7.3/8.0
200 + 640 | 2 (50.0) | 2 (66.7) | 4.0 | 2/4 (50.0)^**^ | 0.7/4.0
400 + 0 | 1 (7.7) | 0 | 10.7 | 2/137 (1.4) | 10.4/10.7
400 + 80 | 1 (8.3) | 0 | 11.8 | 6/140 (4.3) | 11.2/11.8
400 + 320 | 3 (50.0) | 2 (50.0) | 6.0 | 2/18 (11.1) | 4.0/6.0
400 + 640 | —^c^ | — | — | — | —

* Significantly different (P≤0.05) from the vehicle control group by the Cochran-Armitage and Fisher exact tests

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b Excludes values for litters that had no surviving pups

c No litters were delivered

FIGURE 17 Mean Body Weights/Litter of Pups of Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations (LD=lactation day; mean pup weight/litter includes only values for litters in which pups survived to LD 4)

## Caesarean-Section Data

Pregnancy rates were significantly (P≤0.05 or P≤0.01) reduced in the following groups (Table 20): 200 mg/kg AZT alone, 640 mg/kg rifabutin alone, 200 mg/kg AZT+ 320 or 640 mg/kg rifabutin, and 400 mg/kg AZT + 80, 320, or 640 mg/kg rifabutin. For pregnant dams, the average number of corpora lutea and implantations per litter were not affected by treatment with AZT or rifabutin alone or in combination.

Live litter size was significantly (P≤0.01) reduced, and the average number of resorptions and percentage of dead or resorbed conceptuses per litter were significantly (P≤0.05 or P≤0.01) increased for the AZT alone groups and most dose groups treated with combinations (Table 21). For the average number of resorption data, only early resorptions were increased; late resorptions were not affected.

The mean fetal body weight per litter was decreased or significantly (P≤0.05 or P≤0.01) decreased in the 640 mg/kg rifabutin alone group, the AZT alone groups, and all groups treated with the combinations (Table 22).

TABLE 20 Occurrence of Pregnancy in Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Dose^a^ | Number Pregnant (%)
0 + 0 | 20 (100)
0 + 80 | 20 (100)
0 + 320 | 19 (95)
0 + 640 | 13 (65)^**^
200 + 0 | 15 (75)^*^
200 + 80 | 16 (80)
200 + 320 | 10 (50)^**^
200 + 640 | 0^**^
400 + 0 | 17 (85)
400 + 80 | 10 (50)^**^
400 + 320 | 4 (20)^**^
400 + 640 | 0^**^

* Significantly different (P≤0.05) from the vehicle control group by the Cochran-Armitage and Fisher exact tests

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

TABLE 21 Summary of Caesarean-Section Litter Data for Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

| Litter Sizes | Live Fetuses | | Dead Fetuses | | Resorptions
Dose^a^ | Mean ± SD^b^ | No. | Mean ± SD | No. | Mean ± SD | No. | Mean ± SD
0 + 0^c^ | 11.3 ± 2.0 | 200 | 11.1 ± 2.0 | 3 | 0.2 ± 0.4 | 17 | 0.9 ± 1.2
0 + 80^d^ | 12.2 ± 1.9 | 217 | 12.0 ± 2.1 | 2 | 0.1 ± 0.3 | 9 | 0.5 ± 0.9
0 + 320 | 8.6 ± 3.6 | 154 | 8.1 ± 4.0 | 10 | 0.5 ± 2.3 | 27 | 1.4 + 1.7
0 + 640^d^ | 12.2 ± 2.2 | 131 | 11.9 ± 2.2 | 3 | 0.3 ± 0.6 | 4 | 0.4 ± 0.5
200 + 0^d^ | 6.2 ± 3.7^**^ | 87 | 6.2 ± 3.7^**^ | 0 | 0.0 | 59 | 4.2 ± 2.6^**^
200 + 80^d^ | 6.9 ± 3.6^**^ | 103 | 6.9 ± 3.8^**^ | 1 | 0.1 ± 0.2 | 44 | 2.9 ± 2.1^*^
200 + 320^e^ | 3.4 ± 4.4^**^ | 31 | 3.4 ± 4.4^**^ | 0 | 0.0 | 33 | 3.7 + 1.7^**^
200 + 640^f^ | — | — | — | — | — | — | —
400 + 0 | 4.6 ± 4.2^**^ | 78 | 4.6 ± 4.1^**^ | 1 | 0.0 ± 0.2 | 82 | 4.8 ± 3.3^**^
400 + 80 | 4.0 ± 3.7^**^ | 38 | 3.8 ± 3.4^**^ | 2 | 0.2 + 0.4 | 54 | 5.4 ± 3.7^**^
400 + 320^e^ | 3.3 ± 5.8 | 10 | 3.3 ± 5.8 | 0 | 0.0 | 14 | 4.7 ± 2.1
400 + 640^f^ | — | — | — | — | — | — | —

* Significantly different (P<;0.05) from the vehicle control group value by the Cochran-Armitage and Fisher exact tests

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b SD=standard deviation

c Excludes dams that delivered litters before scheduled sacrifice

d Excludes dams that were sacrificed on an estimated day 13 or 14 of gestation and, due to gestational age of fetuses, genders and viability could not be determined

e Excludes dams that were moribund sacrificed on day 26 or 27 of the study

f All animals in the dose group were dead prior to scheduled caesarean-section. No pregnancies were detected in this group.

TABLE 22 Mean Body Weights of Fetuses from Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations

Dose^a^ | Mean Fetal Weight (grams)
0 + 0 | 1.38
0 + 80 | 1.42
0 + 320 | 1.46
0 + 640 | 1.12
200 + 0 | 1.10^**^
200 + 80 | 1.12^*^
200 + 320 | 1.13
200 + 640 | —^b^
400 + 0 | 1.06
400 + 80 | 1.12
400 + 320 | —
400 + 640 | —

* Significantly different (P≤0.05) from the vehicle control group by Dunnett’s or Dunn’s test

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day)

b No fetuses were present.

## Gross External Alterations

With the exception of red-colored fetuses in the groups treated with 320 or 640 mg/kg rifabutin, administration of AZT alone, rifabutin alone, or AZT in combination with rifabutin did not increase the percent of fetuses with any alteration per litter, the percent of litters with any alteration, or the percent of fetuses with any alteration.

Reproductive toxicity was observed in the mice that received the highest dose of rifabutin (640 mg/kg) alone or combinations of AZT and 320 or 640 mg/kg rifabutin. The highest dose of rifabutin alone, both doses of AZT alone, and all combination doses tested produced developmental toxicity (embryo lethality and reduced fetal weights but no external malformations). The combination of drugs markedly increased the reproductive and developmental toxicity caused by either drug alone.

Severity of hematopoietic toxicity due to AZT and rifabutin combinations was dose- and duration-of-treatment dependent. Higher dose combinations (200 or 400 mg/kg AZT + 640 mg/kg rifabutin) caused mild anemia in female-B mice treated for 10 days, severe anemia in male mice treated for 20 days, and the death of all female-A mice by day 22. These results indicate that the hematopoietic toxicity in pregnant female mice was more severe than in males and pregnancy may have contributed to the increased hematopoietic toxicity of AZT + rifabutin combinations. Cytoplasmic alterations in hepatocytes and centrilobular atrophy of the liver appear to be dose- and duration-of-treatment dependent and more severe in pregnant females than in males.

These effects may be secondary to anemia rather than a direct hepatotoxicity of the therapeutic combinations. Plasma concentrations of AZT as well as rifabutin appeared to have increased at the 400 mg/kg AZT + 600 mg/kg rifabutin combination dose when compared to the plasma concentrations of the same doses administered alone. These results indicate that there may be an interaction in absorption, metabolism, or elimination of these compounds when given in combination, especially at high doses. Increased hematopoietic toxicity of the therapeutic combinations may be due to increased plasma levels of these compounds.

Combinations of AZT at 200 and 400 mg/kg with rifabutin at 320 and 640 mg/kg caused mortality after 4 to 19 days of treatment, as well as reproductive and developmental toxicity in female-A and female-B mice. Because most reproductive and developmental toxic effects in female-B mice were observed at the doses that caused maternal toxicity, increases in reproductive and developmental toxicity at these doses may be secondary to increased maternal toxicity. Increased maternal toxicity, as measured by body weights and hematological parameters, was not observed in female-A mice treated with 400 mg/kg AZT + 80 mg/kg rifabutin as compared to the same doses of AZT or rifabutin alone. However, the above dose combination increased the reproductive and developmental toxicity. Therefore, rifabutin at 80 mg/kg, which had no reproductive or developmental effects when administered alone, appears to have increased the reproductive and developmental toxicity of AZT at 400 mg/kg.

## Conclusions

AZT alone caused mild hematopoietic toxicity as indicated by anemia. Rifabutin alone caused mild hematopoietic toxicity and mild hepatic toxicity with increases in liver weights and serum enzymes indicative of liver toxicity. Rifabutin also caused mild degenerative and inflammatory lesions in the stomach. Combinations of AZT and rifabutin caused hematopoietic toxicity accompanied by severe anemia and decreased hematopoietic cells in the bone marrow and spleen. Severe anemia appeared to have contributed to high mortality of female-A mice treated with combinations of 200 or 400 mg/kg AZT and 320 or 640 mg/kg rifabutin. Combinations of the two compounds appeared to have synergized the hematopoietic toxicity leading to mortality. AZT increased the hepatic toxicity but not the gastric lesions caused by rifabutin. AZT and rifabutin at the highest dose combination evaluated in this study appear to have increased the plasma levels of both compounds as compared to administration of either compound alone, and increased plasma levels may have contributed to the increased toxicity when administered in combination. AZT alone, rifabutin alone, and combinations of the two compounds did not cause gross external alterations in pups. AZT alone caused decreases in pregnancy rates and live litter size and increased numbers of resorptions. Rifabutin alone caused decreased pregnancy rates and decreased mean fetal body weight per litter. Administration of AZT and rifabutin in combinations caused marked decreases in pregnancy rates, live litter size, and mean fetal body weight per litter and marked increases in resorptions. However, the increases in reproductive and developmental toxicity of the therapeutic combinations may be due to increased maternal toxicity. These results indicate that AZT and rifabutin combinations have the potential to markedly increase the hematopoietic toxicity of either compound alone.