# Materials and Methods

## Procurement and Characterization of Chemicals

3′-Azido-3′-deoxythymidine (AZT; lot 7494-36-05) was manufactured by Raylo Chemicals (Edmonton, Alberta) and Burroughs Wellcome (Research Triangle Park, NC) and supplied as a powder. Rifabutin (lot 4041M155) was manufactured by Pharmacia, Inc. (Piscataway, NJ).

Rifabutin, a violet-red crystalline powder, is stable at room temperature. It is minimally soluble in water, slightly soluble in ethanol, soluble in methanol, and highly soluble in chloroform (O’Brien et al., 1987).

The purity of AZT was determined to be greater than 99% by high-performance liquid chromatography. Purity of the rifabutin used in this study was estimated by high-performance liquid chromatography to be approximately 99%. Infrared and nuclear magnetic resonance spectroscopy analyses performed on AZT and rifabutin produced spectra which were consistent with the structures of AZT and rifabutin and agreed with the reference spectra. The vehicle used in this study was an aqueous solution containing 0.2% methylcellulose and 0.1% Tween 80.

## Dose Formulations

The required amounts of AZT and rifabutin were combined with the required amount of the vehicle. The dose formulation was then stirred until visually homogeneous. A stability study conducted on AZT/rifabutin stored at 4° C indicated no significant loss of either test chemical for at least 33 days. Dose formulations were stored refrigerated, protected from light, and used within 20 days.

Samples at each dose concentration from the initial mix were analyzed prior to dosing. Residual formulations taken from the same mix after dosing were also analyzed. Prior to dosing, the concentrations of AZT ranged from 100% to 106% of the target concentrations. The concentrations of rifabutin were 104% to 111% of the target concentrations. Concentrations of AZT and rifabutin in the residual formulations ranged from 96% to 104% and 91.6% to 156% of the target concentrations, respectively.

## Study Design

Swiss (CD-1^®^) mice were obtained from Charles River Laboratories, Portage, MI (Area P01), and were approximately 12 weeks old when placed on study. The mice were housed five males or five females per cage during quarantine, uniquely identified before randomization, and individually housed after randomization, except during cohabitation.

The mice were housed in polycarbonate cages with solid bottoms and sides. Average temperature in the animal rooms was 70.7° F, with a standard deviation of 0.7° F; average relative humidity was 47.2%, with a standard deviation of 6.8%.

At terminal sacrifice, blood samples were collected from five male and five female sentinel animals as part of the animal disease screening program. Results indicated all animals were free of viral antibodies.

AIDS patients receive combination therapy with rifabutin and AZT, and controlled laboratory data are required to evaluate the potential toxicity of this combination therapy. At present, there are no adequate alternatives to whole animal models for this purpose. The Swiss (CD-1^®^) mouse chosen for this study is one of the mouse models routinely used for reproductive and developmental toxicity studies by the NIEHS.

The basic premise for dose concentration selection is that the high dose concentration should induce some measurable evidence of toxicity (e.g., anemia, weight loss, target organ toxicity). In a number of reproductive, developmental, and toxicity studies under this project, AZT at the doses selected (200 and 400 mg/kg) caused resorptions and decreased litter sizes. The human therapeutic dose is 10 mg/kg per day (PDR, 1995). The selected doses are 20- and 40-times human doses, but on a body surface area basis (Freirich et al., 1966), the doses are close to two and four times the therapeutic dose. Recent studies under this project have also demonstrated dose-related decreases in hematologic parameters at these doses.

Dose concentrations selected for rifabutin (80, 320, and 640 mg/kg per day) are 2, 8, and 16 times the therapeutic dose and were based upon the following: the therapeutic dose in the mouse for Mycobacterium avium complex (MAC) infection is 20 to 40 mg/kg per day for up to 60 days (Orme, 1988; Saito et al., 1988); no toxicity was reported at these doses. The clinical dose for MAC prophylaxis in humans is 4.3 mg/kg per day (300 mg per day; Nightingale et al., 1993), equivalent to 53 mg/kg per day in the mouse. The maximum tolerated dose reported in humans is 14.2 mg/kg per day (1,000 mg per day; Siegal et al., 1990), equivalent to 175 mg/kg per day in the mouse.

The design of this study is a modification of a design published elsewhere (Harris et al., 1992). A brief summary of the study design is provided in Table 2. The oral route of administration was selected because it is the route used in humans, and the study was conducted in Swiss (CD-1^®^) mice because this strain is routinely used for reproductive and developmental toxicity evaluations. Combinations of AZT and rifabutin were administered by gavage as a single formulation in an aqueous solution containing methylcellulose and Tween 80. Total daily doses of 20 mL/kg were divided into two equal doses of 10 mL/kg given approximately 6 hours apart. Mice were divided into three groups as follows:

Male Mice: Ten males were assigned to each dose group. Five additional males were added to selected groups for determination of plasma concentrations of the test compounds. Prior to dosing, male mice were cohabited with female-B mice on study days 0 to 4. Males were dosed from study day 5 to the day prior to sacrifice for 20 days. Males were cohabited with female-A mice on study days 9 to 13 to identify effects of treatment on mating behavior. On study day 25 or 26, all male mice were weighed, and blood samples were obtained from the retroorbital sinus for hematology and clinical chemistry evaluations. The males were euthanatized with CO_2_, necropsy was conducted, and the testis and epididymides were collected and prepared for evaluation of sperm parameters as described in the Sperm Function Evaluation section of this report.

Female-A Mice: Twenty females were assigned to each dose group. Female-A mice were dosed from study day 0 to the day prior to sacrifice for approximately 30 days. Male mice were cohabited with female-A mice on study days 9 to 13 to identify effects of treatment on mating behavior, fertilization, implantation, or the initial stages of development. During the cohabitation period, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually, and that day was designated as day 0 of gestation. At the end of the cohabitation period, all animals were housed individually. Prior to parturition on day 18 of presumed gestation (study days 28 to 32), all female-A mice were weighed, and blood samples were taken from the retroorbital sinus for hematology and clinical chemistry evaluations. The female-A mice were then euthanatized with CO_2_, and necropsy and caesarean section evaluations were conducted. Live fetuses were removed, weighed, anesthetized on ice, and preserved in Bouin’s fixative. The uteri of all sperm-negative females were examined for evidence of unsuccessful pregnancy and then press-plated between two heavy plates of glass to visualize implantation sites. Additional endpoints for all female-A mice included gravid uterine weight and number of implantation sites, resorptions, corpora lutea, and dead and live fetuses.

Female-B Mice: Twenty females were assigned to each dose group. Prior to dosing, female-B mice were cohabited with males on study days 0 to 4. During the cohabitation period, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually, and that day was designated as day 0 of gestation. At the end of the cohabitation period, sperm-negative female-B mice were euthanatized with CO_2_ and discarded without necropsy; all other animals were housed individually. Sperm-positive female-B mice were assigned evenly across dose groups prior to gestation day 6. Female-B mice were subsequently dosed during gestation days 6 to 15 (for 10 days), during the fetal organogenesis period, to identify effects on fetal development. Residual effects on parturition and the beginning of lactation were also evaluated. Beginning on gestation day 16, the bedding material and feeders were no longer changed. From gestation day 17 until the litters were delivered, female-B mice were observed twice daily for evidence of labor or delivery. The day of completed delivery was determined to the nearest day and designated as postnatal day 0. On postnatal days 0 and 1, dam body weights were recorded along with the number of live and dead pups, the number of male and female pups, the incidence of any gross malformations, and live pup weights. Dead pups were discarded. On postnatal day 4, all female-B mice, including any that did not deliver, were weighed, and blood samples were collected from the retroorbital sinus for hematology evaluations. These mice were then euthanatized with CO_2_, and complete necropsies were performed. The uterus was removed and press-plated. All pups were weighed and given a thorough external examination for lesions and malformations, and the gender was recorded. The pups were then euthanatized with CO_2_ and preserved in Bouin’s fixative.

### Clinical Pathology

All blood samples were collected from the retroorbital sinus under CO_2_:O_2_ (70/30) anesthesia. Blood for hematology analyses was collected in a tube containing EDT A, and blood for clinical chemistry analyses was collected in a tube without anticoagulant. Animals were selected in random order for blood collection, and samples were analyzed in the order collected.

Erythrocyte, platelet, and leukocyte counts; hematocrit; hemoglobin concentration; mean cell hemoglobin; mean cell volume; mean cell hemoglobin concentration; and leukocyte differentials were determined on whole blood using a Technicon H-1™ automated hematology analyzer. Reticulocyte counts were conducted using a Coulter Model Elite Flow Cytometer™. Blood smears were prepared to manually verify leukocyte differentials and erythrocyte and platelet morphology if necessary. Sorbitol dehydrogenase, total bile acids, alanine aminotransferase, alkaline phosphatase, and aspartate aminotransferase were determined using the Roche Cobas Fara™ automated analyzer. Priority for clinical chemistry tests was assigned in the order listed above.

Blood (approximately 0.6 mL) was collected by retroorbital puncture into heparinized tubes at 15, 30, 60, and 90 minutes following the last dose for determination of AZT and rifabutin levels in plasma. Two mice per selected dose group (male and female-A mice) were bled at each time point when possible. Dose groups designated to be bled for plasma concentration determinations included females that received 80 mg/kg rifabutin with or without 400 mg/kg AZT and males and females that received 320 or 640 mg/kg rifabutin with or without 400 mg/kg AZT.

Males used for plasma concentration determinations included extra mice (five per dose group) from the shipment of mice for this study, as well as 3 of 10 males from selected dose groups that were on study; the remaining males in each dose group were bled for clinical pathology determinations. Female mice bled for plasma concentration determinations were pregnant female-A study mice, when possible.

### Sperm Function Evaluation

Sperm motility was evaluated at necropsy in the following manner. The left epididymis was isolated and weighed. The tail of the epididymis (cauda epididymis) was then removed from the epididymal body (corpus epididymis). Modified Tyrode’s buffer was applied to slides, and a small incision was made at the distal border of the cauda epididymis. The sperm effluxing from the incision were dispersed in the buffer on the slides, and the numbers of motile and nonmotile spermatozoa were counted for five fields per slide by two observers.

Following completion of sperm motility estimates, each left cauda epididymis was placed in buffered neutral saline solution. Caudae were finely minced, and the tissue was incubated in the saline solution. Sperm density was then determined microscopically with the aid of a hemocytometer. To quantify spermatogenesis, testicular spermatid head count was determined by removing the tunica albuginea and homogenizing the left testis in phosphate-buffered saline. Homogenization-resistant spermatid nuclei were counted with a hemocytometer.

### Histopathology

Necropsy was performed on all animals (except sperm-negative female-B mice). The liver of male and female-A mice was weighed. Histopathology of male and female-A mice was conducted on the tissues listed in Table 2. With the exception of the testes and epididymides, which were fixed in Bouin’s and stained with PAS, all other tissues were fixed in 10% neutral buffered formalin. These tissues were then trimmed to a maximum thickness of 0.3 cm for processing, embedded in paraffin, sectioned at 4 to 6 μm thickness, stained with hematoxylin and eosin, and examined by light microscopy.

TABLE 2 Experimental Design and Materials and Methods in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin in Swiss (CD-1®) Mice

Study Laboratory; Southern Research Institute, Birmingham, AL
Strain and Species; Swiss (CD-1®) mice
Animal Source; Charles River Laboratories, Portage, MI (Area P01)
Time Held Before Study; 17 days
Age When Placed on Study; 88 days
Duration of Dosing; Male mice day 5 to day prior to sacrifice (except for those animals designated for plasma compound level determination); Female-A mice day 0 to day prior to sacrifice (except for those animals designated for plasma compound level determination); Female-B mice gestation days 6 to 15
Days of Cohabitation; Male and Female-A mice days 9 to 13; Male and Female-B mice days 0 to 4; When possible, one male and two females within the same dose group were housed together by consecutive animal number
Necropsy Dates; Male mice days 25 and 26; Female-A mice days 28 to 32; Female-B mice day 5 (sperm-negative), days 24 through 29 of presumed gestation (sperm-positive, not delivered), postnatal day 4 (sperm-positive, delivered)
Average Age at Necropsy; Male mice 113-114 days; Female-A mice 116-120 days; Female-B mice 112-117 days
Size of Study Groups; Male mice 10 or 15; Female-A mice 20; Female-B mice 20
Method of Animal Distribution; Animals were assigned to groups using a stratified weight method and then assigned to study groups in random order
Animals per Cage; One animal per cage, except during cohabitation
Method of Animal Identification; Tail tattoo
Diet; NIH-07 pelleted feed, available ad libitum
Water; Tap water (Birmingham, AL), available ad libitum
Cages; Polycarbonate cages with solid bottoms and sides
Bedding; Heat-treated hardwood chips (Sam-Chips®, P J Murphy Forest Products Corporation, Montville, NJ)
Cage Filters; Remay® spun-bonded polyester (Andico, Birmingham, AL)
Racks; Stainless steel (Lab Products, Maywood, NJ)
Animal Room Environment; Temperature 70 7° ± 0 7° F; Relative humidity 47 2% ± 6 8%; Fluorescent light 12 hours fluorescent light/day; Room air minimum of 10 changes/hour
Doses; Daily doses in methylcellulose and Tween 80 by gavage; 0 mg AZT + 0 mg rifabutin per kg body weight per day; 0 mg AZT + 80 mg rifabutin per kg body weight per day; 0 mg AZT + 320 mg rifabutin per kg body weight per day; 0 mg AZT + 640 mg rifabutin per kg body weight per day; 200 mg AZT + 0 mg rifabutin per kg body weight per day; 200 mg AZT + 80 mg rifabutin per kg body weight per day; 200 mg AZT + 320 mg rifabutin per kg body weight per day; 200 mg AZT + 640 mg rifabutin per kg body weight per day; 400 mg AZT + 0 mg rifabutin per kg body weight per day; 400 mg AZT + 80 mg rifabutin per kg body weight per day; 400 mg AZT + 320 mg rifabutin per kg body weight per day; 400 mg AZT + 640 mg rifabutin per kg body weight per day
Type and Frequency of Observation; Mortality/monbundity twice daily; Clinical findings once daily; Vaginal plugs days 10 to 14 for female-A mice, days 1 to 5 for female-B mice; Body weights days 3, 5, 9, 13, 17, 21, 23, and sacrifice for male mice, days 0, 4, 12, 16, 20, 23, 26, and sacrifice for female-A mice, gestation days 0, 8, 12, 15, and postnatal days 0, 1, and 4 for female-B mice, postnatal days 0, 1, and 4 for F_1_ pups
Method of Sacrifice; Carbon dioxide asphyxiation
Necropsy; Complete necropsies were performed on all breeder animals except sperm-negative female-B mice Liver was weighed for male and female-A mice
Histopathology; Histopathology was performed on all male and female-A mice In addition to gross lesions and associated lymph nodes, the following tissues were examined Male mice - brain, bone marrow, epididymis, heart, kidneys, liver, lungs, lymph nodes (mandibular and mesenteric), spleen, stomach, and thymus Female-A mice - liver and stomach Pups were examined externally only
Clinical Pathology; Hematology (all animals) and clinical chemistry (male and female-A mice) evaluations were conducted at terminal sacrifice, except for those designated for plasma AZT and rifabutin level determinations; Hematology erythrocyte, reticulocyte, and platelet counts, hematocrit, hemoglobin, mean cell hemoglobin, mean cell volume, mean cell hemoglobin concentration, leukocyte counts and differentials, erythrocyte and platelet morphology (if necessary); Clinical Chemistry sorbitol dehydrogenase, alanine aminotransferase, alkaline phosphatase, and aspartate aminotransferase activities and bile acid concentrations of male and female-A mice
Plasma AZT and Rifabutin Levels; Selected animals from selected dose groups (male and female-A mice only) were bled for plasma AZT and rifabutin level determinations
Sperm Motility Evaluation; Sperm samples were collected from all males at terminal sacrifice The parameters evaluated included spermatid heads, spermatid counts, and motility The left epididymis and cauda epididymis were weighed

## Statistical Methods

Paternal and maternal body weights were analyzed using Bartlett’s test of homogeneity of variances and the analysis of variance (Snedecor and Cochran, 1967a). If Bartlett’s test was not significant (P > 0.05) and the analysis of variance was significant (P≤0.05), then Scheffe’s test (Scheffe, 1953) was used to identify the statistical significance of individual groups. If Bartlett’s test was significant (P≤0.05), the Kruskal-Wallis test (Sokal and Rohlf, 1969) was used; in cases in which the Kruskal-Wallis test was significant (P≤0.05), Dunn’s (1964) method of multiple comparisons was used to identify the statistical significance of individual groups. These methods were also used to analyze fetal body weight and pup body weight (per litter) as well as all other evaluations involving continuous data. For F_0_ generation sires and dams, the analysis of covariance (Snedecor and Cochran, 1967b) was used to evaluate mean body weight changes and mean maternal body weight changes. Observations for delivered and dead conceptuses of the female-A dams and for fetuses from female-A dams caesarean-sectioned on an estimated day 14 of gestation were excluded from fetal body weight summaries and statistical analyses.

Group means and standard deviations were calculated for hematology and clinical chemistry parameters and for final mean body and epididymis weights. Epididymis-weight-to-body-weight ratios were also calculated. Final mean body weights of males and females and mean epididymis weights and epididymis-weight-to-bodyweight ratios for males for each dosed group were compared to those of the control group by a two-tailed Student’s t-test. The standard deviations used in the t-tests were obtained by pooling the individual values for the vehicle control and dosed groups. Hematology and clinical chemistry data were evaluated using Dunnett’s (1955) test.

Severity grades for lesions in liver, spleen, thymus, stomach, and bone marrow were analyzed for interaction using two-way analysis of variance. If a significant interaction between AZT and rifabutin was observed, mean values were plotted to graphically display the interaction between the two chemicals. In the absence of interaction, vehicle control and dosed group means were compared using either Williams’ (Williams, 1971, 1972) or Dunnett’s (Dunnett, 1955) multiple comparison procedures. The choice between the two tests was based on evidence of a dose-related trend in the data as determined by Jonckheere’s test (Jonckheere, 1954). Williams’ test was applied if there was an indication of trend (P≤0.01), and Dunnett’s test was used in the absence of a trend. In selected cases in which interaction was found to be significant, the multiple comparison tests described above were used to detect treatment-related effects.

Proportion data (e.g., clinical findings and incidences of pregnancy, resorption, death, and total resorption) for mice presumed pregnant were analyzed using the Cochran-Armitage test for a linear trend in proportions (Snedecor and Cochran, 1967c) and Fisher’s exact test (Siegel, 1956). Epididymal sperm motility data were analyzed by the Wilcoxon rank sum test for pairwise nonparametric comparisons (Wilcoxon, 1945).