# Introduction

AIDS is a lethal multi-system disease that has become a major public health problem since its recognition in 1981 (Gottlieb et al., 1981; Masur et al., 1981; Siegal et al., 1981). The etiological agent of AIDS is a retrovirus now referred to as HIV (Coffin, 1986). To date, the most effective single agent in the treatment of HIV has been the first dideoxynucleoside analogue used in clinical trials, zidovudine (3′-azido-3′-deoxythymidine, AZT, Retrovir, azidothymidine, compound S, BW A509U, CAS No. 30516-87-1) commonly referred to as AZT (Vince et al., 1988; Amin, 1989).

AZT therapy produces numerous beneficial effects in AIDS patients, including decreases in morbidity and increases in lifespan (Amin, 1989; Jeffries, 1989). The most important adverse effects of AZT are anemia and granulocytopenia, which are believed to reflect bone marrow toxicity (Richman, 1988; Amin, 1989). Two types of anemia may occur with AZT therapy: macrocytic megaloblastic anemia and normocytic normochromic anemia.

Several subacute and subchronic rodent toxicity studies have demonstrated that the primary toxicity of AZT is myelosuppression. Male Swiss (CD-1®) mice were administered 100, 250, 500, or 1,000 mg AZT/kg body weight by gavage for 30 days (Mansuri et al., 1990). No mortality or body weight effects were evident from AZT treatment. Erythropenia and increased mean cell volume were observed at all doses, and anemia was observed at the 1,000 mg/kg dose. Pathologic findings in the AZT-treated mice were consistent with the hematologic results and included lymphoid depletion, reticuloendothelial hyperplasia in spleen and thymus, and bone marrow hypocellularity.

In a 14-week subchronic study (NTP, 1999), B6C3F_1_ mice were treated with 0, 25, 50, 100, 400, or 1,000 mg AZT/kg body weight in 0.5% methylcellulose by gavage twice daily. On day 5, statistically significant dose-related decreases were observed in reticulocyte counts in both males and females. Dose-related anemia was evident on days 23 and 93. To evaluate the ability of treated animals to reverse any compound-related effects when treatment is stopped, additional groups were administered 0, 50, 400, or 1,000 mg/kg AZT twice daily for 92 days and then held without additional treatment for 29 days. Improvement of hematology parameters indicated recovery of the bone marrow after treatment stopped. An apparently nontoxic, treatment-related clinical finding that affected AZT-treated B6C3F_1_ mice was a darkening of the skin on the tail, feet, and/or muzzle.

Oral bioavailability of AZT was determined in female B6C3F_1_ mice by comparison of the area under the curve obtained from an oral dose to that of an intravenous dose at the same concentration (Trang et al., 1993). Bioavailability was found to be 0.86, 0.78, and 0.97 for the 15, 30, and 60 mg/kg oral doses. The mean elimination half-life values ranged from 17.3 to 19.9 minutes for the three intravenous doses and from 16.5 to 21.9 minutes for the three oral doses. Based on these results, the internal dose of AZT was linear and dose proportional over the oral-dose concentration range administered.

Standard teratology studies of AZT have been performed in rats and rabbits (Ayers, 1988). Rats were dosed orally with 125 to 500 mg/kg on gestation days 6 to 15. No fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 61 μg/g, or 76 times the antiviral inhibitory dose for 50% of the viral population being tested (ID_50_). Rabbits were orally dosed at 125 to 500 mg/kg on gestation days 6 to 18, and no fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 40.2 μg/g, or 50 times the antiviral ID_50_.

Female Wistar rats were dosed three times orally with 100 mg/kg AZT at 5-hour intervals on gestation day 10 for a total dose of 300 mg/kg (Greene et al., 1990). No adverse effects on maternal body weight gain, food consumption, fertility, hematologic parameters, or growth or survival of offspring were observed. AZT concentration measurements 30 minutes after the last dose were 62.6 μg/mL in maternal plasma and 21.1 μg/g in fetal tissue.

Studies in C_3_H/He mice concluded that AZT has a direct toxic effect on the developing mouse embryo (Toltzis et al., 1991). Female mice were exposed to 0, 0.25, 0.5, or 2.5 mg AZT/mL drinking water for 8 weeks during mating and throughout gestation. All AZT groups had fewer pregnant mice per group, fewer pups per litter, and increased resorptions per mouse. Dose-related embryolethality was observed.

Disseminated infection with the Mycobacterium avium complex (MAC) is the most common cause of bacteremia in AIDS patients, occurring in as many as 50% of these patients (Masur, 1993). Survival of AIDS patients with MAC infection is half that of nonMAC-infected patients. Existing treatment regimens are not consistently successful, and relapses are common. Rifabutin, a rifamycin analogue, has shown significant activity against MAC in vitro and in vivo.

The pathogenic agent MAC, a ubiquitous organism, can be isolated from water, soil, and a variety of animals including dogs, cats, chickens, pigs, and insects (Masur, 1993). MAC infection was historically associated with chronic lung disease and received little attention; disseminated disease was rare, even in severely immunocompromised patients. Infection occurs via respiratory or gastrointestinal routes, and the gastrointestinal tract is thought to be the most common site of colonization and dissemination.

For reasons not understood, AIDS patients are uniquely predisposed to development of disseminated MAC disease. Fifteen to fifty percent of HIV-infected patients are infected with MAC, which is characterized by fever, diarrhea, night sweats, weight loss, anemia, abdominal pain, and elevated serum alkaline phosphatase. MAC is associated with advanced HIV infection; patients with CD4 lymphocyte counts less that 100/mm^3^ are considered to have increased risk for MAC. Other factors that correlate with the development of disseminated disease are previous opportunistic infection, an interruption in AZT therapy, and significant anemia. The effect of untreated disseminated disease in AIDS patients is unknown, although several studies have suggested that it is associated with decreased survival (Chaisson et al., 1992).

Until recently, available antimicrobial drugs were not active against MAC (Masur, 1993). The intracellular location of this organism serves to protect it from drugs that do not penetrate the plasma membrane. Recently, several new antimicrobial agents have been developed including rifabutin, the first drug approved by the FDA targeted against this organism. Rifabutin, 4-deoxo-3,4-[2-spiro-(N-isobutyl-4-piperidyl)](1H)-imidazole(2,5-dihydro)-rifamycin S, is a semisynthetic spiropiperidyl derivative of rifamycin S.

Following oral administration in humans, rifabutin is rapidly but incompletely absorbed; measurable amounts of the drug are detected in the serum within 30 minutes. Peak serum levels occur 4 hours after administration. The half-life in serum is 16 hours, with detectable levels still present at 24 hours after ingestion.

Two hours after an oral dose of rifabutin in rats, the highest concentrations were found in the liver, followed by lung, abdominal adipose tissue, and spleen (Battaglia et al., 1991). Seventy-two hours after administration, the sequence was abdominal adipose tissue, liver, spleen, bone marrow, and lung.

Pharmacokinetic parameters of rifabutin in healthy male volunteers given 28 doses of 300 to 1,200 mg/day were reported by Skinner et al. (1989). The plasma concentration data were consistent with a two-compartment open model with a terminal half-life of 36 hours. Following the 1,200 mg dose, peak and trough plasma levels were 907 and 194 ng/mL, respectively.

^14^C-Rifabutin is eliminated by renal and fecal routes (Battaglia et al., 1991); the renal route appears to predominate in humans (50.19%) and monkeys (46.73%), whereas fecal excretion is the major elimination route in rats (48.09%) and rabbits (45.01%). Peak plasma levels occurred in 1 to 4 hours in these species.

Significant levels of 31-OH rifabutin were detected by 8 to 24 hours in all four species. The 25-O-deacetyl metabolite was detected in rats and humans only. Polar metabolites were also detected. Rifabutin was excreted unchanged in urine in the rat (8.5%) and in humans (4.6%); only trace amounts were found in rabbit and monkey urine.

Few reports on the toxicity of rifabutin in animals are available. Efficacy studies did not include adverse effects of the drug at the concentrations tested. However, the Physician’s Desk Reference (1995) does include the following: increased bilirubin and liver weight have been reported in rats, mice, and monkeys given 5, 6, and 8 times the human daily dose. Testicular atrophy was seen in baboons and rats at four and 40 times the recommended human dose, respectively.

Rifabutin causes multinucleated hepatocytes in rats (Scampini et al., 1993). Multinucleated hepatocytes were dose- and gender-related and appeared predominantly in male rats after 5 weeks of treatment. This effect is unique to the rat, not caused by rifampin (a derivative of rifabutin), and not associated with an increased number of liver tumors.

In a clinical study of the antiviral activity of rifabutin, Siegal et al. (1990) reported a reversible syndrome of arthralgia/arthritis in patients receiving doses that exceeded 1,050 mg/day; aphthous stomatitis and uveitis were seen at doses above 1,800 mg/day. Doses less than 1 g/day were well tolerated in patients with AIDS-related complex. An orange-tan skin pigmentation and discoloration of body fluids were noted in almost all patients. Other adverse effects of rifabutin include neutropenia, thrombocytopenia, rash, nausea, flatulence, serum aminotransferase elevations, and myositis.

The myelotoxicity of rifabutin in combination with AZT in vitro was investigated in anticipation of a synergistic effect of these drugs (Volpe et al., 1993). While both AZT (5 μM) and rifabutin (5 μM) alone were moderately toxic to hematopoietic progenitors and slightly toxic to granulocyte-macrophage precursors, the combination of these drugs did not exceed the toxicity of AZT alone.

## Study Rationale

The objective of this study was to obtain controlled laboratory data on the general and reproductive and developmental toxicity of AZT and rifabutin when administered in combination to mice. Male and female mice were administered AZT (200 or 400 mg/kg) alone, rifabutin (80, 320, or 640 mg/kg) alone, or combinations of AZT and rifabutin by gavage. Mice were treated twice daily, approximately 6 hours apart. Adult mice were evaluated for mortality, clinical signs, body weight, sperm function, pathology, plasma drug levels, and clinical pathology parameters. Offspring were evaluated for viability, external abnormalities, and weight.