# APPENDIX B Liver Weights

TABLE B1 Mean Absolute Liver Weights for Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations^a^

Dose | Male | Female-A
0 + 0 | 1.7940 ± 0.2359 | 2.5388 ± 0.1378
0 + 80 | 1.8280 ± 0.1468 | 2.7959 ± 0.1668^b^
0 + 320 | 1.9620 ± 0.1526 | 2.6660 ± 0.5721^c^
0 + 640 | 2.2410 + 0.2725^*^ | 3.4033 + 0.2499^*^,^d^
200 + 0 | 1.7590 ± 0.1642 | 2.4057 ± 0.4349^e^
200 + 80 | 1.7970 ± 0.1215 | 2.4692 + 0.3619^f^
200 + 320 | 2.0920 ± 0.3185^*^ | 2.7300 ± 0.8778^b^
200 + 640 | 2.1690 ± 0.2907^*^ | —^g^
400 + 0 | 1.7800 ± 0.1658 | 2.2706 ± 0.4702
400 + 80 | 1.9090 ± 0.2037 | 2.1150 ± 0.3142^h^
400 + 320 | 2.0130 ± 0.2193^*^ | 1.470^i^
400 + 640 | 1.8580 ± 0.3247 | —

* Significantly different (P≤0.05) from the vehicle control group by Dunnett’s test

a Daily gavage doses of AZT + rifabutin (mg/kg per day). Mean absolute liver weights given in grams (mean ± standard deviation); for males, n=10; for females, n=16, unless otherwise noted.

b n=9

c n=10

d n=3

e n=14

f n=13

g No data were available due to 100% mortality in this group.

h n=4

i n=1