# APPENDIX A Clinical Pathology Results

TABLE A1 Hematology Data for Male Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations^a^

Dose | WBC^b^; (10^3^/mm^3^) | RBC; (10^6^/mm^3^) | Hgb; (g/dL) | Hct; (%) | MCV; (fL) | MCH; (pg) | MCHC; (g/dL) | Platelets; (10^3^/mm^3^) | Reticulocytes; (10^5^/mm^3^) | Neutrophils; (10^3^/mm^3^) | Lymphocytes; (10^3^/mm^3^) | Monocytes; (10^3^/mm^3^) | Eosinophils; (10^3^/mm^3^) | Basophils; (10^3^/mm^3^) | LUC^d^; (10^3^/mm^3^)
0 + 0 | 6.97; 1.960 | 9.47; 0.536 | 15.9; 0.86 | 45.7; 2.00 | 48.3; 1.76 | 16.8; 0.53 | 34.9; 0.96 | 992; 266.3 | 4.5; 0.64 | 1.00; 0.304 | 5.53; 1.673 | 0.13; 0.053 | 0.24; 0.110 | 0.02; 0.011 | 0.05; 0.021
200 + 0 | 5.37; 1.786 | 8.36; 0.550 | 14.7; 0.88 | 43.1; 2.90 | 51.6; 2.66 | 17.6; 0.67 | 34.1; 1.22 | 1,320; 127.9 | 5.0; 0.90 | 0.87; 0.342 | 4.24; 1.591 | 0.08; 0.074 | 0.15; 0.051 | 0.01; 0.010 | 0.03^e^; 0.033
400 +0 | 4.81; 1.501 | 8.33^*^; 0.556 | 14.6; 0.76 | 43.1; 3.02 | 51.7; 2.28 | 17.6; 0.71 | 34.1; 0.99 | 1,469; 402.6 | 4.9; 1.02 | 0.68; 0.235 | 3.82; 1.286 | 0.10; 0.054 | 0.18; 0.091 | 0.01; 0.005 | 0.03^f^; 0.014
0 + 80 | 5.62; 2.289 | 9.51; 0.692 | 15.7; 0.94 | 46.2; 3.44 | 48.6; 1.66 | 16.5; 0.47 | 34.0; 0.99 | 1,088; 243.6 | 5.3; 0.64 | 0.93; 0.368 | 4.32; 1.849 | 0.09; 0.040 | 0.23; 0.149 | 0.02; 0.011 | 0.03; 0.020
200 + 80 | 5.83; 1.613 | 8.15^*^; 0.533 | 14.2; 1.01 | 41.8; 2.46 | 51.3; 1.93 | 17.5; 0.85 | 34.1; 0.75 | 1,439; 407.3 | 4.9; 0.63 | 0.75; 0.229 | 4.66; 1.524 | 0.10; 0.035 | 0.25; 0.091 | 0.01; 0.007 | 0.06; 0.033
400 + 80 | 6.14; 2.424 | 7.43^**^; 0.561 | 13.2^**^; 0.71 | 38.4^*^; 2.03 | 51.8; 2.18 | 17.8; 0.76 | 34.4; 0.97 | 1,693^**^; 442.8 | 5.1; 0.78 | 0.68; 0.290 | 5.08; 2.002 | 0.11; 0.060 | 0.22; 0.198 | 0.02; 0.013 | 0.05^f^; 0.030
0 + 320^c^ | 8.24; 2.042 | 8.47; 0.617 | 13.7^*^; 1.11 | 40.7; 2.23 | 48.2; 1.74 | 16.2; 0.55 | 33.7; 1.24 | 1,300; 302.9 | 6.6; 2.33 | 1.75; 0.524 | 6.04; 1.655 | 0.14; 0.042 | 0.21; 0.106 | 0.03; 0.011 | 0.08; 0.038
200 + 320 | 6.49; 2.169 | 6.99^**^; 0.521 | 12.5^**^; 0.77 | 38.1^*^; 2.48 | 54.6^**^; 1.95 | 17.9^*^; 0.60 | 32.8; 0.45 | 1,497^*^; 275.7 | 6.1; 1.46 | 1.16; 0.513 | 4.92; 1.679 | 0.10; 0.042 | 0.23; 0.082 | 0.02; 0.013 | 0.07; 0.043
400 + 320^c^ | 5.04; 1.206 | 6.09^**^; 1.488 | 10.5^**^; 2.48 | 32.0^**^; 8.40 | 52.2; 5.83 | 17.3; 1.23 | 33.3; 2.08 | 1,562^*^; 650.3 | 7.3; 4.01 | 0.93; 0.667 | 3.77; 0.748 | 0.08; 0.049 | 0.18; 0.157 | 0.01; 0.010 | 0.07; 0.032
0 + 640^c^ | 8.26; 2.971 | 8.65; 0.879 | 13.6^*^; 1.12 | 39.7; 4.00 | 45.9; 0.91 | 15.7; 0.56 | 34.2; 1.12 | 1,357; 116.4 | 8.1; 0.91 | 2.04^**^; 0.599 | 5.73; 2.638 | 0.13; 0.041 | 0.24; 0.192 | 0.03; 0.020 | 0.09; 0.064
200 + 640 | 6.02; 3.425 | 4.13^**^; 2.012 | 7.3^**^; 3.92 | 21.9^**^; 13.98 | 49.8; 10.92 | 17.3; 1.82 | 35.6; 4.92 | 1,921^**^; 410.1 | 6.3; 6.74 | 1.49; 1.432 | 3.95; 2.040 | 0.13; 0.082 | 0.26; 0.393 | 0.01; 0.015 | 0.19^**^,^f^; 0.169
400 + 640^c^ | 2.92; 1.246 | 2.31^**^; 0.458 | 3.7^**^; 0.73 | 9.2^**^; 2.08 | 39.7^**^; 3.55 | 15.9; 0.63 | 40.1^**^; 2.56 | 2,135^**^; 825.1 | 1.1; 0.50 | 0.74; 0.642 | 2.05; 0.645 | 0.04; 0.039 | 0.04; 0.032 | 0.00; 0.005 | 0.06; 0.042^g^

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day). For each parameter, the mean is presented above the standard deviation; n=10, unless otherwise noted.

b WBC counts corrected for RBC test counts greater than 10 per 100 WBCs

c n=7

d Large unstained cells

e n=8

f n=9

g n=6

TABLE A2 Hematology Data for Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations^a^

Dose | WBC^b^; (10^3^/mm^3^) | RBC; (10^6^/mm^3^) | Hgb; (g/dL) | Hct; (%) | MCV; (fL) | MCH; (pg) | MCHC; (g/dL) | Platelets; (10^3^/mm^3^) | Reticulocytes; (10^5^/mm^3^) | Neutrophils; (10^3^/mm^3^) | Lymphocytes; (10^3^/mm^3^) | Monocytes; (10^3^/mm^3^) | Eosinophils; (10^3^/mm^3^) | Basophils; (10^3^/mm^3^) | LUC^h^; (10^3^/mm^3^)
0 + 0 | 7.68; 2.671 | 8.74; 0.624 | 14.6; 0.92 | 42.8; 2.52 | 49.1; 1.88 | 16.8; 0.73 | 34.1; 1.04 | 1,382; 339.7 | 4.1; 0.96 | 2.62; 1.584 | 4.67; 1.137 | 0.17; 0.069 | 0.15; 0.081 | 0.02; 0.013 | 0.05; 0.054
200 + 0 | 5.69^*^; 1.548 | 7.51^**^; 0.594 | 14.0; 0.73 | 41.9; 2.62 | 55.9^**^; 3.06 | 18.8^**^; 1.00 | 33.6; 0.85 | 1,672; 206.8 | 4.2; 0.89 | 1.10^**^; 0.444 | 4.21; 1.272 | 0.11; 0.054 | 0.22; 0.161 | 0.01; 0.007 | 0.03; 0.014
400 + 0 | 5.86; 1.111 | 7.71^**^; 0.710 | 14.6; 1.00 | 43.7; 3.12 | 56.8^**^; 3.17 | 19.0^**^; 0.95 | 33.4; 0.97 | 1,379; 474.3 | 4.6; 1.56 | 1.19^**^; 0.600 | 4.31; 0.897 | 0.14; 0.083 | 0.16; 0.092 | 0.01; 0.007 | 0.04^i^; 0.029
0 + 80^c^ | 8.28; 3.034 | 8.81; 0.648 | 14.7; 0.91 | 43.5; 2.62 | 49.4; 1.84 | 16.8; 0.71 | 33.9; 1.17 | 1,163; 416.5 | 4.6; 1.49 | 2.65; 2.058 | 5.10; 1.014 | 0.20; 0.089 | 0.23; 0.217 | 0.02; 0.018 | 0.07^j^; 0.114
200 + 80 | 6.34; 1.934 | 7.11^**^; 0.785 | 13.5; 1.37 | 40.7; 4.26 | 57.3^**^; 2.07 | 19.0^**^; 0.79 | 33.2; 1.01 | 1,509; 233.6 | 4.3; 1.29 | 1.19^**^; 0.600 | 4.78; 1.398 | 0.12; 0.058 | 0.20; 0.140 | 0.02; 0.008 | 0.04; 0.019
400 + 80^d^ | 5.32^*^; 1.470 | 6.96^**^; 0.702 | 13.2; 1.16 | 39.7; 3.89 | 57.1^**^; 2.06 | 19.0^**^; 0.54 | 33.3; 0.79 | 1,354; 335.2 | 5.4; 2.11 | 1.07^**^; 0.771 | 3.90; 0.975 | 0.09; 0.051 | 0.21; 0.116 | 0.01; 0.009 | 0.04^j^; 0.022
0 + 320^c^ | 8.65; 2.542 | 8.88; 0.463 | 14.5; 0.88 | 44.0; 2.48 | 49.6; 1.96 | 16.3; 0.82 | 32.9; 0.80 | 1,217; 232.1 | 3.9; 1.09 | 2.83; 1.224 | 5.43; 1.837 | 0.13; 0.065 | 0.16; 0.134 | 0.03; 0.015 | 0.08; 0.046
200 + 320^e^ | 6.41; 2.879 | 5.99^**^; 2.017 | 11.7^**^; 4.01 | 35.6^**^; 12.47 | 58.0^**^; 8.74 | 19.2^**^; 1.83 | 33.4; 2.65 | 1,504; 322.5 | 3.7^d^; 1.67 | 1.66; 0.995 | 4.29; 1.890 | 0.11; 0.060 | 0.25; 0.163 | 0.01; 0.011 | 0.08; 0.053
400 + 320^f^ | 4.34; 2.566 | 2.85^**^; 2.633 | 5.2^**^; 4.97 | 15.8^**^; 17.3 | 49.6; 10.52 | 17.6; 0.95 | 36.3; 5.50 | 2,279; 683.4 | 2.4; 2.53 | 0.91; 0.692 | 3.22; 1.636 | 0.09; 0.107 | 0.10; 0.153 | 0.00; 0.006 | 0.02^k^; 0.007
0 + 640^c^ | 11.18^**^; 2.250 | 9.23; 0.885 | 14.6; 1.15 | 43.3; 4.18 | 47.0; 2.05 | 15.9; 0.49 | 33.8; 1.66 | 1,218; 314.3 | 5.7; 2.08 | 3.85^*^; 1.818 | 6.70; 1.606 | 0.18; 0.080 | 0.16; 0.066 | 0.07; 0.102 | 0.25^**^; 0.218
200 + 640^g^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
400 + 640^g^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day). For each parameter, the mean is presented above the standard deviation; n=20, unless otherwise noted.

b WBC counts corrected for RBC test counts greater than 10 per 100 WBCs

c n=12

d n=14

e n=15

f n=3

g No data were available due to 100% mortality in this group.

h Large unstained cells

i n=19

j n=11

k n=2

TABLE A3 Hematology Data for Female-B Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations^a^

Dose | WBC^b^; (10^3^/mm^3^) | RBC; (10^6^/mm^3^) | Hgb; (g/dL) | Hct; (%) | MCV; (fL) | MCH; (pg) | MCHC; (g/dL) | Platelets; (10^3^/mm^3^) | Reticulocytes; (10^5^/mm^3^) | Neutrophils; (10^3^/mm^3^) | Lymphocytes; (10^3^/mm^3^) | Monocytes; (10^3^/mm^3^) | Eosinophils; (10^6^/mm^3^) | Basophils; (10^3^/mm^3^) | LUC^g^; (10^3^/mm^3^)
0 + 0^c^ | 4.92; 1.452 | 8.44; 0.542 | 14.5; 0.81 | 43.4; 2.18 | 51.4; 1.70 | 17.2; 0.49 | 33.4; 0.64 | 1,262; 279.3 | 4.6; 1.27 | 1.06; 0.328 | 3.54; 1.188 | 0.10; 0.031 | 0.20; 0.212 | 0.01; 0.011 | 0.02^h^; 0.013
200 + 0^c^ | 5.85; 1.577 | 7.91; 0.538 | 14.0; 0.58 | 42.4; 1.43 | 53.8; 2.76 | 17.8; 1.02 | 33.0; 0.95 | 1,522; 259.9 | 5.5; 1.75 | 1.07; 0.305 | 4.48; 1.338 | 0.10; 0.040 | 0.15; 0.095 | 0.02; 0.010 | 0.03; 0.011
400 + 0^d^ | 5.44; 1.838 | 8.28; 0.614 | 14.5; 0.98 | 44.1; 2.70 | 53.3; 2.79 | 17.5; 0.89 | 32.9; 0.99 | 1,262; 276.2 | 6.1; 2.46 | 1.02; 0.481 | 4.11; 1.530 | 0.10; 0.051 | 0.18; 0.088 | 0.01; 0.008 | 0.02^i^; 0.015
0 + 80^c^ | 5.46; 1.376 | 8.83; 0.913 | 14.7; 1.10 | 43.6; 2.64 | 49.7; 3.10 | 16.7; 0.78 | 33.7; 1.29 | 1,358; 258.2 | 4.5; 1.67 | 1.12; 0.595 | 4.07; 1.054 | 0.10; 0.069 | 0.14; 0.121 | 0.01; 0.010 | 0.02^j^; 0.009
200 + 80^c^ | 5.66; 1.506 | 8.05; 0.758 | 14.3; 0.98 | 43.3; 3.38 | 54.0; 2.83 | 17.8; 0.73 | 33.0; 1.09 | 1,267; 343.8 | 4.8; 1.47 | 0.93; 0.273 | 4.36; 1.285 | 0.09; 0.046 | 0.24; 0.156 | 0.01; 0.011 | 0.03^h^; 0.012
400 + 80 | 5.55; 1.550 | 8.31; 0.671 | 14.8; 0.83 | 44.2; 2.08 | 53.4; 3.14 | 17.9; 0.93 | 33.5; 0.66 | 1,242; 266.3 | 5.5; 2.05 | 1.09; 0.385 | 4.06; 1.130 | 0.11; 0.048 | 0.26; 0.167 | 0.01; 0.007 | 0.03^c^; 0.016
0 + 320^e^ | 6.45; 1.793 | 8.66; 0.697 | 14.5; 1.17 | 44.3; 3.29 | 51.2; 2.58 | 16.8; 0.71 | 32.8; 0.96 | 1,455; 286.2 | 5.4; 1.78 | 1.19; 0.525 | 4.92; 1.387 | 0.12; 0.087 | 0.19; 0.171 | 0.02; 0.012 | 0.03^k^; 0.012
200 + 320 | 6.06; 0.985 | 7.98; 0.514 | 14.2; 0.70 | 43.6; 2.30 | 54.7^**^; 2.72 | 17.8; 0.75 | 32.5; 0.63 | 1,352; 268.5 | 5.7; 2.43 | 1.18; 0.425 | 4.51; 0.964 | 0.11; 0.030 | 0.22; 0.114 | 0.02; 0.008 | 0.03^c^; 0.017
400 + 320^f^ | 6.71; 1.853 | 8.35; 0.744 | 14.5; 1.40 | 45.4; 4.37 | 54.4^*^; 2.77 | 17.4; 0.71 | 32.0^**^; 0.94 | 1,545; 551.9 | 7.4; 6.16 | 1.30; 0.391 | 4.95; 1.469 | 0.12; 0.053 | 0.27; 0.225 | 0.02; 0.014 | 0.05; 0.056
0 + 640 | 5.44; 1.645 | 8.37; 0.727 | 13.8; 1.13 | 42.1; 3.56 | 50.3; 1.53 | 16.5; 0.65 | 32.9; 1.00 | 1,644; 485.9 | 7.0; 1.98 | 1.24; 0.383 | 3.84; 1.256 | 0.12; 0.083 | 0.18; 0.108 | 0.01; 0.010 | 0.04^c^; 0.026
200 + 640 | 6.40; 2.859 | 7.63^*^; 1.025 | 13.6; 1.81 | 42.9; 4.66 | 56.6^**^; 4.06 | 17.8; 0.79 | 31.6^**^; 1.79 | 1,608; 488.3 | 7.3; 4.73 | 1.43; 0.698 | 4.53; 2.215 | 0.13; 0.065 | 0.26; 0.210 | 0.02; 0.011 | 0.03^c^; 0.024
400 + 640 | 8.46; 5.618 | 7.33^**^; 0.982 | 12.9; 1.90 | 42.1; 5.81 | 57.4^**^; 1.85 | 17.6; 0.53 | 30.7^**^; 1.09 | 1,786; 608.4 | 9.0; 5.11 | 2.27; 2.247 | 5.63; 3.529 | 0.17; 0.087 | 0.31; 0.148 | 0.02; 0.019 | 0.07^j^; 0.058

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day). For each parameter, the mean is presented above the standard deviation; n=16, unless otherwise noted.

b WBC counts corrected for RBC test counts greater than 10 per 100 WBCs

c n=15

d n=20

e n=17

f n=12

g Large unstained cells

h n=13

i n=18

j n=14

k n=16

TABLE A4 Clinical Chemistry Data for Male Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations^a^

Dose | ALP; (IU/L) | ALT; (IU/L) | AST; (IU/L) | SDH; (IU/L) | Bile Acids; (μmol/L)
0 + 0^b^ | 56; 30.4 | 26; 7.0 | 71^e^; 22.7 | 20^e^; 4.4 | 15^f^; 10.7
200 + 0^c^ | 55; 16.1 | 23; 5.2 | 59^g^; 33.6 | 23^e^; 4.9 | 7^h^; 1.4
400 + 0^c^ | 69; 20.3 | 29; 4.9 | 71; 22.7 | 24^g^; 5.9 | 13^e^; 9.2
0 + 80^c^ | 53; 11.6 | 24; 4.5 | 64^e^; 13.9 | 22^i^; 7.7 | 12^i^; 8.4
200 + 80^b^ | 59; 11.5 | 25; 5.6 | 54^e^; 6.3 | 19^e^; 9.7 | 12^f^; 7.4
400 + 80^c^ | 52; 12.6 | 24; 6.6 | 55^b^; 20.7 | 27^g^; 8.0 | 18^f^; 18.2
0 + 320 | 43; 10.3 | 35; 10.9 | 80; 31.1 | 23^e^; 5.6 | 19^i^; 16.1
200 + 320^d^ | 66; 22.8 | 36; 29.2 | 65; 17.1 | 22^g^; 8.6 | 17^e^; 13.3
400 + 320 | 43; 10.1 | 41; 23.8 | 72; 17.8 | 30^e^; 13.8 | 16^i^; 5.6
0+640 | 64; 21.2 | 65; 53.5 | 90^e^; 16.5 | 17^i^; 6.4 | 12^j^; 9.7
200 + 640^d^ | 63; 13.1 | 31; 19.5 | 74; 21.6 | 27^g^; 6.4 | 54^**^,^e^; 37.9
400 + 640 | 67; 16.9 | 21; 9.2 | 57; 13.4 | 25; 5.2 | 48^*^,^e^; 8.0

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day). For each parameter, the mean is presented above the standard deviation; n=7, unless otherwise noted.

b n=8

c n=9

d n=10

e n=6

f n=4

g n=7

h n=2

i n=5

j n=3

TABLE A5 Clinical Chemistry Data for Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Rifabutin Combinations^a^

Dose | ALP; (IU/L) | ALT; (IU/L) | AST; (IU/L) | SDH; (IU/L) | Bile Acids; (μmol/L)
0 + 0 | 52; 10.8 | 39; 16.6 | 118; 31.4 | 31^b^; 6.6 | 15^h^; 8.9
200 + 0^b^ | 71; 21.4 | 27; 7.5 | 87; 37.7 | 26^i^; 5.2 | 11^j^; 6.3
400 + 0 | 74; 20.9 | 31; 12.1 | 99^k^; 47.5 | 25^k^; 5.5 | 12^e^; 5.5
0 + 80^c^ | 40; 8.5 | 30; 5.8 | 94; 16.7 | 23^l^; 4.7 | 12^m^; 3.3
200 + 80 | 52; 11.1 | 25; 6.8 | 87; 23.1 | 27^k^; 3.5 | 12^k^; 6.4
400 + 80^d^ | 65; 17.4 | 23; 7.4 | 78; 30.7 | 24^m^; 7.6 | 15^l^; 8.4
0 + 320^e^ | 47; 11.8 | 75^*^; 50.3 | 122; 45.7 | 30^c^; 9.4 | 19^c^; 9.3
200 + 320^d^ | 63; 25.4 | 97^**^; 65.9 | 124^j^; 78.2 | 36^n^; 5.4 | 25^o^; 11.2
400 + 320^f^ | 82; 3.0 | 30; 18.2 | 109; 58.3 | 29^p^; 1.4 | 60^**^; 37.3
0 + 640^e^ | 67; 24.6 | 159^**^; 81.9 | 200; 120.6 | 29^q^; 10.3 | 31^**^,^m^; 10.8
200 + 640^g^ | — | — | — | — | —
400 + 640^g^ | — | — | — | — | —

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + rifabutin (mg/kg per day). For each parameter, the mean is presented above the standard deviation; n=20, unless otherwise noted.

b n=19

c n=11

d n=14

e n=12

f n=3

g No data were available due to 100% mortality in this group.

h n=15

i n=18

j n=13

k n=17

l n=10

m n=8

n n=7

o n=9

p n=2

q n=6