# References

Amin, N.M. (1989). Zidovudine for treating AIDS: What physicians need to know. Postgrad. Med. 86, 195–208.2662155
Ayers, K.M. (1988). Preclinical toxicology of zidovudine: An overview. Am. J. Med. 85, 186–188.3044084
Barnes, P.F., Bloch, A.B., Davidson, P.T., and Snider, D.E., Jr. (1991). Tuberculosis in patients with human immunodeficiency virus infection. N. Engl. J. Med. 324, 1644–1650.2030721
Benson, W.M., Stefko, P.L., and Roe, M.D. (1952). Pharmacologic and toxicologic observations on hydrazine derivatives of isonicotinic acid (Rimifon, Marsilid). Am. Rev. Respir. Dis. 65, 376–391.
Blakemore, W.F. (1986). Isoniazid. Neurotoxicology 1706, 476–489.
Centers for Disease Control (CDC), Department of Health and Human Services (1987). Diagnosis and management of mycobacterial infection and disease in persons with human immunodeficiency virus infection. Ann. Intern. Med. 106, 254–256.3800186
Coffin, J.M. (1986). Genetic variation in AIDS viruses. Cell 46, 1–4.3013415
Dixon, W.J., and Massey, F.J., Jr. (1951). Introduction to Statistical Analysis, 1st ed., pp. 145–147. McGraw-Hill Book Company, New York.
Dunn, O.J. (1964). Multiple comparisons using rank sums. Technometrics 6, 241–252.
Dunnett, C.W. (1955). A multiple comparison procedure for comparing several treatments with a control. J. Am. Stat. Assoc. 50, 1096–1121.
Goldschmidt, R.H., and Dong, B.J. (1992). Treatment of AIDS and HIV-related conditions: 1992. J. Am. Board Fam. Pract. 5, 335–350.1580182
Goodman and Gilman’s The Pharmacological Basis of Therapeutics (1990). 8th ed. (A.G. Gilman, T.W. Rall, A.S. Nies, and P. Taylor, Eds.), pp. 1146–1164. Pergamon Press, Inc., New York.
Gottlieb, M.S., Schroff, R., Schanker, H.M., Weisman, J.D., Fan, P.T., Wolf, R.A., and Saxon, A. (1981). Pneumocystis carinii pneumonia and mucosal candidiasis in previously healthy homosexual men: Evidence of a new acquired cellular immunodeficiency. N. Engl. J. Med. 305, 1425–1431.6272109
Greene, J.A., Ayers, K.M., de Miranda, P., and Tucker, W.E., Jr. (1990). Postnatal survival in Wistar rats following oral dosage with zidovudine on gestation day 10. Fundam. Appl. Toxicol. 15, 201–206.2373299
Hardy, W.D. (1991). Prophylaxis of AIDS-related opportunistic infections (OIs). Current status and future strategies. AIDS Clin. Rev. 145–180.1651099
Harkins, T., and Herriot, K.B. (1992). Medical management of acquired immune deficiency syndrome patients: A review. J. Am. Optom. Assoc. 63, 35–42.1583259
Harper, K.H., and Worden, A.N. (1966). Comparative toxicity of isonicotinic acid hydrazide and its methanosulfonate derivative. Toxicol. Appl. Pharmacol. 8, 325–333.5956883
Harris, M.W., Chapin, R.E., Lockhart, A.C., and Jokinen, M.P. (1992). Assessment of short-term reproductive and developmental toxicity screen. Fundam. Appl. Toxicol. 19, 186–196.1516774
Jacobson, M.A. (1988). Mycobacterial diseases: Tuberculosis and Mycobacterium avium complex. In Medical Management of AIDS (M.A. Sande, Ed.), pp. 235–246. W.B. Saunders, Philadelphia.
Jeffries, D.J. (1989). Targets for antiviral therapy of human immunodeficiency virus infection. J. Infect. 18 (Suppl. 1), 5–13.2464649
Jonckheere, A.R. (1954). A distribution-free k-sample test against ordered alternatives. Biometrika 41, 133–145.
Mansuri, M.M., Hitchcock, M.J., Buroker, R.A., Bregman, C.L., Ghazzouli, I., Desiderio, J.V., Starrett, J.E., Sterzycki, R.Z., and Martin, J.C. (1990). Comparison of in vitro biological properties and mouse toxicities of three thymidine analogs active against human immunodeficiency virus. Antimicrob. Agents Chemother. 34, 637–641.1693057
Masur, H., Michelis, M.A., Greene, J.B., Onorato, L., Stouwe, R.A., Holzman, R.S., Wormser, G., Brettman, L. Lange, M., Murray, H.W., and Cunningham-Rundles, S. (1981). An outbreak of community-acquired Pneumocystis carinii pneumonia: Initial manifestations of cellular immune dysfunction. N. Engl. J. Med. 305, 1431–1438.6975437
Mate, N.B., Maru, G.B., and Bhide, S.V. (1981). Studies on tumorigenicity and metabolism of isoniazid in mice and rats. Indian J. Exp. Biol. 19, 1037–1039.7338358
Menon, M.M., and Bhide, S.V. (1980). Transplacental, biological and metabolic effects of isoniazid (INH) in Swiss mice. Indian J. Exp. Biol. 18, 1104–1106.7216260
Menon, M.M., and Bhide, S.V. (1983). Perinatal carcinogenicity of isoniazid (INH) in Swiss mice. J. Cancer Res. Clin. Oncol. 105, 258–261.6853587
Morrissey, R.E., Harris, M.W., and Schwetz, B.A. (1989). Developmental toxicity screen: Results of rat studies with diethylhexyl phthalate and ethylene glycol monomethyl ether. Teratog. Carcinog. Mutagen. 9, 119–129.2568021
National Toxicology Program (NTP) (1999). Toxicology and Carcinogenesis Studies of AZT (CAS No. 30516-87-1) and AZT/α-Interferon A/D in B6C3F_1_ Mice (Gavage Studies). Technical Report Series No. 469. NIH Publication No. 99-3959. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, Research Triangle Park, NC.
Nolan, C.M. (1992). Human immunodeficiency syndrome-associated tuberculosis: A review with an emphasis on infection control issues. Am. J. Infect. Control 20, 30–34.1554145
Oksenhendler, E. (1989). Azidothymidine. Nouv. Rev. Fr. Hematol. 31, 69–72.2671931
Peretti, E., Karlaganis, G., and Lauterburg, B.H. (1987). Acetylation of acetylhydrazine, the toxic metabolite of isoniazid, in humans. Inhibition by concomitant administration of isoniazid. J. Pharmacol. Exp. Ther. 243, 686–689.3681700
Richman, D.D. (1988). The treatment of HIV infection. Azidothymidine (AZT) and other new antiviral drugs. Infect. Dis. Clin. North Am. 2, 397–407.2462584
Rubin, B., and Burke, J.C. (1953). Absorption, distribution, and excretion of isoniazid (Nydrazid) in the dog. Proc. Soc. Exp. Biol. Med. 107, 219–224.
Rubin, B., Hassert, G.L., Thomas, B.G.H., and Burke, J.C. (1952). Pharmacology of isonicotinic acid hydrazide (Nydrazid). Am. Rev. Respir. Dis. 65, 392–402.
Scheffe, H. (1953). A method for judging all contrasts in the analysis of variance. Biometrika 40, 87–104.
Shirley, E. (1977). A nonparametric equivalent of Williams’ test for contrasting increasing dose levels of a treatment. Biometrics 33, 386–389.884197
Siegal, F.P., Lopez, C., Hammer, G.S., Brown, A.E., Kornfeld, S.J., Gold, J., Hassett, J., Hirschman, S.Z., Cunningham-Rundles, C., Adelsberg, B.R., Parham, D.M., Siegal, M., Cunningham-Rundles, S., and Armstrong, D. (1981). Severe acquired immunodeficiency in male homosexuals manifested by chronic perianal ulcerative herpes simplex lesions. N. Engl. J. Med. 305, 1439–1444.6272110
Siegel, S. (1956). Nonparametric Statistics for the Behavioral Sciences, pp. 96–104. McGraw-Hill, New York.
Snedecor, G.W., and Cochran, W.G., Eds. (1967a). Analysis of variance. In Statistical Methods, 6th ed., pp. 258–275. Iowa State University Press, Ames, IA.
Snedecor, G.W., and Cochran, W.G., Eds. (1967b). Test for a linear trend in proportions. In Statistical Methods, 6th ed., pp. 246–248. Iowa State University Press, Ames, IA.
Sokal, R.R., and Rohlf, F.J. (1969a). Bartlett’s test of homogeneity of variances. In Biometry, pp. 370–371. W.H. Freeman and Company, San Francisco.
Sokal, R.R., and Rohlf, F.J. (1969b). Kruskal-Wallis test. In Biometry, pp. 388–389. W.H. Freeman and Company, San Francisco.
Tannen, R.H., and Weber, W.W. (1979). Rodent models of the human isoniazid-acetylator polymorphism. Drug Metab. Dispos. 7, 274–279.40765
Timbrell, J.A. (1979). The role of metabolism in the hepatotoxicity of isoniazid and iproniazid. Drug Metab. Rev. 10, 125–147.393481
Timbrell, J.A. (1981). Isoniazid metabolism in relation to hepatotoxicity. In Drug Reactions in the Liver (M. Davis, J.M. Tredger, and R. Williams Eds.), pp. 190–196. Pitman Medical, London.
Timbrell, J.A., Mitchell, J.R., Snodgrass, W.R., and Nelson, S.D. (1980). Isoniazid hepatotoxicity: The relationship between covalent binding and metabolism in vivo. J. Pharmacol. Exp. Ther. 213, 364–369.6767840
Toltzis, P., Marx, C.M., Kleinman, N., Levine, E.M., and Schmidt, E.V. (1991). Zidovudine-associated embryonic toxicity in mice. J. Infect. Dis. 163, 1212–1218.2037787
Trang, J.M., Prejean, J.D., James, R.H., Irwin, R.D., Goehl, T.J., and Page, J.G. (1993). Zidovudine bioavailability and linear pharmacokinetics in female B6C3F_1_ mice. Drug Metab. Dispos. 21, 189–193.8095218
Vince, R., Hua, M., Brownell, J., Daluge, S., Lee, F.C., Shannon, W.M., Lavelle, G.C., Qualls, J., Weislow, O.S., Kiser, R., Canonico, P.G., Schultz, R.H., Narayanan, V.L., Mayo, J.G., Shoemaker, R.H., and Boyd, M.R. (1988). Potent and selective activity of a new carbocyclic nucleoside analog (Carbovir: NSC 614846) against human immunodeficiency virus in vitro. Biochem. Biophys. Res. Commun. 156, 1046–1053.2847711
Wilcoxon, F. (1945). Individual comparisons by ranking methods. Biometrics 1, 80–83.