# Peer Review

The draft report on the reproductive, developmental, and general toxicity studies of 3′-azido-3′-deoxythymidine and isoniazid combinations was evaluated by the peer reviewers listed below. These reviewers serve as independent scientists, not as representatives of any institution, company, or governmental agency. In this capacity, reviewers determine if the design and conditions of these studies are appropriate and ensure that this reproductive, developmental, and general toxicity study report presents the experimental results and conclusions fully and clearly. The comments of the reviewers were reviewed prior to the finalization of this document. Changes were made such that the concerns of the reviewers were addressed to the extent possible.

- Lisa B. Biegel, Ph.D.
  E. I. du Pont de Nemours and Company
  Haskell Laboratory
  Newark, DE
- Eric D. Clegg, Ph.D.
  U.S. Environmental Protection Agency
  National Center for Environmental Assessment
  Washington, DC