# Results and Discussion

## Survival and Clinical Findings

### Male Mice

All males survived to the end of the study with the exception of one death due to a dosing accident in the 100 + 100 mg/kg group. No clinical findings of toxicity were observed in male mice.

### Female-A Mice

Five female-A mice died during the study; three of the deaths resulted from dosing accidents. Of the two remaining deaths, one death occurred on day 18 in the 200 + 150 mg/kg group and the other death occurred on day 30 in the group administered 400 + 150 mg/kg; the cause of these two deaths was undetermined. No clinical findings of toxicity were observed in any of the female-A mice.

### Female-B Mice

All female-B mice survived to the end of the study. No clinical findings of toxicity were observed in any of the female-B mice.

## Body and Organ Weights

### Male Mice

The mean body weights of male mice were unaffected by the administration of AZT alone or in combination with isoniazid (Figure 1). Absolute right epididymal weights were increased in all dose groups relative to the vehicle controls, and the increases were significant (P≤0.05) in all groups except the 100 + 0 and 0 + 50 mg/kg groups. The effects of the combined administration of AZT and isoniazid did not appear to be biologically significant, as they were not additive or synergistic (Table 3).

FIGURE 1 Mean Body Weights of Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations in Swiss (CD-1®) Mice (TSAC = terminal sacrifice)

TABLE 3 Right Epididymal Weights of Male Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations^a^

Dose^b^ | Mean Body Weight | Right Epididymis
Dose^b^ | Mean Body Weight | Absolute | % Difference | Relative
0 + 0 | 37.12 | 0.03906 ± 0.00518 | | 1.1 ± 0.1
100 + 0 | 36.97 | 0.04122 ± 0.00266 | (+5.5) | 1.1 ± 0.1
200 + 0 | 37.88 | 0.04446 ± 0.00413 | (+13.8)^*^ | 1.2 ± 0.1^*^
400 + 0 | 36.59 | 0.04659 ± 0.00683 | (+19.3)^*^ | 1.3 ± 0.2^*^
0 + 50 | 37.52 | 0.04222 ± 0.00278 | (+8.1) | 1.1 ± 0.1
100 + 50 | 37.58 | 0.04362 ± 0.00206 | (+11.7)^*^,^c^ | 1.2 ± 0.0^*^,^c^
200 + 50 | 37.25 | 0.04413 ± 0.00528 | (+13.0)^*^ | 1.2 ± 0.1^*^
400 + 50 | 36.69 | 0.04338 ± 0.00404 | (+11.1)^*^ | 1.2 ± 0.1^*^
0 + 100 | 37.66 | 0.04335 ± 0.00280 | (+11.0)^*^ | 1.2 ± 0.1
100 + 100 | 37.11 | 0.04574 ± 0.00439 | (+17.1)^*^ | 1.2 ± 0.1^*^
200 + 100 | 39.11^*^ | 0.04370 ± 0.00543 | (+11.9)^*^ | 1.1 ± 0.1
400 + 100 | 37.97 | 0.04592 ± 0.00368 | (+17.6)^*^ | 1.2 ± 0.1^*^
0 + 150 | 38.96 | 0.04229 ± 0.00475 | (+8.3)^*^ | 1.1 ± 0.1
100 + 150 | 38.77 | 0.04652 ± 0.00365 | (+19.1)^*^ | 1.2 ± 0.1^*^
200 + 150 | 37.70 | 0.04465 ± 0.00278 | (+14.3)^*^ | 1.2 ± 0.1^*^
400 + 150 | 39.00 | 0.04478 ± 0.00600 | (+14.6)^*^ | 1.2 ± 0.1^*^

* Significantly different from the vehicle control group (P≤0.05) by two-tailed Student’s t-test

a Organ weights (absolute weights) and body weights are given in grams; organ-to-body-weight ratios (relative weights) are given as mg organ weight/g body weight (mean ± standard error).

b Daily gavage doses of AZT + isoniazid (mg/kg per day)

c n=9

### Female-A Mice

A decrease in mean body weights was apparent on approximately day 23 of the study in all groups of female-A mice receiving 100, 200, or 400 mg/kg AZT alone or in combination with 50, 100, or 150 mg/kg isoniazid (Figure 2). By day 26, these mean body weight decreases were significant (P≤0.05) in groups receiving 200 or 400 mg/kg AZT (alone or with isoniazid) compared to the vehicle control group or groups administered isoniazid alone. These decreases reflected reduced gravid uterine weights (P≤0.05), especially in the female-A mice receiving 200 or 400 mg/kg AZT. Mean gravid uterine weights of female-A mice receiving isoniazid alone were similar to those of the vehicle control group. For all groups of female-A mice administered AZT alone or with isoniazid, final mean body weights were corrected by subtracting the gravid uterine weights. The corrected final mean body weights of dosed and vehicle control females were similar. Thus, the principal AZT effect in female-A mice was upon gravid uterine weights.

Administration of isoniazid at doses up to 150 mg/kg did not produce statistically significant differences in mean body weights, mean body weight gains, terminal body weights, or gravid uterine weights.

### Female-B Mice

On gestation day 15, the mean body weight of the 400 + 150 mg/kg group was significantly reduced (P≤0.05) compared to groups administered isoniazid alone (Figure 3). The 400 + 100 mg/kg group also had a reduced mean body weight compared to the vehicle control group, 0 + 100 mg/kg group, and groups administered 100, 200, or 400 mg/kg AZT + 100 mg/kg isoniazid, but the difference was not statistically significant. Otherwise, mean body weights of female-B mice administered AZT alone, AZT with isoniazid, or isoniazid alone were similar to that of the vehicle control group.

During the lactation period, maternal mean body weights and body weight gains were generally reduced for the 400 mg/kg AZT + 100 or 150 mg/kg isoniazid dams with surviving litters compared to the vehicle control group and the groups administered isoniazid alone.

FIGURE 2 Mean Body Weights of Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations in Swiss (CD-1®) Mice

(Plots A and C show terminal body weights [TBW] from day 0 through terminal sacrifice [TSAC]. Plots B and D show corrected body weights [CBW; without gravid uterus] at TSAC. TBW and CBW include only values for dams that were actually pregnant and that were sacrificed and caesarean-sectioned on presumed day 19 of gestation.)

(Plots E and G show terminal body weights [TBW] from day 0 through terminal sacrifice [TSAC]. Plots F and H show corrected body weights [CBW; without gravid uterus] at TSAC. TBW and CBW include only values for dams that were actually pregnant and that were sacrificed and caesarean-sectioned on presumed day 19 of presumed gestation.)

FIGURE 3 Mean Body Weights of Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations in Swiss (CD-1®) Mice (GD = gestation day; LD = lactation day. Note: Mean body weights include only values for those dams that were actually pregnant, that survived to LD 4, and that delivered pups that survived to LD 4.)

## Clinical Pathology

### Hematology

#### Male Mice

Administration of AZT alone to male mice produced significant decreases in erythrocyte (RBC) counts (P≤0.01) and hemoglobin (Hgb) concentrations (P≤0.05), slight decreases in hematocrit (Hct) values, and slight increases in platelet counts (Figures 4 through 7 and Table A1). Respective RBC counts for the 100, 200, and 400 mg/kg AZT groups were approximately 15%, 14%, and 18% less than the RBC count of the vehicle control group.

Isoniazid administered alone did not result in biologically significant alterations in any of the parameters evaluated. The statistically significant increase in the reticulocyte count (P≤0.01) of males administered 150 mg/kg isoniazid alone was not considered biologically significant because there was no evidence of anemia in this group (Table A1).

The reduction in RBC counts observed in males administered AZT alone was more pronounced in males administered AZT in combination with 150 mg/kg isoniazid. The administration of 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid resulted in RBC counts that were 21%, 25%, or 36% less (P≤0.01) than that of the vehicle control group, respectively. In general, Hgb concentrations and Hct values paralleled the decreases in RBC counts and were accompanied by marginal elevations in mean cell volume (MCV) and mean cell hemoglobin (MCH) values for combined doses of AZT and isoniazid. Variations in cell size and shape consistent with anemia were evident. Respective platelet counts (Figure 7 and Table A1) of the 100, 200, and 400 mg/kg AZT + 150 mg/kg isoniazid groups were 19%, 29%, and 56% greater (P≤0.01) than the platelet count of the vehicle control group. Sporadic elevations in reticulocyte counts were observed; however, the inconsistency of this finding precluded any interpretations. No biologically significant alterations were detected in any of the other hematologic parameters evaluated in male mice in this study (Table A1).

#### Female-A Mice

Female-A mice administered AZT alone developed marginally reduced RBC counts (Figure 4 and Table A2) accompanied by minor decreases in Hgb concentrations and Hct values and slightly elevated (P≤0.01) MCV and MCH values. A 24% reduction occurred in the leukocyte (WBC) count of the 400 + 0 mg/kg group compared to that of the vehicle control group (Figure 8 and Table A2). Administration of isoniazid alone did not result in any biologically significant alterations (Table A2).

FIGURE 4 Mean Erythrocyte Values of Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations (For statistically significant differences, see Tables A1 and A2.)

FIGURE 5 Mean Hemoglobin Values of Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations (For statistically significant differences, see Tables A1 and A2.)

FIGURE 6 Mean Hematocrit Values of Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations (For statistically significant differences, see Tables A1 and A2.)

FIGURE 7 Mean Platelet Values of Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations (For statistically significant differences, see Tables A1 and A2.)

FIGURE 8 Mean Leukocyte Values of Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations (For statistically significant differences, see Tables A1 and A2.)

In female-A mice administered AZT in combination with 150 mg/kg isoniazid, the effect on RBC counts was magnified. Respective RBC counts of the 100, 200, and 400 mg/kg AZT + 150 mg/kg isoniazid groups were approximately 20%, 34%, and 42% less (P≤0.01) than the RBC count of the vehicle controls. Hgb concentrations and Hct values were significantly reduced (P≤0.01) in the 200 and 400 mg/kg AZT + 150 mg/kg isoniazid groups (Table A2).

The mild leukopenia observed in female-A mice administered AZT alone was increased in groups administered AZT in combination with isoniazid; 400 + 150 mg/kg resulted in a 32% reduction (P≤0.01) in the WBC count compared to that of the vehicle control group (Figure 8 and Table A2). Evaluation of the corresponding WBC differentials revealed that the leukopenia was predominantly myelocytic in origin.

A prominent dose-related thrombocytosis was evident in the female-A mice administered both AZT and isoniazid. Respective platelet counts (Figure 7 and Table A2) of the 100, 200, and 400 mg/kg AZT + 150 mg/kg isoniazid groups were approximately 27% (P≤0.05), 49% (P≤0.01), and 72% (P≤0.01) greater than the mean platelet count of the vehicle control group. No biologically significant alterations were detected in any of the other parameters evaluated (Table A2).

#### Female-B Mice

Biologically significant alterations were not detected in any of the hematologic parameters evaluated in female-B mice treated with AZT alone, isoniazid alone, or combinations of AZT and isoniazid (Table A3).

### Clinical Chemistry

Biologically significant alterations were not detected in any of the clinical chemistry parameters evaluated in male, female-A, or female-B mice treated with AZT alone, isoniazid alone, or combinations of AZT and isoniazid. AZT and isoniazid each appeared to cause a slight decrease in alanine aminotransferase in female-A mice. These changes were minimal, however, with most values within normal physiological ranges.

## Necropsy Observations

Splenic enlargement occurred in various treatment groups of males and females. This finding was observed in no more than one animal in any of the dosed groups with the exception of the female-A group administered 200 + 150 mg/kg; three incidences occurred in this group. Because splenic enlargement did not occur in the vehicle control group, it may be associated with the administration of either AZT or isoniazid. Other gross findings were considered incidental in nature, and none were examined microscopically.

## Sperm Function Evaluations

AZT alone at 100 and 200 mg/kg and isoniazid alone at 50, 100, and 150 mg/kg did not affect epididymal sperm motility (Table 4). A significant (P≤0.05) decrease in epididymal sperm motility was caused by 400 mg/kg AZT + 100 mg/kg isoniazid. Slight decreases in sperm motility were caused by 400 mg/kg AZT alone and in combination with 50 or 150 mg/kg isoniazid, but these decreases were not significant (P > 0.05).

Other parameters, including left caudal, epididymal, and testicular weights; epididymal sperm counts; spermatid heads per testis; and total spermatid heads per gram testis, were not affected by AZT alone, isoniazid alone, or the combinations of AZT and isoniazid tested in this study.

TABLE 4 Epididymal Sperm Motility in Male Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations^a^

Dose^b^ | Motility (%)
0 + 0 | 73.76 ± 5.26
100 + 0 | 72.88 ± 2.24
200 + 0 | 72.81 ± 6.78
400 + 0 | 58.36 ± 6.04
0 +50 | 80.34 ± 2.14
100 + 50 | 75.41 ± 4.27
200 + 50 | 67.93 ± 4.07
400 + 50 | 62.53 ± 8.00
0 + 100 | 78.71 ± 2.03
100 + 100 | 79.64 ± 2.23^c^
200 + 100 | 70.87 ± 4.78
400 + 100 | 45.09 ± 8.21^*^
0 + 150 | 80.55 ± 1.54
100 + 150 | 69.46 ± 4.25
200 + 150 | 71.52 ± 4.08
400 + 150 | 53.59 ± 8.77

* Significantly different (P≤0.05) from the vehicle control group by the Wilcoxon rank sum test

a Data are given as mean ± standard error; 10 animals per group were examined unless otherwise noted.

b Daily gavage doses of AZT + isoniazid (mg/kg per day)

c n=9

## Natural Delivery Data

Treatment with AZT and/or isoniazid had no significant effects on the pregnancy of female-B mice (Table 5). All of the pregnant mice delivered litters except one mouse in the 100 + 50 mg/kg group, two mice in the 400 + 100 mg/kg group, and four mice in the 400 + 150 mg/kg group.

TABLE 5 Occurrence of Pregnancy in Female-B Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | Number per Group | Number Pregnant (%) | Number Delivered (%)
0 + 0 | 14 | 14 (100%) | 14 (100%)
100 + 0 | 13 | 12 (92.3%) | 12 (100%)
200 + 0 | 14 | 11 (78.6%) | 11 (100%)
400 + 0 | 14 | 12 (85.7%) | 12 (100%)
0 + 50 | 13 | 13 (100%) | 13 (100%)
100 + 50 | 14 | 14 (100%) | 13 (92.8%)
200 + 50 | 14 | 13 (92.8%) | 13 (100%)
400 + 50 | 14 | 14 (100%) | 14 (100%)
0 + 100 | 14 | 14 (100%) | 14 (100%)
100 + 100 | 14 | 13 (92.8%) | 13 (100%)
200 + 100 | 14 | 13 (92.8%) | 13 (100%)
400 + 100 | 14 | 13 (92.8%) | 11 (84.6%)
0 + 150 | 13 | 12 (92.3%) | 12 (100%)
100 + 150 | 13 | 11 (84.6%) | 11 (100%)
200 + 150 | 14 | 11 (78.6%) | 11 (100%)
400 + 150 | 13 | 13 (100%) | 9 (69.2%)

a Daily gavage doses of AZT + isoniazid (mg/kg per day)

Among the dosed groups, the mean live litter size was similar to that of the vehicle control group except for significant reductions (P≤0.05) in the groups receiving 200 or 400 mg/kg AZT + 150 mg/kg isoniazid (Table 6). Administration of AZT alone, isoniazid alone, or AZT in combination with isoniazid produced no effect on any parameters evaluated except in the 400 + 150 mg/kg group for the following parameters: duration of gestation, mean live litter size, and cumulative litter survival. Mean live litter size was also decreased (P≤0.05) in the 200 + 150 mg/kg group.

TABLE 6 Summary of Natural Delivery Litter Data for Female-B Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | Duration of Gestation | Dams with Stillborn Pups (% of Dams that Delivered) | Dams with All Pups Dying on Days 0–4 (% of Dams with Liveborn Pups) | Mean Live Litter Size | Pups Dying on Days 1–4/Total Alive on Day 1 (%) | Survival/Live Litter Size^b^ on Day 4 Postpartum
0 + 0 | 20.1 | 0 (0.0%) | 0 (0.0%) | 12.4 | 12/174 (6.9%) | 11.6/11.6
100 + 0 | 20.2 | 1 (8.3%) | 0 (0.0%) | 12.5 | 1/138 (0.7%) | 12.4/12.4
200 + 0 | 20.0 | 1 (9.1%) | 0 (0.0%) | 11.6 | 0/128 (0.0%) | 11.36/11.6
400 + 0 | 20.0 | 1 (8.3%) | 0 (0.0%) | 12.7 | 2/152 (1.3%) | 12.5/12.5
0 + 50 | 20.0 | 0 (0.0%) | 0 (0.0%) | 13.1 | 0/170 (0.0%) | 13.0/13.0
100 + 50 | 20.2 | 0 (0.0%) | 0 (0.0%) | 12.1 | 1/157 (0.6%) | 12.0/12.0
200 +50 | 20.0 | 0 (0.0%) | 0 (0.0%) | 11.8 | 13/154 (8.4%) | 10.6/11.5
400 +50 | 20.4 | 0 (0.0%) | 0 (0.0%) | 11.5 | 6/149 (4.0%) | 9.8/10.7
0 + 100 | 19.9 | 0 (0.0%) | 0 (0.0%) | 12.3 | 4/172 (2.3%) | 12.0/12.0
100 + 100 | 19.9 | 0 (0.0%) | 0 (0.0%) | 12.2 | 0/158 (0.0%) | 12.2/12.2
200 + 100 | 20.3 | 0 (0.0%) | 0 (0.0%) | 10.7 | 3/128 (2.4%) | 10.3/10.3
400 + 100 | 20.5 | 1 (9.1 %) | 0 (0.0%) | 10.1 | 3/91 (3.4%) | 9.6/9.6
0 + 150 | 20.1 | 0 (0.0%) | 0 (0.0%) | 12.4 | 1/136 (0.7%) | 12.3/12.3
100 + 150 | 20.0 | 0 (0.0%) | 0 (0.0%) | 11.3 | 2/124 (1.6%) | 11.0/11.0
200 + 150 | 20.5 | 0 (0.0%) | 1 (9.1%) | 8.1^*^ | 0/89 (0.0%) | 8.0/8.8
400 + 150 | 20.9^*^ | 0 (0.0%) | 2 (22.2%) | 5.2^**^ | 6/47 (13.0%) | 4.4^*^/5.7

* Significantly different (P≤0.05) from the vehicle control group by the Cochran-Armitage and Fisher exact tests

** P≤0.01

a Daily gavage doses of AZT + isoniazid (mg/kg per day)

b Excludes values for litters that had no surviving pups

## Caesarean Section Data

The administration of 200 or 400 mg/kg AZT alone or 150 mg/kg isoniazid alone, as well as several combination doses, resulted in reductions (P≤0.05) in pregnancy among female-A mice (Table 7). In addition, the groups that received 200 + 50 mg/kg, 200 + 100 mg/kg, or 400 + 100 mg/kg had significant (P≤0.05) decreases in the numbers of corpora lutea and implantations (Table 7).

TABLE 7 Occurrence of Pregnancy in Female-A Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | Number Pregnant (%)^b^ | Mean Corpora Lutea | Mean Implantations
0 + 0 | 17 (85.0%) | 14.0 | 13.3
100 + 0 | 12 (60.0%) | 13.2 | 11.9
200 + 0 | 9 (45.0%)^*^ | 11.6 | 10.7
400 + 0 | 8 (40.0%)^**^ | 9.9 | 9.2
0 +50 | 18 (90.0%) | 14.8 | 13.7
100 + 50 | 11 (55.0%) | 15.0 | 13.9
200 + 50 | 13 (65.0%) | 8.3^**^ | 7.6^*^
400 + 50 | 6 (30.0%)^**^ | 10.8 | 10.5
0 + 100 | 13 (65.0%) | 12.8 | 11.8
100 + 100 | 16 (80.0%) | 11.2 | 10.2
200 + 100 | 8 (40.0%)^**^ | 10.1^*^ | 9.0^*^
400 + 100 | 8 (40.0%)^**^ | 11.1^*^ | 8.9^*^
0 + 150 | 10 (50.0%)^*^ | 13.0 | 12.2
100 + 150 | 11 (55.0%) | 13.7 | 12.5
200 + 150 | 11 (55.0%) | 12.7 | 9.9
400 + 150 | 6 (30.0%)^**^ | 11.5 | 9.7

* Significantly different (P≤0.05) from the vehicle control group by the Cochran-Armitage and Fisher exact tests

** P≤0.01

a Daily gavage doses of AZT + isoniazid (mg/kg per day)

b Twenty mice were assigned to each group.

The administration of 400 mg/kg AZT alone as well as several combinations of AZT and isoniazid (including 200 or 400 mg/kg AZT + any dose of isoniazid) resulted in decreased litter sizes (P≤0.05), decreased live fetuses per litter (P≤0.05), and an increase (P≤0.05) in resorptions (Table 8). Most of the resorptions were early; late resorptions were significantly increased (P≤0.05) in the 200 + 150 mg/kg and 400 + 150 mg/kg groups only.

TABLE 8 Summary of Caesarean-Section Litter Data for Female-A Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | Litter Sizes Mean ± SD^b^ | Live Fetuses | | Dead Fetuses | | Resorptions
Dose^a^ | Litter Sizes Mean ± SD^b^ | No. | Mean ± SD | No. | Mean ± SD | No. | Mean ± SD
0 + 0 | 12.6 ± 2.2 | 212 | 12.5 ± 2.1 | 2 | 0.1 ± 0.3 | 12 | 0.7 ± 1.0
100 + 0 | 9.3 ± 3.9 | 112 | 9.3 ± 3.9 | 0 | 0.0 ± 0.0 | 31 | 2.1 ± 2.2
200 + 0 | 8.6 ± 4.6 | 77 | 8.6 ± 4.6 | 0 | 0.0 ± 0.0 | 19 | 2.1 ± 1.8
400 + 0 | 1.4 ± 1.5^**^ | 11 | 1.4 ± 1.5^**^ | 0 | 0.0 ± 0.0 | 63 | 7.9 ± 3.6^**^
0 + 50 | 12.6 ± 1.8 | 212 | 12.5 ± 1.7 | 3 | 0.2 ± 0.4 | 18 | 1.0 ± 1.0
100 +50 | 10.4 ± 4.6 | 113 | 10.3 ± 4.8 | 1 | 0.1 ± 0.3 | 39 | 3.5 ± 3.8
200 + 50 | 4.2 ± 3.6^**^ | 53 | 4.1 ± 3.3^**^ | 2 | 0.2 ± 0.4 | 44 | 3.4 ± 3.1^*^
400 + 50 | 6.8 ± 2.8^*^ | 40 | 6.7 ± 2.9^*^ | 1 | 0.2 ± 0.4 | 22 | 3.7 ± 1.2^**^
0 + 100 | 10.2 ± 3.5 | 133 | 10.2 ± 3.5 | 0 | 0.0 ± 0.0 | 21 | 1.6 ± 1.4
100 + 100 | 7.4 ± 4.8^*^ | 118 | 7.4 ± 4.8^*^ | 0 | 0.0 ± 0.0 | 45 | 2.8 ± 3.4
200 + 100 | 4.1 ± 3.5^**^ | 32 | 4.0 ± 3.4^**^ | 1 | 0.1 ± 0.4 | 39 | 4.9 ± 2.7^**^
400 + 100 | 1.4 ± 2.2^**^ | 8 | 1.0 ± 2.1^**^ | 3 | 0.4 ± 1.1 | 60 | 7.5 ± 3.1^**^
0 + 150 | 10.8 ± 2.1 | 108 | 10.8 ± 2.1 | 0 | 0.0 ± 0.0 | 14 | 1.4 ± 1.7
100 + 150 | 8.9 ± 3.2 | 96 | 8.7 ± 3.3 | 2 | 0.2 ± 0.6 | 40 | 3.6 ± 3.8^*^
200 + 150 | 2.0 ± 3.3^**^ | 20 | 2.0 ± 3.3^**^ | 0 | 0.0 ± 0.0 | 79 | 7.9 ± 5.0^**^
400 + 150 | 1.5 ± 2.3^**^ | 9 | 1.5 ± 23.3^**^ | 0 | 0.0 ± 0.0 | 49 | 8.2 ± 4.7^**^

* Significantly different (P≤0.05) from the vehicle control group by the Cochran-Armitage and Fisher exact tests

** P≤0.01

a Excludes dams that delivered or began to deliver litters before scheduled sacrifice; also excludes dams that were sacrificed prior to presumed day 18 of gestation and, due to gestational age of fetuses, gender and viability could not be determined; and excludes dams that were found dead.

b Daily gavage doses of AZT + isoniazid (mg/kg per day); SD = standard deviation

Significant reductions (P≤0.05) in the mean fetal weight per litter were noted for all doses of AZT alone, as well as the 200 + 50 mg/kg, 400 + 50 mg/kg, and 100 + 150 mg/kg groups (Table 9). Reductions in fetal weight were also noted in most other combination dose groups, although these were not statistically significant, probably due to limited numbers of live fetuses.

TABLE 9 Body Weights of Fetuses from Female-A Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | Mean Fetal Weight^b^ per Litter (g)
0+0 | 1.34
100 + 0 | 1.16^**^
200 + 0 | 1.07^**^
400 + 0 | 1.03^**^
0 +50 | 1.36
100 +50 | 1.22
200 +50 | 1.09^**^
400 +50 | 1.03^*^
0 + 100 | 1.33
100 + 100 | 1.18
200 + 100 | 1.16
400 + 100 | 0.94
0 + 150 | 1.40
100 + 150 | 1.07^**^
200 + 150 | 0.98
400 + 150 | 0.90

* Significantly different (P≤0.05) from the vehicle control group by Dunnett’s or Dunn’s test

** P≤0.01

a Daily gavage doses of AZT + isoniazid (mg/kg per day)

b See Table 8 for litter size.

## Gross External Alterations (Female-B Litters)

Compared to the control group which had no fetal gross abnormalities, treatment with AZT alone, isoniazid alone, and combinations of AZT and isoniazid caused some increases (not statistically significant) in the number of litters and fetuses with gross external alterations in some groups (Table 10). Although the percentage of fetuses per litter with any type of gross external alteration was increased (P≤0.01) in the group treated with 400 + 150 mg/kg, there were no individual gross alterations that were statistically significant. The alterations were observed in one to three fetuses in the affected groups and included exencephaly, meningocele, open eyes, gastroschisis, hyperflexed limbs, and curled or coiled tails; none of these specific alterations were increased significantly.

TABLE 10 Summary of Fetal Gross Alterations in Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations^a^

| 0 + 0 | 100 + 0 | 0 + 50 | 0 + 100 | 200 + 100 | 0 + 150 | 400 + 150
Litters examined/fetuses examined | 17/212 | 12/112 | 17/212 | 13/133 | 6/32 | 10/108 | 2/9
Malformation^b^
Exencephaly | —^c^ | — | — | 1 (7.7)/1 (0.8) | — | 1 (10.0)/1 (0.9) | 1 (50.0)/1 (11.1)
Meningocele | — | — | — | — | 1 (16.7)/1 (3.1) | — | —
Open eyes | — | — | — | — | — | — | 1 (50.0)/1 (11.1)
Gastroschisis | — | — | — | — | — | — | 1 (50.0)/1 (11.1)
Hyperflexed limbs | — | 1 (8.3)/1 (0.9) | 1 (5.9)/1 (0.5) | 1 (7.7)/1 (0.8) | — | 2 (20.0)/2 (1.8) | —
Curled/coiled tail | — | 1 (8.3)/1 (0.9) | — | — | — | — | 1 (50.0)/1 (11.1)
% Fetuses with any alteration per litter^d^ | — | 1.98 ± 5.06 | 0.39 ± 1.62 | 3.42 ± 9.49 | 2.38 ± 5.84 | 2.97 ± 5.11 | 20.00 ± 28.28^**^

** Significantly different (P≤0.01) from the vehicle control group by the Cochran-Armitage and Fisher exact tests

a Fetal gross alterations occurred only in the treatment groups listed; all other treatment groups had no fetal gross alterations. Doses are expressed as AZT + isoniazid (mg/kg per day).

b Data presented as the number (percentage of litters with the alteration over the number (percentage) of fetuses with the alteration

c Not observed in this treatment group

d Mean ± standard deviation

## Discussion

Administration of AZT alone resulted in mild hematologic toxicity in male mice. Administration of isoniazid alone did not produce toxicity in male mice. Treatment with combinations of AZT and isoniazid appeared to enhance the anemia produced by AZT. AZT alone caused slight decreases in epididymal sperm motility at all three doses tested (100, 200, and 400 mg/kg). Isoniazid alone or in combination with AZT did not have a significant affect on epididymal sperm motility.

In female-A mice, AZT alone caused anemia and leukopenia, but isoniazid alone did not cause hematologic toxicity. Treatment with combinations of AZT and isoniazid enhanced the anemia caused by AZT. In female-B mice, AZT alone or in combination with isoniazid did not cause hematologic toxicity because the duration of treatment was only 10 days whereas female-A mice were treated for 30 days. In pregnant female mice, AZT caused decreased body weights and body weight gains. These differences were probably related to reduced litter sizes, increased resorptions, and reduced pup weights that occurred in groups administered AZT, because the body weights corrected for gravid uterine weights were not reduced in these groups. Isoniazid alone at doses up to 150 mg/kg did not cause maternal toxicity. AZT and isoniazid each appeared to be more toxic to the developing fetus and pup than to adult mice. Doses of 100, 200, or 400 mg/kg AZT alone and 50, 100, or 150 mg/kg isoniazid alone produced developmental toxicity with increases in the incidences of resorptions and the percentage of dead or resorbed fetuses per litter. Administered in combination, AZT and isoniazid increased both maternal and developmental toxicity.