# Materials and Methods

## Procurement and Characterization of Chemicals

3′-Azido-3′-deoxythymidine (AZT; lot 1401-R-7) was manufactured by Raylo Chemicals (Edmonton, Alberta) and supplied as a fine, off-white powder. Isoniazid (lot 7232-74-02) was manufactured by Fluka Chemical Corporation (Ronkonkoma, NY) and supplied as a white crystalline substance. Identification of both compounds was confirmed by nuclear magnetic resonance and infrared spectroscopy. The purity of both AZT and isoniazid was determined to be approximately 99% by high-performance liquid chromatography.

## Dose Formulations

The required amounts of AZT and isoniazid were combined with the required amount of the vehicle, 0.5% methylcellulose in deionized water. Each dose formulation was stirred until a solution or homogeneous suspension was observed.

Stability studies conducted on 0.5% methylcellulose solutions containing 5.0 mg/mL AZT and 1.5 mg/mL isoniazid indicated no significant loss of either test chemical after storage for 30 days at ambient temperature (23° to 28° C) or refrigerated (2° to 5° C) or for 3 hours at room temperature, open to air and light. Dose formulations of AZT and isoniazid used in this study were stored refrigerated in the dark for up to 20 days.

Samples of formulations from each dose concentration from the first mix indicated all formulations analyzed prior to dosing were within the acceptable range (within 10% of theoretical values) except for one isoniazid dose formulation, which was 87% of the target dose. Animal room samples contained 94% to 105% of the target AZT concentrations and 97% to 118% of the target isoniazid concentrations (3 of 15 samples were outside the acceptable range). The animal room samples that were out of specification were not regarded as having an adverse effect on the results of the study.

## Study Design

Male and female Swiss (CD-1^®^) mice were obtained from Charles River Laboratories (Raleigh, NC) and were about 13 weeks of age when the study began. At terminal sacrifice, blood samples were collected from five male and five female sentinel animals as part of the animal disease screening program. Results indicated all animals were free of viral antibodies.

The mice were housed five males or five females per cage during quarantine before randomization and were individually housed after randomization, except during cohabitation. Solid-bottom polycarbonate cages were used to house the animals. Two animal rooms were used in this study; the average temperature and relative humidity in one room were 22.0° C and 51% and in the other were 22.4° C and 47%.

The design of this study is a modification of a design published elsewhere (Harris et al., 1992). A brief summary of the study design is provided in Table 2. The oral route of administration was selected because it is the route used in humans. The Swiss (CD-1^®^) mouse was chosen for this study because it is one of the mouse models routinely used for reproductive and developmental toxicity studies by the NIEHS. AZT was administered at concentrations of 100, 200, or 400 mg/kg and isoniazid at concentrations of 50, 100, or 150 mg/kg by gavage in 0.5% methylcellulose. Each drug was given alone and in combination with each concentration of the other drug. Total daily dose volumes of 20 mL/kg were divided into two equal dose volumes of 10 mL/kg that were administered to the animals approximately 6 hours apart. Mice were divided into three groups as follows:

Male Mice: Ten males were assigned to each dose group. Prior to dosing, male mice were cohabited with female-B mice on study days 0 to 4. Males were dosed from study day 5 to the day prior to sacrifice. Males were cohabited with female-A mice on study days 9 to 13 to identify any effects of treatment on mating behavior. On study day 25 or 26, all male mice were weighed, and blood samples were obtained from the retroorbital sinus for hematology and clinical chemistry evaluations. The males were euthanized with CO_2_, necropsy was conducted, and the testes and epididymides were collected and prepared for evaluation of sperm parameters as described in the Sperm Function Evaluation section.

Female-A Mice: Twenty females were assigned to each dose group. Female-A mice were dosed from study day 0 to the day prior to sacrifice. Males were cohabited with female-A mice on study days 9 to 13 to identify any effects of treatment on mating behavior, fertilization, implantation, or the initial stages of development. During the cohabitation period, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually, and that day was designated as day 0 of gestation. At the end of the cohabitation period, all animals were housed individually. Prior to parturition on day 18 of presumed gestation (study days 28 to 32), all female-A mice were weighed, and blood samples were taken from the retroorbital sinus for hematology and clinical chemistry evaluations. The female-A mice were then euthanized with CO_2_, and necropsy and caesarean section evaluations were conducted. Live fetuses were removed, weighed, anesthetized on ice, and preserved in Bouin’s fixative. The uteri of all sperm-negative females were examined for evidence of unsuccessful pregnancy and then press-plated between two heavy plates of glass to visualize implantation sites. Additional endpoints for all female-A mice included gravid uterine weight and number of implantation sites, resorptions, corpora lutea, and dead and live fetuses.

Female-B Mice: Twenty females were assigned to each dose group. Prior to dosing, female-B mice were cohabited with males on study days 0 to 4. During the cohabitation period, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually, and that day was designated as day 0 of gestation. At the end of the cohabitation period, sperm-negative female-B mice were euthanized with CO_2_ and discarded without necropsy; all other animals were housed individually. Sperm-positive female-B mice were assigned evenly across dose groups prior to gestation day 6. Female-B mice were subsequently dosed during gestation days 6 to 15, during the fetal organogenesis period, to identify effects on fetal development. Residual effects on parturition and the beginning of lactation were also evaluated. After gestation day 16, the bedding material and feeders were no longer changed. From gestation day 17 until the litters were delivered, female-B mice were observed twice daily for evidence of labor or delivery. The day of completed delivery was determined to the nearest day and designated as postnatal day 0. On postnatal days 0 and 1, dam body weights were recorded along with the number of live and dead pups, the number of male and female pups, the incidence of any gross malformations, and live pup weights. Dead pups were discarded. On postnatal day 4, all female-B mice, including any that did not deliver, were weighed, and blood samples were collected from the retroorbital sinus for hematology and clinical chemistry evaluations. These mice were then euthanized with CO_2_, and complete necropsies were performed. The uterus was removed and press-plated. All pups were weighed and given a thorough external examination for lesions and malformations, and the gender was recorded. The pups were then euthanized with CO_2_ and preserved in Bouin’s fixative.

### Clinical Pathology

All blood samples were collected from the retroorbital sinus under carbon dioxide:oxygen anesthesia. Blood for hematology analyses was collected into a tube containing EDTA, and blood for clinical chemistry analyses was collected in a tube without anticoagulant. Animals were selected in random order for blood collection, and samples were analyzed in the order collected.

Erythrocyte and platelet counts, hematocrit, hemoglobin concentration, mean cell hemoglobin, mean cell volume, mean cell hemoglobin concentration, leukocyte count and differentials, and erythrocyte and platelet morphologies were determined on whole blood using a Technicon H·1™ automated hematology analyzer (Technicon Corporation, Tarrytown, NY). Reticulocytes were counted by a Coulter Model Elite® Flow Cytometer (Coulter Electronics, Inc., Hialeah, FL). Blood smears were prepared to manually verify leukocyte differentials and erythrocyte and platelet morphologies, if necessary.

Alanine aminotransferase, alkaline phosphatase, aspartate aminotransferase, and sorbitol dehydrogenase activities and bile acid concentrations were determined using the Roche Cobas Fara® automated analyzer (Roche Diagnostic Systems, Inc., Montclair, NJ). Priority for clinical chemistry tests was assigned in the order listed above.

### Sperm Function Evaluations

Sperm motility was evaluated at necropsy in the following manner. The left epididymis was isolated and weighed. The tail of the epididymis (cauda epididymis) was then removed from the epididymal body (corpus epididymis) and weighed. Modified Tyrode’s buffer was applied to slides, and a small incision was made at the distal border of the cauda epididymis. The sperm effluxing from the incision were dispersed in the buffer on the slides, and the numbers of motile and nonmotile spermatozoa were counted for five fields per slide by two observers.

Following completion of sperm motility estimates, each left cauda epididymis was placed in a buffered neutral saline solution. Caudae were finely minced, and the tissue was incubated in the saline solution and then heat fixed at 65° C. Sperm density was then determined microscopically with the aid of a hemocytometer. To quantify spermatogenesis, testicular spermatid head count was determined by removing the tunica albuginea and homogenizing the left testis in phosphate-buffered saline containing 10% dimethyl sulfoxide. Homogenization-resistant spermatid nuclei were counted with a hemocytometer.

### Histopathology

A necropsy was performed on all animals except sperm-negative female-B mice. If gross lesions were present, the tissue was fixed in formalin, trimmed to a maximum thickness of 0.3 cm for processing, embedded in paraffin, sectioned to a thickness of 4 to 6 μm, stained with hematoxylin and eosin, and examined by light microscopy.

TABLE 2 Experimental Design and Materials and Methods in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid in Swiss (CD-1^®^) Mice

Study Laboratory; Southern Research Institute, Birmingham, AL
Strain and Species; Swiss (CD-1^®^) mice
Animal Source; Charles River Laboratories, Raleigh, NC (Area R03)
Time Held Before Studies; 17 to 18 days
Average Age When Studies Began; 88 to 89 days
Date of First Dose; Male mice: 17 or 24 March 1993; Female-A mice: 12 or 19 March 1993; Female-B mice: 18–22 or 25–29 March 1993
Duration of Dosing; Male mice: day 5 to day prior to sacrifice (day 24 or 25); Female-A mice: day 0 to day prior to sacrifice (days 27 to 31); Female-B mice: gestation days 6 through 15
Days of Cohabitation; Male and female-A mice: days 9 to 13; Male and female-B mice: days 0 to 4; When possible, one male and two female mice within the same dose group were housed together by consecutive animal number.
Date of Last Dose; Male mice: 5–6 or 12–13 April 1993; Female-A mice: 8–12 or 15–19 April 1993; Female-B mice: 27–31 March or 3–7 April 1993
Necropsy Dates; Male mice: day 25 or 26; Female-A mice: days 28 to 32; Female-B mice: postnatal day 4 (sperm-positive)
Average Age at Necropsy; Male mice: 113 to 115 days; Female-A mice: 116 to 121 days; Female-B mice: 112 to 117 days
Size of Study Groups; Male mice: 10; Female-A mice: 20; Female-B mice: 20
Method of Animal Distribution; Animals were distributed randomly into groups of approximately equal initial mean body weights.
Animals per Cage; One animal per cage, except during cohabitation
Method of Animal Identification; Tail tattoo
Diet; NIH-07 Open Formula pelleted diet (Zeigler Brothers Inc., Gardners, PA), available ad libitum, changed weekly or as necessary
Water; Tap water (Birmingham, AL), available ad libitum
Cages; Polycarbonate cages with solid bottom and sides
Bedding; Heat-treated hardwood chips (Sani-Chips^®^; P.J. Murphy Forest Products Corporation, Montville, NJ)
Cage Filters; Reemay^®^ spun-bonded polyester (Andico, Birmingham, AL)
Racks; Stainless steel (Lab Products, Maywood, NJ)
Animal Room Environment; Temperature: 20.9°C to 23.6°C; Relative humidity: 37% to 66%; Fluorescent light: 12 hours fluorescent light/day; Room air: minimum of 10 changes/hour
Doses; Daily doses in 0.5% methylcellulose gavage:; 0 mg AZT + 0 mg isoniazid per kg body weight per day; 0 mg AZT + 50 mg isoniazid per kg body weight per day; 0 mg AZT + 100 mg isoniazid per kg body weight per day; 0 mg AZT + 150 mg isoniazid per kg body weight per day; 100 mg AZT + 0 mg isoniazid per kg body weight per day; 100 mg AZT + 50 mg isoniazid per kg body weight per day; 100 mg AZT + 100 mg isoniazid per kg body weight per day; 100 mg AZT + 150 mg isoniazid per kg body weight per day; 200 mg AZT + 0 mg isoniazid per kg body weight per day; 200 mg AZT + 50 mg isoniazid per kg body weight per day; 200 mg AZT + 100 mg isoniazid per kg body weight per day; 200 mg AZT + 150 mg isoniazid per kg body weight per day; 400 mg AZT + 0 mg isoniazid per kg body weight per day; 400 mg AZT + 50 mg isoniazid per kg body weight per day; 400 mg AZT + 100 mg isoniazid per kg body weight per day; 400 mg AZT + 150 mg isoniazid per kg body weight per day
Type and Frequency of Observation; Mortality/moribundity: twice daily; Clinical findings: once daily; Vaginal plugs: days 10 to 14 for female-A mice, days 1 to 5 for female-B mice; Body weights: days 3, 5, 9, 13, 17, 21, 23, and sacrifice for male mice; days 0, 4, 12, 16, 20, 23, 26, and sacrifice for female-A mice; gestation days 0, 8, 12, 15, and postnatal days 0, 1, and 4 for female-B mice; postnatal days O, 1, and 4 for pups
Method of Sacrifice; Carbon dioxide asphyxiation
Necropsy; Complete necropsies were performed on all breeder animals except sperm-negative female-B mice. The epididymis was weighed for all male mice.
Histopathology; Gross lesions of F_0_ mice were collected, fixed in 10% formalin, and microscopically examined. Pups were examined externally only.
Clinical Pathology; Hematology and clinical chemistry evaluations were conducted on all animals at terminal sacrifice.; Hematology: erythrocyte and platelet counts, hematocrit, hemoglobin concentration, mean cell hemoglobin, mean cell volume, mean cell hemoglobin concentration, leukocyte count and differentials, and erythrocyte and platelet morphologies; Clinical Chemistry: alanine aminotransferase, alkaline phosphatase, aspartate aminotransferase, and sorbitol dehydrogenase activities and bile acid concentrations
Sperm Function Evaluations; Sperm samples were collected on all males at terminal sacrifice. The parameters evaluated included spermatid heads, spermatid counts, and motility. The left epididymis and cauda epididymis were weighed.

## Statistical Methods

Paternal and maternal body weights were analyzed using Bartlett’s test of homogeneity of variances (Sokal and Rohlf, 1969a) and the analysis of variance (Snedecor and Cochran, 1967a). If Bartlett’s test was not significant (P>0.05) and the analysis of variance was significant (P≤0.05), then Scheffe’s test (Scheffe, 1953) was used to identify the statistical significance of individual groups. If Bartlett’s test was significant (P≤0.05), the Kruskal-Wallis test (Sokal and Rohlf, 1969b) was used; in cases in which the Kruskal-Wallis test was significant (P≤0.05), Dunn’s (1964) method of multiple comparisons was used to identify the statistical significance of individual groups. These methods were also used to analyze fetal body weight and pup body weight per litter as well as all other evaluations involving continuous data. Observations of delivered and dead fetuses of the female-A dams and the fetuses from female-A dams caesarean-sectioned on an estimated day 14 of gestation were excluded from fetal body weight summaries and statistical analyses.

Group means and standard deviations were calculated for hematology and clinical chemistry parameters and for final mean body and epididymis weights. Epididymis-to-body-weight ratios were also calculated. Final mean body weights of males and females and mean epididymis weights and epididymis-to-body-weight ratios of males for each dosed group were compared to those of the control group by a two-tailed Student’s t-test. The standard deviations used in the t-tests were obtained by pooling the individual values for the control and dosed groups. Hematology and clinical chemistry data were evaluated using Dunnett’s test (Dunnett, 1955).

Proportion data (e.g., clinical findings and incidences of pregnancy, resorption, death, and total resorption) for mice presumed pregnant were analyzed using the Cochran-Armitage test for a linear trend in proportions (Snedecor and Cochran, 1967b) and Fisher’s exact test (Siegel, 1956).

Testis and body weight data obtained during sperm function evaluations were analyzed using a two-way analysis of variance. Sperm measurements were analyzed using the nonparametric test for interaction; if the interaction was not statistically significant, averages were taken for each compound over the concentrations of the second compound. Control and dosed group means were compared using either Shirley’s (1977) nonparametric multiple comparison procedure if a trend was present or Dunn’s (1964) nonparametric multiple comparison procedure if no trend was observed. The application of Shirley’s or Dunn’s procedure was determined by application of Jonckheere’s test (Jonckheere, 1954) for evidence of a dose-related trend. The outlier test of Dixon and Massey (1951) was employed to detect extreme values. Sperm motility was evaluated using the nonparametric comparison of Wilcoxon’s rank sum test (Wilcoxon, 1945).