# Introduction

AIDS is a lethal multi-system disease that has become a major public health problem since its recognition in 1981 (Gottlieb et al., 1981; Masur et al., 1981; Siegal et al., 1981). The etiological agent of AIDS is a retrovirus now referred to as HIV (Coffin, 1986). To date, the most effective single agent in the treatment of HIV has been the first dideoxynucleoside analogue used in clinical trials, zidovudine (3′-azido-3′-deoxythymidine, AZT, Retrovir, azidothymidine, compound S, BW A509U, CAS No. 30516-87-1), commonly referred to as AZT (Vince et al., 1988; Amin, 1989).

AZT therapy produces numerous beneficial effects in AIDS patients including decreases in morbidity and increases in lifespan (Amin, 1989; Jeffries, 1989). The most important adverse side effects of AZT are anemia and granulocytopenia, which are believed to reflect bone marrow toxicity (Richman, 1988; Amin, 1989; Oksenhendler, 1989). Two types of anemia may occur with AZT therapy: macrocytic megaloblastic anemia and normocytic, normochromic anemia.

Several subacute and subchronic rodent toxicity studies have demonstrated that the primary toxicity of AZT is myelosuppression. Male Swiss (CD-1®) mice were administered 100, 250, 500, or 1,000 mg AZT/kg body weight by gavage for 30 days (Mansuri et al., 1990). No mortality or body weight effects were evident from AZT treatment. Erythropenia and increased mean cell volume were observed at all doses, and anemia was observed at the 1,000 mg/kg dose. Pathologic findings in the AZT-treated mice were consistent with the hematological results and included lymphoid depletion, reticuloendothelial hyperplasia in the spleen and thymus, and bone marrow hypocellularity.

In a 14-week subchronic study (NTP, 1999), B6C3F_1_ mice were treated with 0, 25, 50, 100, 400, or 1,000 mg AZT/kg body weight in 0.5% methylcellulose by gavage twice daily. On day 5, statistically significant dose-related decreases were observed in reticulocyte counts in males and females. Dose-related anemia was evident on days 23 and 93. To evaluate the ability of treated animals to reverse any compound-related effects after treatment ended, additional groups were administered 0, 50, 400, or 1,000 mg/kg AZT twice daily for 92 days and then held without additional treatment for 29 days. Improvement of hematology parameters indicated recovery of the bone marrow after treatment stopped. An apparently nontoxic, treatment-related clinical finding that affected all AZT-treated B6C3F_1_ mice was a darkening of the skin on the tail, feet, and/or muzzle.

Oral bioavailability of AZT was determined in female B6C3F_1_ mice by comparison of the area under the curve obtained from an oral dose to that of an intravenous dose at the same concentration (Trang et al., 1993). Bioavailability was found to be 0.86, 0.78, and 0.97 for the 15, 30, and 60 mg/kg oral doses. The mean elimination half-life values ranged from 17.3 to 19.9 minutes for the three intravenous doses and from 16.5 to 21.9 minutes for the three oral doses. Based on these results, the internal dose of AZT was linear and dose proportional over the oral-dose concentration range administered.

Standard teratology tests of AZT have been performed in rats and rabbits (Ayers, 1988). Rats were dosed orally with 125 to 500 mg/kg on gestation days 6 to 15. No fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 61 μg/g, or 76 times the antiviral ID_50_ (inhibitory dose for 50% of the viral population being tested). Rabbits were dosed orally at 125 to 500 mg/kg on gestation days 6 to 18, and no fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 40.2 μg/g, or 50 times the antiviral ID_50_.

Female Wistar rats were dosed three times orally with 100 mg/kg AZT at 5-hour intervals on gestation day 10 for a total dose of 300 mg/kg (Greene et al., 1990). No adverse effects on maternal body weight gain, feed consumption, fertility, hematological parameters, or growth or survival of offspring were observed. Drug concentrations 30 minutes after the last dose were 62.6 μg/mL in maternal plasma and 21.1 μg/g in fetal tissue.

Studies in C_3_H/He mice concluded that AZT has a direct toxic effect on the developing mouse embryo (Toltzis et al., 1991). Female mice were exposed to 0, 0.25, 0.5, or 2.5 mg AZT/mL drinking water for 8 weeks during mating and throughout gestation. All AZT groups had fewer pregnant mice per group, fewer pups per litter, and increased resorptions per mouse. Dose-related embryolethality was observed.

Because AIDS is a disease of immune suppression, the majority of AIDS patients actually die from characteristic opportunistic infections (Hardy, 1991; Harkins and Herriot, 1992). Thus, AIDS is increasingly treated with a combination of antiretroviral and antimicrobial drugs (Goldschmidt and Dong, 1992). One of the opportunistic infections leading to mortality in AIDS patients is tuberculosis (Nolan, 1992). AIDS patients with tuberculosis receive combination therapy with AZT and antituberculosis drugs, the primary one of which is isoniazid. Therapy for tuberculosis involves combinations of multiple antibacterial agents in order to eliminate the strains of organisms inducing the disease, including those resistant to isoniazid. The standard daily regimen is isoniazid (300 mg), rifampin (600 mg, or 450 mg for persons weighing less than 50 kg), and pyrazinamide (20 to 30 mg) for the first 2 months of treatment. Isoniazid and rifampin are continued for another 7 months, for a total therapy duration of 9 months (CDC, 1987; Barnes et al., 1991).

Isoniazid is used alone for chemoprophylaxis of tuberculosis at a daily dose of 5 to 10 mg/kg for 12 months. This therapeutic regimen is relevant to AIDS in that up to 31% of new cases of tuberculosis are subsequently found to be HIV seropositive (Jacobson, 1988). Therefore, it is now recommended that all HIV-seropositive patients, with or without clinical evidence of AIDS, be evaluated for the presence of latent tuberculosis infection and the need for chemoprophylaxis.

Isoniazid is water soluble and is readily absorbed into all body fluids and cells following administration by any route. Peak plasma concentrations of 3 to 5 μg/mL are obtained in humans 1 to 2 hours after an oral dose of 5 mg/kg (Goodman and Gilman’s, 1990). Thirty minutes after an oral dose of 144 mg/kg in albino mice, mean plasma concentrations of 44 μg/mL isoniazid were achieved (Rubin et al., 1952). The absorption, distribution, and excretion of isoniazid appear to be similar between rodents, dogs, and humans (Rubin and Burke, 1953; Peretti et al., 1987). The drug is excreted in the urine within 24 hours, primarily as acetylisoniazid and isonicotinic acid, products of acetylation and hydrolysis, respectively. Smaller quantities of isonicotinyl conjugates (e.g., glycine), isonicotinyl hydrazones, and N-methylisoniazid are also detected in urine (Goodman and Gilman’s, 1990). Isoniazid does not appear to accumulate following daily administration for up to 8 months (Rubin and Burke, 1953).

Acetylation by the enzyme N-acetyltransferase represents a major route of metabolism for isoniazid in rodents, dogs, and humans (Timbrell, 1981). The metabolism, pharmacokinetics, and toxicity of isoniazid are determined, in part, by the inheritance of a “rapid” or “slow” acetylator phenotype. The plasma concentrations of acetylisoniazid and isonicotinic acid are increased in rapid acetylators, while concentrations of unchanged isoniazid and hydrazones are increased in slow acetylators. The half-life of isoniazid in humans is approximately 3 hours in slow acetylators and 70 minutes in the rapid phenotype (Goodman and Gilman’s, 1990). Slow acetylators are more likely to develop isoniazid neurotoxicity, which results from the competitive inhibition of pyridoxal phosphokinase (reviewed by Blakemore, 1986). This enzyme phosphorylates vitamin B6 to form an active coenzyme that participates in a variety of enzymatic reactions. Timbrell et al. (1980) reviewed studies showing that the association of acetylator phenotype and hepatotoxicity is less clear. The metabolite acetylhydrazine is transformed by cytochrome P_450_ to an intermediate that covalently bonds to liver proteins. Acetylhydrazine can be further acetylated to diacetylhydrazine, a nontoxic moiety, and acetylation and P_450_-dependent biotransformation are inhibited by isoniazid. Therefore, hepatotoxicity appears to be dependent upon acetylator phenotype, which will determine the relative concentrations of isoniazid, acetylhydrazine, and diacetylhydrazine and on the relative activities of other metabolic pathways. In mice (or rodents), the acetylator phenotype is strain specific (Tannen and Weber, 1979). Swiss (CD-1®) mice are reported to be slow acetylators compared to Wistar rats (Mate et al., 1981). The authors reported that slow acetylation resulted in prolonged (18 hours) circulating levels of mono- and di-acetylhydrazine in mice; these metabolites were not detected in rats after 3 hours. The fact that mice, and not rats, develop lung tumors after long-term exposure to isoniazid led the investigators to correlate the slow acetylator phenotype with tumorigenicity.

Isoniazid has been used for the treatment of tuberculosis since 1951; clinical toxicities are fairly well known and include rash (2% incidence), fever (1.2%), jaundice (0.6%), and peripheral neuritis (0.2%) (Goodman and Gilman’s, 1990). Hypersensitivity, hematological effects (agranulocytosis, eosinophilia, thrombocytopenia, and anemia), vasculitis, arthritic symptoms, and neurologic effects occur at lesser incidences. Hepatotoxicity resulting in death can occur in some individuals. The peripheral neuritis and hepatotoxicity observed clinically with isoniazid use are reproducible in rodents (Timbrell, 1979; Blakemore, 1986).

The following oral lethal doses causing 50% mortality (LD_50_) for isoniazid in mice were determined by Benson et al. (1952): oral, 133 mg/kg; subcutaneous, 177 mg/kg; intravenous, 153 mg/kg; intraperitoneal, 130 mg/kg; and intramuscular, 137 mg/kg. In rats, the oral LD_50_ was 1,435 mg/kg, and in rabbits, the oral LD_50_ was 200 mg/kg and the intravenous LD_50_ 94 mg/kg. Male and female Sprague-Dawley rats were administered 0%, 0.025%, 0.05%, 0.25%, or 0.5% isoniazid in feed for 52 weeks (Harper and Worden, 1966). The authors reported that the 0.5% concentration was equivalent to a daily dose of 500 mg/kg; the majority of animals that received this dose died within a few weeks, and hepatic necrosis and ovarian or testicular hypertrophy were observed. Ovarian or testicular hypertrophy and reduced mean body weight gains were observed at 0.25%. No adverse effects were observed at 0.025% or 0.05%.

The carcinogenic potential of isoniazid in Swiss (CD-1^®^) mice has been studied by Menon and Bhide (1983). Beginning at 10 weeks of age, male and female mice were treated with 0 or 1.1 mg isoniazid by gavage in distilled water 5 days per week until death. A significant increase in the incidences of adenocarcinoma of the lung were observed in treated males and females. In a second experiment, 1.1 mg/day was administered in distilled water by gavage to pregnant mice throughout gestation and lactation. Eight weeks after weaning, F_1_ males and F_1_ females were administered 0 (distilled water), 0.55, 1.1, or 2.2 mg isoniazid per day. Four weeks after initiation of treatment, F_1_ males and F_1_ females were mated. The dose of 2.2 mg/day was highly toxic to the F_1_ mice and resulted in mortality; therefore, no mating occurred at this dose. Pregnant F_1_ females received isoniazid treatment during gestation and lactation and were then divided into a group that was dosed postweaning and a group that was not. At study termination, the incidences of lung neoplasms were significantly increased in the F_1_ mice at all three doses and in both postweaning groups. The F_2_ generations from two groups were raised: a) from F_1_ mice given 1.1 mg/day with no treatment postweaning, and b) from F_1_ mice given 1.1 mg/day and 0.55 mg/day postweaning. The incidence of lung neoplasms was 11% in F_2_ mice from the first group, 70% in F_2_ mice from the second group, and 5% in the control group.

Reproductive and developmental toxicity studies of isoniazid have been conducted in Swiss (CD-1^®^) mice (Menon and Bhide, 1980). Groups of pregnant female mice were administered 0 (distilled water), 1.1, or 2.2 mg/day by gavage during gestation days 1 to 4, gestation days 10 to 13, or gestation days 1 to 19. The results indicated that isoniazid induced early resorptions and embryolethality, but no teratogenicity. Hemorrhages were observed in some of the progeny from the isoniazid-treated dams. In a second experiment (Menon and Bhide, 1983), pregnant females were administered 0 (distilled water), 0.55, 1.1, or 2.2 mg isoniazid per day by gavage during gestation days 1 to 19. There were no adverse effects in the offspring of the dams administered 0.55 mg/day, while embryolethality and reduced mean body weights were observed in the offspring of the dams administered 1.1 or 2.2 mg/day. The F_1_ offspring were mated and then dosed during gestation days 1 to 19. Successful mating of the F_1_ offspring occurred only in the F_1_ group from dams that received 0.55 mg/day. Embryolethality was observed in the F_2_ generation of the group administered 0.55 mg/day.

## Study Rationale

This study of the combination of AZT and isoniazid was conducted by the NIEHS as part of its program to evaluate the toxicity of drugs used in the treatment of AIDS or the opportunistic infections accompanying AIDS in pregnant women and in the developing conceptus. Tuberculosis is a frequent complication of AIDS and is commonly treated with isoniazid. Additionally, effects on the motility and density of sperm were also evaluated. The National Toxicology Program has developed a protocol, published elsewhere (Morrissey et al., 1989; Harris et al., 1992), to facilitate the screening of chemicals for reproductive and developmental toxicity. Because the liver may be a target of isoniazid toxicity, based on the effects of isoniazid in humans, liver enzyme determinations were included, depending on sample availability.