# APPENDIX A Hematology Results

TABLE A1 Hematology Data for Male Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations^a^

| Vehicle Control | 100 + 0 | 200 + 0 | 400 + 0 | 0 + 100 | 100 + 100 | 200 + 100 | 400 + 100
n | 10 | 10 | 10 | 10 | 10 | 8 | 10 | 10
Hematocrit (%) | 45.1 ± 2.8 | 41.3 ± 3.3 | 40.9 ± 3.9^b^ | 40.7 ± 3.6 | 43.2 ± 2.7 | 40.2 ± 3.9 | 38.8 ± 7.2^**^ | 36.7 ± 3.7^**^
Hemoglobin (g/dL) | 15.3 ± 0.8 | 13.6 ± 1.4^*^ | 13.9 ± 1.4^b^ | 13.4 ± 1.2^**^ | 14.4 ± 0.7 | 13.4 ± 1.3^*^ | 12.9 ± 2.1^**^ | 12.2 ± 1.3^**^
Erythrocytes (10^6^/μL) | 9.77 ± 0.38 | 8.29 ± 0.76^**^ | 8.41 ± 0.66^**^,^b^ | 7.99 ± 0.66^**^ | 9.44 ± 0.61 | 8.23 ± 0.68^**^ | 7.67 ± 0.97^**^ | 7.26 ± 0.70^**^
Reticulocytes (10^5^/μL) | 3.3 ± 0.60 | 3.7 ± 0.85 | 3.7 ± 0.50 | 4.3 ± 0.53 | 4.2 ± 0.67 | 4.5 ± 1.23^*^ | 4.5 ± 0.78^*^ | 4.5 ± 1.04^*^
Mean cell volume (fL) | 46.2 ± 2.3 | 50.0 ± 2.7^*^ | 48.7 ± 3.6^b^ | 51.0 ± 3.1^**^ | 45.8 ± 2.0 | 49.0 ± 3.8 | 50.1 ± 5.2^*^ | 50.5 ± 2.4^*^
Mean cell hemoglobin (pg) | 15.7 ± 0.6 | 16.4 ± 0.7 | 16.5 ± 1.3^b^ | 16.7 ± 0.9 | 15.3 ± 0.5 | 16.3 ± 1.3 | 16.7 ± 1.3 | 16.8 ± 0.7^*^
Mean cell hemoglobin concentration (g/dL) | 34.0 ± 1.0 | 32.8 ± 1.3 | 33.9 ± 0.7^b^ | 32.8 ± 0.6 | 33.4 ± 0.7 | 33.3 ± 0.7 | 33.5 ± 1.7 | 33.3 ± 1.1
Platelets (10^3^/μL) | 1,421 ± 290.4 | 1,567 ± 311.0 | 1,608 ± 442.2^b^ | 1,686 ± 501.2 | 1,475 ± 313.5 | 1,612 ± 419.7 | 1,854 ± 769.9 | 1,863 ± 323.2
Leukocytes (10^3^/μL)^c^ | 7.74 ± 2.28 | 7.70 ± 2.46 | 8.44 ± 2.40^b^ | 6.84 ± 3.59 | 8.18 ± 2.27 | 7.56 ± 2.52 | 13.37 ± 22.71 | 6.67 ± 1.74
Segmented neutrophils (10^3^/μL) | 1.31 ± 0.67 | 0.98 ± 0.41 | 2.06 ± 2.53 | 1.87 ± 3.19 | 1.49 ± 0.62 | 1.93 ± 1.16 | 7.17 ± 19.55 | 0.82 ± 0.24
Lymphocytes (10^3^/μL) | 5.82 ± 0.36 | 6.11 ± 2.05 | 5.67 ± 1.54 | 4.42 ± 1.52 | 5.92 ± 1.85 | 5.08 ± 1.44 | 6.01 ± 3.65 | 5.19 ± 1.35
Monocytes (10^3^/μL) | 0.18 ± 0.09 | 0.19 ± 0.08 | 0.31 ± 0.21 | 0.21 ± 0.10 | 0.34 ± 0.13 | 0.27 ± 0.24 | 0.31 ± 0.44 | 0.27 ± 0.14
Basophils (10^3^/μL) | 0.02 ± 0.021 | 0.02 ± 0.018 | 0.02 ± 0.013 | 0.02 ± 0.014 | 0.02 ± 0.013 | 0.01 ± 0.016 | 0.01 ± 0.013 | 0.02 ± 0.013
Eosinophils (10^3^/μL) | 0.39 ± 0.19 | 0.40 ± 0.21 | 0.35 ± 0.22 | 0.25 ± 0.16 | 0.39 ± 0.21 | 0.25 ± 0.10 | 0.24 ± 0.21 | 0.35 ± 0.21
Large unstained cells (10^3^/μL) | 0.02 ± 0.01^d^ | 0.03 ± 0.02^e^ | 0.04 ± 0.04^d^ | 0.08 ± 0.17^b^ | 0.03 ± 0.01^e^ | 0.04 ± 0.02^f^ | 0.03 ± 0.02^g^ | 0.03 ± 0.02^e^
| 0 + 50 | 100 + 50 | 200 + 50 | 400 + 50 | 0 + 150 | 100 + 150 | 200 + 150 | 400 + 150
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
Hematocrit (%) | 42.2 ± 3.8 | 42.5 ± 2.7 | 38.9 ± 2.2^**^ | 38.2 ± 2.1^**^ | 41.5 ± 2.7 | 37.0 ± 2.9^**^ | 35.9 ± 2.9^**^ | 30.8 ± 6.0^**^
Hemoglobin (g/dL) | 14.2 ± 1.3 | 14.3 ± 0.8 | 13.1 ± 0.9^**^ | 12.8 ± 0.8^**^ | 13.8 ± 1.2 | 12.3 ± 1.0^*^ | 11.9 ± 1.1^**^ | 10.2 ± 1.9^**^
Erythrocytes (10^6^/μL) | 9.15 ± 0.80 | 8.75 ± 0.38^*^ | 7.86 ± 0.68^**^ | 7.81 ± 0.61^**^ | 9.17 ± 0.62 | 7.74 ± 0.69^**^ | 7.32 ± 0.64^**^ | 6.23 ± 0.94^**^
Reticulocytes (10^5^/μL) | 4.2 ± 1.61 | 4.1 ± 0.61 | 3.9 ± 0.43 | 4.3 ± 0.67 | 4.9 ± 0.66^**^ | 4.5 ± 0.71^*^ | 5.2 ± 1.09^**^ | 3.9 ± 1.41
Mean cell volume (fL) | 46.1 ± 1.3 | 48.5 ± 1.8 | 49.7 ± 2.7 | 49.0 ± 2.8 | 45.3 ± 2.4 | 48.0 ± 3.1 | 49.2 ± 3.1 | 49.2 ± 2.9
Mean cell hemoglobin (pg) | 15.5 ± 0.5 | 16.3 ± 0.6 | 16.7 ± 0.6 | 16.4 ± 0.8 | 15.1 ± 0.8 | 15.9 ± 1.0 | 16.3 ± 0.7 | 16.4 ± 1.0
Mean cell hemoglobin concentration (g/dL) | 33.7 ± 0.7 | 33.7 ± 0.6 | 33.6 ± 1.3 | 33.6 ± 0.7 | 33.3 ± 1.1 | 33.2 ± 0.9 | 33.2 ± 1.6 | 33.4 ± 1.0
Platelets (10^3^/μL) | 1,516 ± 269.6 | 1,502 ± 357.2 | 1,625 ± 223.0 | 1,599 ± 215.8 | 1,514 ± 409.7 | 1,689 ± 238.3 | 1,834 ± 172.3 | 2,214 ± 345.5^**^
Leukocytes (10^3^/μL) | 10.03 ± 7.53 | 7.82 ± 2.28 | 7.05 ± 1.91 | 8.21 ± 1.41 | 7.71 ± 2.58 | 6.83 ± 1.88 | 6.89 ± 2.02 | 6.53 ± 2.00
Segmented neutrophils (10^3^/μL) | 3.35 ± 6.18 | 1.36 ± 1.07 | 1.19 ± 0.43 | 1.34 ± 0.49 | 1.22 ± 0.62 | 0.93 ± 0.36 | 1.00 ± 0.47 | 1.15 ± 1.30
Lymphocytes (10^3^/μL) | 5.80 ± 2.49 | 5.93 ± 1.40 | 5.20 ± 1.45 | 6.34 ± 1.43 | 5.96 ± 2.38 | 5.40 ± 1.65 | 5.08 ± 2.09 | 5.32 ± 1.61
Monocytes (10^3^/μL) | 0.34 ± 0.25 | 0.23 ± 0.11 | 0.26 ± 0.19 | 0.25 ± 0.16 | 0.27 ± 0.12 | 0.23 ± 0.17 | 0.24 ± 0.09 | 0.22 ± 0.08
Basophils (10^3^/μL) | 0.03 ± 0.027 | 0.03 ± 0.028 | 0.02 ± 0.013 | 0.01 ± 0.020 | 0.02 ± 0.016 | 0.02 ± 0.012 | 0.02 ± 0.016 | 0.02 ± 0.010
Eosinophils (10^3^/μL) | 0.41 ± 0.38 | 0.27 ± 0.19 | 0.35 ± 0.20 | 0.25 ± 0.15 | 0.22 ± 0.14 | 0.22 ± 0.14 | 0.32 ± 0.11 | 0.36 ± 0.27
Large unstained cells (10^3^/μL) | 0.10 ± 0.20^b^ | 0.03 ± 0.01^e^ | 0.03 ± 0.01^e^ | 0.03 ± 0.02^f^ | 0.03 ± 0.02^h^ | 0.03 ± 0.01^e^ | 0.03 ± 0.01^h^ | 0.03 ± 0.02^e^

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + isoniazid (mg/kg per day). Data are given as mean ± standard error. Statistical tests were performed on unrounded data.

b n=9

c Leukocyte counts corrected for nucleated erythrocyte counts greater than 10 per 100 leukocytes

d n=6

e n=8

f n=4

g n=5

h n=7

TABLE A2 Hematology Data for Female-A Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations^a^

| Vehicle Control | 100 + 0 | 200 + 0 | 400 + 0 | 0 + 100 | 100 + 100 | 200 + 100 | 400 + 100
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 19
Hematocrit (%) | 41.1 ± 3.0 | 40.8 ± 2.8 | 42.0 ± 2.9 | 41.0 ± 3.3 | 39.9 ± 3.1 | 38.8 ± 3.6 | 36.4 ± 8.3^*^ | 35.4 ± 10.1^*^
Hemoglobin (g/dL) | 14.1 ± 1.1 | 13.9 ± 1.1 | 14.2 ± 1.1 | 13.7 ± 1.3 | 13.4 ± 1.1 | 12.6 ± 1.1^*^ | 12.2 ± 2.8^**^ | 11.6 ± 3.2^**^
Erythrocytes (10^6^/μL) | 8.33 ± 0.68 | 7.56 ± 0.71 | 7.61 ± 0.73 | 7.45 ± 0.64 | 8.48 ± 0.78 | 7.01 ± 0.79^**^ | 6.57 ± 1.36^**^ | 6.26 ± 1.60^**^
Reticulocytes (10^5^/μL) | 3.8 ± 1.19^b^ | 3.4 ± 0.76 | 3.8 ± 0.78 | 3.5 ± 0.73 | 4.4 ± 1.27^b^ | 4.5 ± 1.94 | 4.5 ± 1.87 | 4.4 ± 2.42
Mean cell volume (fL) | 49.5 ± 2.6 | 54.2 ± 2.4^**^ | 55.4 ± 2.5^**^ | 55.1 ± 2.8^**^ | 47.1 ± 2.3 | 55.6 ± 3.5^**^ | 54.9 ± 4.5^**^ | 55.4 ± 5.7^**^
Mean cell hemoglobin (pg) | 17.0 ± 1.0 | 18.4 ± 1.0^**^ | 18.7 ± 0.9^**^ | 18.5 ± 1.1^**^ | 15.9 ± 0.9^*^ | 18.1 ± 1.2^*^ | 18.4 ± 1.6^**^ | 18.3 ± 1.5^**^
Mean cell hemoglobin concentration (g/dL) | 34.3 ± 1.2 | 34.0 ± 1.1 | 33.7 ± 1.2 | 33.5 ± 1.0 | 33.7 ± 1.0 | 32.5 ± 1.0^**^ | 33.5 ± 1.0 | 33.2 ± 1.5
Platelets (10^3^/μL) | 1,363 ± 222.8 | 1,409 ± 303.3 | 1,422 ± 356.3 | 1,479 ± 415.1 | 1,631 ± 300.9 | 1,705 ± 216.6^*^ | 1,792 ± 425.5^**^ | 1,772 ± 575.1
Leukocytes (10^3^/μL)^c^ | 7.49 ± 1.55 | 6.25 ± 1.43 | 6.43 ± 1.58 | 5.71 ± 1.60^**^ | 7.34 ± 1.63 | 5.95 ± 1.10^*^ | 5.60 ± 1.85^**^ | 5.00 ± 1.43^**^
Segmented neutrophils (10^3^/μL) | 2.27 ± 0.58 | 1.41 ± 0.74^**^ | 1.26 ± 0.57^**^ | 0.76 ± 0.47^**^ | 2.13 ± 0.85 | 1.50 ± 0.62^*^ | 1.13 ± 1.26^**^ | 0.67 ± 0.40^**^
Lymphocytes (10^3^/μL) | 4.62 ± 1.29 | 4.29 ± 1.07 | 4.72 ± 1.48 | 4.56 ± 1.47 | 4.70 ± 1.24 | 4.01 ± 0.81 | 4.09 ± 0.85 | 4.00 ± 1.23
Monocytes (10^3^/μL) | 0.31 ± 0.08 | 0.22 ± 0.08 | 0.18 ± 0.11^**^ | 0.13 ± 0.11^**^ | 0.27 ± 0.11 | 0.22 ± 0.08 | 0.17 ± 0.15^**^ | 0.13 ± 0.08^**^
Basophils (10^3^/μL) | 0.02 ± 0.009 | 0.01 ± 0.010 | 0.02 ± 0.010 | 0.01 ± 0.011 | 0.02 ± 0.009 | 0.01 ± 0.007^**^ | 0.01 ± 0.008 | 0.01 ± 0.007^**^
Eosinophils (10^3^/μL) | 0.25 ± 0.15 | 0.29 ± 0.20 | 0.23 ± 0.15 | 0.23 ± 0.14 | 0.20 ± 0.18 | 0.20 ± 0.19 | 0.19 ± 0.15 | 0.19 ± 0.17
Large unstained cells (10^3^/μL) | 0.02 ± 0.01 | 0.02 ± 0.01^b^ | 0.02 ± 0.01^d^ | 0.02 ± 0.01^e^ | 0.01 ± 0.01^b^ | 0.02 ± 0.01^g^ | 0.01 ± 0.01^d^ | 0.01 ± 0.01^i^
| 0 + 50 | 100 + 50 | 200 + 50 | 400 + 50 | 0 + 150 | 100 + 150 | 200 + 150 | 400 + 150
n | 20 | 20 | 20 | 20 | 20 | 20 | 17 | 18
Hematocrit (%) | 39.8 ± 3.9 | 39.9 ± 2.3 | 40.4 ± 3.8 | 39.6 ± 2.8 | 39.6 ± 3.3 | 36.5 ± 5.0 | 30.2 ± 11.7^**^ | 26.4 ± 12.4^**^
Hemoglobin (g/dL) | 13.6 ± 1.4 | 13.5 ± 0.9 | 13.7 ± 1.5 | 13.2 ± 1.0 | 13.1 ± 1.2 | 11.9 ± 1.6^**^ | 9.9 ± 3.7^**^ | 8.9 ± 3.9^**^
Erythrocytes (10^6^/μL) | 8.11 ± 0.69 | 7.56 ± 0.60 | 7.48 ± 0.74 | 7.12 ± 0.55^**^ | 8.31 ± 0.90 | 6.70 ± 0.98^**^ | 5.46 ± 1.94^**^ | 4.82 ± 1.94^**^
Reticulocytes (10^5^/μL) | 3.5 ± 1.17 | 3.5 ± 0.70^b^ | 3.6 ± 1.02 | 4.3 ± 1.23 | 5.2 ± 2.00 | 4.9 ± 1.88 | 4.8 ± 3.17 | 3.3 ± 2.22
Mean cell volume (fL) | 49.0 ± 2.0 | 53.0 ± 3.2^*^ | 54.1 ± 2.0^**^ | 55.7 ± 2.2^**^ | 47.8 ± 2.7 | 54.7 ± 3.8^**^ | 54.0 ± 7.4^**^ | 52.3 ± 7.2
Mean cell hemoglobin (pg) | 16.7 ± 0.7 | 17.9 ± 0.9 | 18.4 ± 1.0^**^ | 18.5 ± 0.9^**^ | 15.8 ± 1.0^*^ | 17.8 ± 1.1 | 17.8 ± 1.8 | 17.9 ± 1.8
Mean cell hemoglobin concentration (g/dL) | 34.1 ± 1.0 | 33.8 ± 1.1 | 33.9 ± 1.2 | 33.2 ± 0.8 | 33.0 ± 1.1^**^ | 32.6 ± 1.0^**^ | 33.1 ± 1.9^*^ | 34.4 ± 2.0
Platelets (10^3^/μL) | 1,507 + 276.0 | 1,528 ± 271.0 | 1,509 ± 398.7 | 1,549 ± 417.4 | 1,482 ± 453.2 | 1,732 ± 421.4^*^ | 2,025 ± 455.3^**^ | 2,347 ± 731.8^**^
Leukocytes (10^3^/μL) | 8.03 + 2.09 | 6.64 ± 2.14 | 6.16 ± 1.21 | 5.52 ± 1.96^**^ | 7.01 ± 1.66 | 6.09 ± 1.43 | 5.07 ± 1.62^**^ | 5.06 ± 1.50^**^
Segmented neutrophils (10^3^/μL) | 2.81 ± 1.36 | 1.52 ± 0.90^*^ | 1.19 ± 0.85^**^ | 0.83 ± 0.40^**^ | 1.75 ± 1.08 | 1.25 ± 0.65^**^ | 0.90 ± 0.79^**^ | 0.65 ± 0.34^**^
Lymphocytes (10^3^/μL) | 4.64 ± 1.29 | 4.61 ± 1.67 | 4.56 ± 0.95 | 4.25 ± 1.72 | 4.81 ± 1.30 | 4.43 ± 1.16 | 3.84 ± 1.07 | 4.10 ± 1.30
Monocytes (10^3^/μL) | 0.33 ± 0.16 | 0.24 ± 0.16 | 0.17 ± 0.08^**^ | 0.17 ± 0.07^**^ | 0.25 ± 0.11 | 0.20 ± 0.12^*^ | 0.16 ± 0.10^**^ | 0.14 ± 0.10^**^
Basophils (10^3^/μL) | 0.02 ± 0.010 | 0.02 ± 0.012 | 0.01 ± 0.009 | 0.01 ± 0.011 | 0.02 ± 0.010 | 0.01 ± 0.009 | 0.01 ± 0.007 | 0.01 ± 0.006^*^
Eosinophils (10^3^/μL) | 0.22 ± 0.14 | 0.23 ± 0.16 | 0.21 ± 0.17 | 0.24 ± 0.18 | 0.17 ± 0.13 | 0.19 ± 0.15 | 0.15 ± 0.11 | 0.15 ± 0.10
Large unstained cells (10^3^/μL) | 0.02 ± 0.01^f^ | 0.02 ± 0.02^f^ | 0.02 ± 0.01^g^ | 0.02 ± 0.01^h^ | 0.02 ± 0.01^f^ | 0.02 ± 0.01^d^ | 0.01 ± 0.01^d^ | 0.02 ± 0.01^i^

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + isoniazid (mg/kg per day). Data are given as mean ± standard error. Statistical tests were performed on unrounded data.

b n=19

c Leukocyte counts corrected for nucleated erythrocyte counts greater than 10 per 100 leukocytes

d n=16

e n= 11

f n=18

g n=15

h n=14

i n=13

TABLE A3 Hematology Data for Female-B Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Isoniazid Combinations^a^

| Vehicle Control | 100 + 0 | 200 + 0 | 400 + 0 | 0+100 | 100 + 100 | 200 + 100 | 400 + 100
n | 20 | 20 | 20 | 20 | 13 or 14 | 13 or 14 | 13 or 14 | 13 or 14
Hematocrit (%) | 42.3 + 2.8 | 42.0 ± 2.5 | 41.3 ± 5.7 | 40.9 ± 2.7 | 41.0 ± 4.6 | 40.7 ± 3.3 | 42.8 ± 3.1 | 42.5 ± 3.2
Hemoglobin (g/dL) | 14.2 ± 0.8 | 14.1 ± 1.1 | 13.8 ± 2.2 | 13.7 ± 1.2 | 13.6 ± 1.6 | 13.5 ± 1.2 | 14.1 ± 0.9 | 14.2 ± 1.0
Erythrocytes (10^6^/μL) | 8.52 ± 0.60 | 8.08 ± 0.74 | 7.87 ± 1.52 | 7.75 ± 0.67 | 8.23 ± 1.00 | 7.81 ± 0.53 | 8.15 ± 0.77 | 8.02 ± 0.73
Reticulocytes (10^5^/μL)^b^ | 4.9 ± 1.19 | 5.2 ± 2.12 | 5.9 ± 1.35 | 5.8 ± 1.77 | 5.2 ± 1.68 | 6.0 ± 1.34 | 5.4 ± 2.21 | 6.7 ± 5.23
Mean cell volume (fL) | 49.7 ± 1.6 | 52.1 ± 2.2 | 53.2 ± 4.3 | 53.0 ± 4.0 | 49.9 ± 2.2 | 52.1 ± 3.1 | 52.7 ± 3.2 | 53.2 ± 4.5
Mean cell hemoglobin (pg) | 16.7 ± 0.5 | 17.4 ± 0.8 | 17.6 ± 1.0 | 17.7 ± 1.1^*^ | 16.6 ± 0.9 | 17.3 ± 0.8 | 17.3 ± 1.1 | 17.7 ± 1.1^*^
Mean cell hemoglobin concentration (g/dL) | 33.6 ± 0.8 | 33.4 ± 1.1 | 33.2 ± 1.7 | 33.5 ± 1.9 | 33.2 ± 1.0 | 32.2 ± 1.0 | 32.9 ± 0.5 | 33.4 ± 1.0
Platelets (10^3^/μL) | 1,497 ± 351.0 | 1,413 ± 309.9 | 1,417 ± 360.9 | 1,380 ± 234.1 | 1,458 ± 327.8 | 1,438 ± 234.0 | 1,461 ± 227.3 | 1,500 ± 212.7
Leukocytes (10^3^/μL)^c^ | 7.03 ± 1.78 | 6.99 ± 1.69 | 7.05 ± 0.85 | 7.33 ± 2.11 | 6.86 ± 1.42 | 6.01 ± 0.86 | 7.52 ± 2.21 | 6.39 ± 1.40
Segmented neutrophils (10^3^/μL)^b^ | 1.77 ± 0.65 | 1.73 ± 0.51 | 1.73 ± 0.77 | 1.58 ± 0.54 | 1.94 ± 0.77 | 1.70 ± 0.90 | 1.92 ± 0.86 | 1.63 ± 0.56
Lymphocytes (10^3^/μL)^b^ | 4.86 ± 1.14 | 4.69 ± 1.45 | 4.82 ± 1.06 | 5.23 ± 1.70 | 4.38 ± 0.84 | 3.94 ± 0.66 | 5.09 ± 1.80 | 4.28 ± 1.48
Monocytes (10^3^/μL)^b^ | 0.20 ± 0.14 | 0.23 ± 0.08 | 0.22 ± 0.09 | 0.22 ± 0.12 | 0.23 ± 0.12 | 0.20 ± 0.10 | 0.23 ± 0.24 | 0.19 ± 0.14
Basophils (10^3^/μL)^b^ | 0.01 ± 0.015 | 0.01 ± 0.012 | 0.01 ± 0.012 | 0.02 ± 0.016 | 0.02 ± 0.012 | 0.01 ± 0.009 | 0.01 ± 0.015 | 0.01 ± 0.012
Eosinophils (10^3^/μL)^b^ | 0.20 ± 0.20 | 0.31 ± 0.22 | 0.27 ± 0.20 | 0.27 ± 0.18 | 0.27 ± 0.25 | 0.16 ± 0.17 | 0.26 ± 0.21 | 0.26 ± 0.26
Large unstained cells (10^3^/μL)^b^ | 0.03 ± 0.02 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.03 ± 0.02 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.03 ± 0.01
| 0 + 50 | 100 + 50 | 200 + 50 | 400 + 50 | 0 + 150 | 100 + 150 | 200 + 150 | 400 + 150
n | 20 | 20 | 20 | 20 | 13 or 14 | 13 or 14 | 13 or 14 | 13 or 14
Hematocrit (%) | 42.9 ± 2.7 | 41.1 ± 2.5 | 40.1 ± 3.9 | 41.9 ± 2.6 | 42.4 ± 3.5 | 43.7 ± 3.7 | 42.6 ± 2.8 | 44.6 ± 3.3
Hemoglobin (g/dL) | 14.2 ± 1.0 | 13.6 ± 0.8 | 13.4 ± 1.1 | 13.8 ± 0.8 | 14.1 ± 1.3 | 14.3 ± 1.3 | 14.1 ± 1.2 | 14.9 ± 1.2
Erythrocytes (10^6^/μL) | 8.68 ± 0.74 | 7.87 ± 0.57 | 7.72 ± 0.74 | 7.76 ± 0.43 | 8.60 ± 0.86 | 8.37 ± 1.01 | 8.06 ± 0.74 | 8.49 ± 0.71
Reticulocytes (10^5^/μL) | 5.5 ± 1.94 | 5.6 ± 2.15 | 5.7 ± 1.56 | 5.4 ± 1.93 | 4.8 ± 1.46 | 6.0 ± 1.80 | 6.2 ± 4.09 | 3.2 ± 1.97
Mean cell volume (fL) | 49.6 ± 2.5 | 52.3 ± 3.3 | 51.9 ± 2.5 | 54.0 ± 3.1 | 49.5 ± 2.2 | 52.5 ± 4.1 | 53.1 ± 4.4 | 52.6 ± 2.6
Mean cell hemoglobin (pg) | 16.4 ± 0.8 | 17.3 + 0.8 | 17.4 ± 0.6 | 17.8 ± 1.1^*^ | 16.4 ± 0.7 | 17.2 ± 1.4 | 17.5 ± 1.2 | 17.6 ± 0.9
Mean cell hemoglobin concentration (g/dL) | 33.1 ± 0.7 | 33.1 ± 1.2 | 33.6 ± 1.4 | 32.9 ± 1.0 | 33.2 ± 1.0 | 32.7 ± 1.2 | 33.0 ± 1.3 | 33.5 ± 1.0
Platelets (10^3^/μL) | 1,583 ± 271.4 | 1,580 ± 330.1 | 1,572 ± 428.4 | 1,495 ± 347.1 | 1,557 ± 304.2 | 1,435 ± 405.9 | 1,450 ± 313.9 | 1,483 ± 228.9
Leukocytes (10^3^/μL) | 6.93 ± 1.97 | 7.54 ± 1.95 | 7.49 ± 2.80 | 6.44 ± 1.92 | 7.19 ± 1.74 | 6.64 ± 2.08 | 6.58 ± 1.68 | 7.01 ± 1.72
Segmented neutrophils (10^3^/μL) | 1.78 ± 0.67 | 1.49 ± 0.48 | 2.06 ± 1.00 | 1.74 ± 0.51 | 1.90 ± 0.76 | 1.73 ± 0.75 | 1.29 ± 0.45 | 1.63 ± 0.70
Lymphocytes (10^3^/μL) | 4.81 ± 1.58 | 5.63 ± 1.77 | 4.83 ± 1.85 | 4.19 ± 1.30 | 4.79 ± 1.01 | 4.41 ± 1.66 | 4.74 ± 1.59 | 4.75 ± 1.54
Monocytes (10^3^/μL) | 0.15 ± 0.14 | 0.23 ± 0.06 | 0.25 ± 0.19 | 0.23 ± 0.14 | 0.19 ± 0.12 | 0.21 ± 0.13 | 0.23 ± 0.09 | 0.24 ± 0.11
Basophils (10^3^/μL) | 0.01 ± 0.009 | 0.02 ± 0.019 | 0.02 ± 0.018 | 0.02 ± 0.017 | 0.02 ± 0.020 | 0.01 ± 0.015 | 0.02 ± 0.014 | 0.02 ± 0.015
Eosinophils (10^3^/μL) | 0.17 ± 0.22 | 0.16 ± 0.15 | 0.32 ± 0.37 | 0.25 ± 0.25 | 0.28 ± 0.35 | 0.28 ± 0.33 | 0.28 ± 0.17 | 0.35 ± 0.11
Large unstained cells (10^3^/μL) | 0.02 ± 0.01 | 0.03 ± 0.02 | 0.02 ± 0.02 | 0.02 ± 0.01 | 0.03 ± 0.02 | 0.02 ± 0.01 | 0.02 ± 0.01 | 0.03 ± 0.01

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

a Daily gavage doses of AZT + isoniazid (mg/kg per day). Data are given as mean ± standard error. Statistical tests were performed on unrounded data.

b n=13 or 14

c Leukocyte counts corrected for nucleated erythrocyte counts greater than 10 per 100 leukocytes