# References

Amin, N.M. (1989). Zidovudine for treating AIDS: What physicians need to know. Postgrad. Med. 86, 195–208.2662155
Ayers, K.M. (1988). Preclinical toxicology of zidovudine: An overview. Am. J. Med. 85, 186–188.3044084
Bagdon, R.E. (1964). Experimental pharmacology and toxicology of sulfonamides. Exp. Chemother. 2, 249–306.
Bergan, T., and Brodwall, E.K. (1972). Kidney transport in man of sulfamethoxazole and trimethoprim. Chemotherapy 17, 320–333.4669555
Bergan, T., Brodwall, E.K., Vik-Mo, H., and Anstad, U. (1979). Pharmacokinetics of sulphadiazine, sulphamethoxazole and trimethoprim in patients with varying renal function. Infection 7 (Suppl. 4), S382–S387.511352
Berglund, F., Killander, J., and Pompeius, R. (1975). Effect of trimethoprim-sulfamethoxazole on the renal excretion of creatinine in man. J. Urol. 114, 802–808.1195454
Bushby, S.R.M. (1973). Trimethoprim-sulfamethoxazole: In vitro microbiological aspects. J. Infect. Dis. 128 (Suppl.), 442–462.
Chisholm, G.D., Waterworth, P.M., Calnan, J.S., and Garrod, L.P. (1973). Concentration of antibacterial agents in interstitial tissue fluid. Br. Med. J. 1, 569–573.4694402
Coffin, J.M. (1986). Genetic variation in AIDS viruses. Cell 46, 1–4.3013415
Cohen, H.N., Fyffe, J.A., Ratcliffe, W.A., McNicol, A.M., McIntyre, H., Kennedy, J.S., and Thomson, J.A. (1981). Effects of trimethoprim and sulphonamide preparations on the pituitary-thyroid axis of rodents. J. Endocrinol. 91, 299–303.6975345
Craig, W.A., and Kunin, C.M. (1973). Distribution of trimethoprim-sulfamethoxazole in tissues of rhesus monkeys. J. Infect. Dis. 128 (Suppl.), 575–579.
Dunn, O.J. (1964). Multiple comparisons using rank sums. Technometrics 6, 241–252.
Dunnett, C.W. (1955). A multiple comparison procedure for comparing several treatments with a control. J. Am. Stat. Assoc. 50, 1096–1121.
Follath, F. (1979). Pharmacokinetics of long half-life antimicrobials. J. Antimicrob. Chemother. 5, 97–102.536350
Freireich, E.J., Gehan, E.A., Rall, D.P., Schmidt, L.H., and Skipper, H.E. (1966). Quantitative comparison of toxicity of anticancer agents in mouse, rat, hamster, dog, monkey, and man. Cancer Chemother. Rep. 50, 219–244.4957125
Gleckman, R., Alvarez, S., and Joubert, D.W. (1979). Drug therapy reviews: Trimethoprim-sulfamethoxazole. Am. J. Hosp. Pharm. 36, 893–906.382841
Gleckman, R., Blagg, N., and Joubert, D.W. (1981). Trimethoprim: Mechanisms of action, antimicrobial activity, bacterial resistance, pharmacokinetics, adverse reactions, and therapeutic indications. Pharmacotherapy 1, 14–20.6985448
Goldschmidt, R.H., and Dong, B.J. (1992). Treatment of AIDS and HIV-related conditions: 1992. J. Am. Board Fam. Pract. 5, 335–350.1580182
Goodman and Gilman’s The Pharmacological Basis of Therapeutics (1990). 8th ed. (A.G. Gilman, T.W. Rall, A.S. Nies, and P. Taylor, Eds.). Pergamon Press, Inc., New York.
Gottlieb, M.S., Schroff, R., Schanker, H.M., Weisman, J.D., Fan, P.T., Wolf, R.A., and Saxon, A. (1981). Pneumocystis carinii pneumonia and mucosal candidiasis in previously healthy homosexual men: Evidence of a new acquired cellular immunodeficiency. N. Engl. J. Med. 305, 1425–1431.6272109
Greene, J.A., Ayers, K.M., de Miranda, P., and Tucker, W.E., Jr. (1990). Postnatal survival in Wistar rats following oral dosage with zidovudine on gestation day 10. Fundam. Appl. Toxicol. 15, 201–206.2373299
Hardy, W.D. (1991). Prophylaxis of AIDS-related opportunistic infections (OIs). Current status and future strategies. AIDS Clin. Rev. 145–180.1651099
Harkins, T., and Herriot, K.B. (1992). Medical management of acquired immune deficiency syndrome patients: A review. J. Am. Optom. Assoc. 63, 35–42.1583259
Harris, M.W., Chapin, R.E., Lockhart, A.C., and Jokinen, M.P. (1992). Assessment of short-term reproductive and developmental toxicity screen. Fundam. Appl. Toxicol. 19, 186–196.1516774
Hausen, I., Lykkegaard Nielsen, M., Heerfordt, L., Henriksen, B., and Bertelsen, S. (1973). Trimethoprim in normal and pathological human lung tissue. Chemotherapy 19, 221–234.4204085
Heath, J.E., and Littlefield, N.A. (1984). Morphological effects of subchronic oral sulfamethazine administration on Fischer 344 rats and B6C3F_1_ mice. Toxicol. Pathol. 12, 3–9.6494732
Herzlich, B.C., Ranginwala, M., Nawabi, I., and Herbert, V. (1990). Synergy of inhibition of DNA synthesis in human bone marrow by azidothymidine plus deficiency of folate and/or vitamin B_12_? Am. J. Hematol. 33, 177–183.2301378
Hollander, M., and Wolfe, D.A. (1973). Nonparametric Statistical Methods, pp. 120–123. John Wiley and Sons, New York.
Hughes, D.T.D. (1979). Antibiotic treatment of chronic bronchitis. J. R. Coll. Physicians Lond. 13, 26–28.253030
Hughes, W.T., and Smith, B.L. (1984). Efficacy of diaminodiphenylsulfone and other drugs in murine Pneumocystis carcinii pneumonitis. Antimicrob. Agents Chemother. 26, 436–440.6335017
Israel, D.S., and Plaisance, K.I. (1991). Neutropenia in patients infected with human immunodeficiency virus. Clin. Pharm. 10, 268–279.2032444
Jeffries, D.J. (1989). Targets for antiviral therapy of human immunodeficiency virus infection. J. Infect. 18 (Suppl. 1), 5–13.2464649
Jonckheere, A.R. (1954). A distribution-free k-sample test against ordered alternatives. Biometrika 41, 133–145.
Kremers, P., Duvivier, J., and Heusghem, C. (1974). Pharmacokinetic studies of co-trimoxazole in man after single and repeated doses. J. Clin. Pharmacal. 14, 112–117.
Kreutz, R. (1981). Investigation on the influence of trimethoprim at the intrauterine development in the rat [in German, English summary]. Anat. Anz. 149, 151–159.7258662
Lewis, M.R. (1938). Inertness of sulfanilamide in relation to tumors in mice. Am. J. Cancer 34, 431–433.
MacKenzie, C.G., and MacKenzie, J.B. (1943). Effect of sulfonamides and thioureas on the thyroid gland and basal metabolism. Endocrinology 32, 185–209.
Mansuri, M.M., Hitchcock, M.J., Buroker, R.A., Bregman, C.L., Ghazzouli, I., Desiderio, J.V., Starrett, J.E., Sterzycki, R.Z., and Martin, J.C. (1990). Comparison of in vitro biological properties and mouse toxicities of three thymidine analogs active against human immunodeficiency virus. Antimicrob. Agents Chemother. 34, 637–641.1693057
Masur, H., Michelis, M.A., Greene, J.B., Onorato, I., Stouwe, R.A., Holzman, R.S., Wormser, G., Brettman, L., Lange, M., Murray, H.W., and Cunningham-Rundles, S. (1981). An outbreak of community-acquired Pneumocystis carinii pneumonia: Initial manifestation of cellular immune dysfunction. N. Engl. J. Med. 305, 1431–1438.6975437
The Merck Index (1989). 11th ed. (S. Budavari, Ed.), p. 8892. Merck and Company, Rahway, NJ.
Miller, R., and Salter, A. (1973). The passage of trimethoprim/sulfamethoxazole to breast milk and its significance. Proceedings of the Eighth Congress of Chemotherapy (G.K. Daikos, Ed.), pp. 687–691. Hellenic Society, Athens.
National Research Council (NRC) (1978). Nutrient Requirements of Laboratory Animals. No. 10, pp. 38–53. National Academy of Sciences, Washington, DC.
National Toxicology Program (NTP) (1998). Toxicology and Carcinogenesis Studies of AZT (CAS No. 30516–87-1) and AZT/α:-Interferon A/D in B6C3F_1_ Mice (Gavage Studies). Technical Report Series No. 469. NIH Publication No. 99–3959. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, Research Triangle Park, NC.
Nguyen, B.T., and Stadtsbaeder, S. (1985). Comparative effects of cotrimoxazole (trimethoprimsulphamethoxazole) and spiramycin in pregnant mice infected with Toxoplasma gondii (Beverley strain). Br. J. Pharmacol. 85, 713–716.3875381
Nicholls, M.W.M. (1972). Trimethoprim levels in cerebrospinal fluid. J. Clin. Pathol. 25, 550. (Abstr.)
Physicians’ Desk Reference (PDR) (1994). 48th ed., pp. 120–123, 802–807, 1973–1975. Medical Economics Company, Inc., Montvale, NJ.
Registry of Toxic Effects of Chemical Substances (RTECS) (1989). 1985–1986 Edition, p. 22,746. National Institute for Occupational Safety and Health, Cincinnati, OH.
Reid, D.W., Caille, G., and Kaufman, N.R. (1975). Maternal and transplacental kinetics of trimethoprim and sulfamethoxazole, separately and in combination. Can. Med. Assoc. J. 112 (Suppl.), 67–72.1137830
Revell, P., O’Doherty, M.J., Tang, A., and Savidge, G.F. (1991). Folic acid absorption in patients infected with the human immunodeficiency virus. J. Intern. Med. 230, 227–231.1680150
Richman, D.D. (1988). The treatment of HIV infection. Azidothymidine (AZT) and other new antiviral drugs. Infect. Dis. Clin. North Am. 2, 397–407.2462584
Rieder, J. (1973). Excretion of sulfamethoxazole and trimethoprim into human bile. J. Infect. Dis. 128 (Suppl.), 574.4777541
Rieder, J., Schwartz, D.E., and Zangaglia, O. (1974). Passage of sulfamethoxazole and trimethoprim into the bile in man. Chemotherapy 20, 65–81.4845675
Romankiewicz, J.A. (1974). Factors influencing renal distribution of antibiotics: A key to therapy of pyelonephritis. Drug Intell. Clin. Pharm. 8, 512–519.
Salmon, J.D., Fowle, A.S.E., and Bye, A. (1975). Concentrations of trimethoprim and sulphamethoxazole in aqueous humor and plasma from regimens of co-trimoxazole in man. J. Antimicrob. Chemother. 1, 205–211.1165232
Salter, A. J. (1973). The toxicity profile of trimethoprim/sulphamethoxazole after four years of widespread use. Med. J. Aust. 1, 70–74.4758163
Salter, A.J. (1982). Overview. Trimethoprim-sulfamethoxazole: An assessment of more than 12 years of use. Rev. Infect. Dis. 4, 196–236.7051224
Schwartz, D.E., and Rieder, J. (1970). Pharmacokinetics of sulfamethoxazole plus trimethoprim in man and their distribution in the rat. Chemotherapy 15, 337–355.5514974
Schwartz, D.E., and Ziegler, W.H. (1969). Assay and pharmacokinetics of trimethoprim in man and animals. Postgrad. Med. J. 45 (Suppl.), 32–37.4307160
Sharpstone, P. (1969). The renal handling of trimethoprim and sulphamethoxazole in man. Postgrad. Med. J. 45, 38–42.5364313
Siegal, F.P., Lopez, C., Hammer, G.S., Brown, A.E., Kornfeld, S.J., Gold, J., Hassett, J., Hirschman, S.Z., Cunningham-Rundles, C., Adelsberg, B.R., Parham, D.M., Siegal, M., Cunningham-Rundles, S., and Armstrong, D. (1981). Severe acquired immunodeficiency in male homosexuals manifested by chronic perianal ulcerative herpes simplex lesions. N. Engl. J. Med. 305, 1439–1444.6272110
Siegel, S. (1956). Nonparametric Statistics for the Behavioral Sciences, pp.96–104. McGraw-Hill, New York.
Sigel, C.W., and Brent, D.A. (1973). Identification of trimethoprim 3-oxide as a new urinary metabolite of trimethoprim in man. J. Pharm. Sci. 62, 694–695.4699000
Sigel, C.W., Grace, M.E., and Nichol, C.A. (1973). Metabolism of trimethoprim in man and measurement of a new metabolite: A new fluorescence assay. J. Infect. Dis. 128 (Suppl.), 580–583.
Snedecor, G.W., and Cochran, W.G., Eds. (1967). Test for a linear trend in proportions. In Statistical Methods, 6th ed., pp. 246–248. Iowa State University Press, Ames, IA.
Snower, D.P., and Well, S.C. (1993). Changing etiology of macrocytosis. Zidovudine as a frequent causative factor. Am. J. Clin. Pathol. 99, 57–60.8422018
Stokstad, E.L.R., and Koch, J. (1967). Folic acid metabolism. Physiol. Rev. 47, 83–116.5343223
Swarm, R.L., Roberts, G.K.S., Levy, A.C., and Hines, L.R. (1973). Observations on the thyroid gland in rats following the administration of sulfamethoxazole and trimethoprim. Toxicol. Appl. Pharmacol. 24, 351–363.4634184
Szabo, K.T. (1989). Congenital Malformations in Laboratory and Farm Animals, pp. 10, 195–200. Academic Press, Inc., San Diego, CA.
Timmermans, L. (1974). Influence of antibiotics on spermatogenesis. J. Urol. 112, 348–349.4852428
Toltzis, P., Marx, C.M., Kleinman, N., Levine, E.M., and Schmidt, E.V. (1991). Zidovudine-associated embryonic toxicity in mice. J. Infect. Dis. 163, 1212–1218.2037787
Trang, J.M., Prejean, J.D., James, R.H., Irwin, R.D., Goehl, T.J., and Page, J.G. (1993). Zidovudine bioavailability and linear pharmacokinetics in female B6C3F_1_ mice. Drug Metab. Dispos. 21, 189–193.8095218
Udall, V. (1969). Toxicology of sulphonamide-trimethoprim combinations. Postgrad. Med. J. 45 (Suppl.), 42–45.
Vince, R., Hua, M., Brownell, J., Daluge, S., Lee, F.C., Shannon, W.M., Lavelle, G.C., Qualls, J., Weislow, O.S., Kiser, R., Canonico, P.G., Schultz, R.H., Narayanan, V.L., Mayo, J.G., Shoemaker, R.H., and Boyd, M.R. (1988). Potent and selective activity of a new carbocyclic nucleoside analog (Carbovir: NSC 614846) against human immunodeficiency virus in vitro. Biochem. Biophys. Res. Commun. 156, 1046–1053.2847711
Walzer, P.D., Kurtis-Kim, C., Foy, J.M., Linke, M.J., and Cushion, M.T. (1988). Inhibitors of folic acid synthesis in the treatment of experimental Pneumocystis carinii pneumonia. Antimicrob. Agents Chemother. 32, 96–103.3258144
Williams, D.A. (1971). A test for differences between treatment means when several dose levels are compared with a zero dose control. Biometrics 27, 103–117.5547548
Williams, D.A. (1972). The comparison of several dose levels with a zero dose control. Biometrics 28, 519–531.5037867
Wofsy, C.B. (1987). Use of trimethoprim-sulfamethoxazole in the treatment of Pneumocystis carinii in patients with acquired immunodeficiency syndrome. Rev. Infect. Dis. 9 (Suppl. 2), S184–S194.3554457
Woods, D.D. (1940). The relation of p-aminobenzoic acid to the mechanism of the action of sulphanilamide. Br. J. Exp. Pathol. 21, 74–90.
Yamamoto, K., Hirose, K., Eigyo, M., Jyoyama, H., and Naito, Y. (1973). Pharmacological studies on sulfamethoxazole trimethoprim and their mixture [in Japanese, English summary]. Chemotherapy (Tokyo) 21, 187–196.
Ylikorkala, O., Sjostedt, E., Jarvinen, P.A., Tikkanen, R., and Gaines, T. (1973). Trimethoprim-sulfonamide combination administered orally and intravaginally in the first trimester of pregnancy: Its absorption into serum and transfer to amniotic fluid. Acta Obstet. Gynecol. Scand. 52, 229–234.4743777