# Peer Review

The draft report on the reproductive, developmental, and general toxicity studies of 3′-azido-3′-deoxythymidine (AZT), trimethoprim/sulfamethoxazole (TMP/SMX), and folinic acid combinations was evaluated by peer reviewers. These reviewers serve as independent scientists, not as representatives of any institution, company, or governmental agency. In this capacity, reviewers determine if the design and conditions of these studies are appropriate and ensure that this reproductive, developmental, and general toxicity study report presents the experimental results and conclusions fully and clearly. The comments of the reviewers were reviewed prior to the finalization of this document. Changes were made such that the concerns of the reviewers were addressed to the extent possible.

- Michael J. Brabec, Ph.D.
  Eastern Michigan University
  Department of Chemistry
  YpsilanU, MI
- Jay Gandy, Ph.D.
  University of Arkansas for Medical Sciences
  Department of Pharmacology and Toxicology
  Little Rock, AR