# Discussion

The most significant measurable evidence of toxicity in adult mice subsequent to the administration of 3′-azido-3′-deoxythymidine (AZT) alone was in the hematopoietic system. A mild dose-related anemia accompanied by macrocytosis occurred in male and female mice. The histopathologic findings of cellular depletion of the bone marrow corresponded well with the clinical anemia. Administration of trimethoprim/sulfamethoxazole (TMP/SMX) alone to adult mice resulted in only a mild anemia in the 3,000 mg/kg TMP/SMX group of male and female mice.

Combination therapy with AZT and TMP/SMX resulted in hematopoietic toxicity of far greater severity than that detected subsequent to the administration of either compound alone. Male and female-A mice receiving combination therapy developed severe anemia, reticulocytopenia, and thrombocytosis accompanied by cellular depletion of bone marrow and diminished splenic hematopoiesis. The anemia was degenerative, with diminished reticulocyte counts, and surprisingly was microcytic, with elevated MCHC values indicative of hemolysis. In contrast, female-B mice administered combination therapy for only approximately 10 days had only a mild regenerative anemia that was macrocytic and was accompanied by elevated reticulocyte counts. These findings suggest that with the shorter duration of dosing in female-B animals, the macrocytic erythrocytes did not rupture and hemolysis did not occur. The addition of folinic acid had no apparent impact on the hematopoietic toxicity induced by the administration of AZT alone, TMP/SMX alone, or combinations of AZT and TMP/SMX.

Other manifestations of toxicity frequently encountered that are likely secondary to debilitation from the anemia consisted of lower mean body weight and body weight gain, pallor, piloerection, labored breathing, diminished motor activity, and emaciation.

Manifestations of toxicity involving other organ systems were also encountered in adult mice administered TMP/SMX alone or in combination with AZT. Gross enlargement of the thyroid gland, manifested microscopically by thyroid gland hyperplasia, was found in all groups receiving TMP/SMX alone or in combination with AZT. The thyroid gland lesions were believed to be due to SMX, as the goitrogenic properties of sulfonamides in rodents were previously described in the literature (Cohen et al., 1981; Heath and Littlefield, 1984). It has been established that these effects are mediated through the adenohypophysis; decreased blood levels of thyroid hormone reverse the negative feedback mechanism that inhibits thyrotropic hormone production, resulting in unregulated stimulation of the thyroid gland. Thyroid gland hyperplasia induced by long-term oral administration of SMX to rats progressed to tumor formation with lung metastasis (Swarm et al., 1973). The carcinogenic properties of sulfonamides have been of interest to investigators since the 1930s due to the structural similarity between sulfonamides and aniline dyes (Lewis, 1938). Neoplasms of the thyroid gland were not observed in this study.

TMP/SMX alone and in combination with AZT also resulted in hepatocyte hypertrophy. Minor elevations in alanine aminotransferase activity accompanied the hepatocyte hypertrophy. Thymic atrophy encountered in many control female mice in this study appeared to be associated with pregnancy and the number of fetuses per dam. Administration of AZT in combination with TMP/SMX potentiated the development of thymic atrophy.

Evidence of reproductive toxicity was also observed in this study. The most striking compound-related effect was the incidence of cleft palate noted in the fetuses of female-A mice that received 2,000 or 3,000 mg/kg TMP/SMX alone or in combination with AZT; at least 80% of the fetuses in 100% of the litters had cleft palate. These compounds, TMP and SMX, have distinct inhibitory effects on the function of folic acid, a vitamin required for macromolecular synthesis and cell division. Folic acid antagonists are known to induce developmental anomalies, including cleft palate (Szabo, 1989). The finding of a 100% incidence of cleft palate in litters from females administered two or three times the therapeutic dose of TMP/SMX was unexpected. The lack of any improvement in the dose groups supplemented with folinic acid at 100 times the nutritional requirement was equally surprising; these results suggest that the increased incidence of cleft palate following treatment with TMP/SMX results from a mechanism other than inhibition of folic acid synthesis. These fetuses also exhibited increased incidences of open eyes and distended abdomens. The distended abdomens likely were secondary to the cleft palate and its effect on the ability to swallow.

In female-A and female-B mice, AZT alone produced decreases in uterine weights, live litter sizes, pup body weights, and fetal weight. Administration of AZT also increased pup deaths and resorptions. Administration of 2,000 or 3,000 mg/kg TMP/SMX alone produced mortality in pups and fetuses and slightly reduced the number of litters and the live litter size in the female-A and female-B groups. Administration of 1,000, 2,000, or 3,000 mg/kg TMP/SMX in the female-A and female-B groups decreased litter size, increased the number of pups dying on days 1 through 4, and decreased pup body weights.

Male mice treated with 1,000, 2,000, or 3,000 mg/kg TMP/SMX alone or in combination with 200 or 400 mg/kg AZT had decreased left testicular weights. Diminished sperm motility occurred in groups treated with 200 or 400 mg/kg AZT alone and in groups treated with 2,000 or 3,000 mg/kg TMP/SMX alone. Diminished sperm motility also occurred in all groups treated with combinations of AZT and TMP/SMX.

In general, the combination of AZT and TMP/SMX at a few times the therapeutic dose appeared to cause synergistic effects, and the basis for this synergism is not known. The liver lesions induced by TMP/SMX are consistent with the hypothesis that TMP/SMX causes liver toxicity and inhibits the metabolism of AZT, resulting in increased plasma levels or half-life. Although the animal model was not folate deficient, administration of folinic acid failed to significantly ameliorate any of the toxic effects of AZT and/or TMP/SMX. Generally, the toxicity observed in this study tended to correspond with the duration of dosing. Overall toxicity was greatest in female-A mice dosed for approximately 30 days. Manifestations of toxicity were less obvious in the males dosed for approximately 20 days and least obvious in female-B mice dosed for approximately 10 days.