# Results

## Survival and Clinical Findings

### Male Mice

Seven males died before the end of the study (Table 3). With the exception of three accidental gavage deaths, these deaths are potentially treatment related. Two deaths in the 400 + 3,000 + 0 mg/kg group were preceded by several days of body weight loss and are, therefore, likely to be related to treatment with 3′-azido-3′-deoxythymidine (AZT) or trimethoprim/sulfamethoxazole (TMP/SMX). Statistically significant (P≤0.05) incidences of pallor and piloerection occurred in the 200 + 3,000 + 0 mg/kg and 400 + 3,000 + 0 mg/kg groups. A significant incidence of piloerection was also noted in the 400 + 2,000 + 10 mg/kg and 0 + 3,000 + 0 mg/kg groups. Other less significant findings generally occurred in the mice that died and occurred only on the day of death.

TABLE 3 Early Deaths of Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Number of Deaths | Day of Death | Type of Death | Clinical Findings
0 + 2,000 + 0 | 1 | 16 | Found dead | None
400 + 2,000 + 10 | 1 | 22 | Gavage accident | Piloerection, pallor, head swelling
0 + 3,000 + 0 | 1 | 10 | Moribund | Decreased motor activity, labored breathing, abdominal distension
0 + 3,000 + 0 | 1 | 14 | Gavage accident | Labored breathing, pallor, piloerection
400 + 3,000 + 0 | 1 | 8 | Gavage accident | None
400 + 3,000 + 0 | 1 | 14 | Found dead | None
400 + 3,000 + 0 | 1 | 21 | Moribund | Pallor, piloerection, labored breathing

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

### Female-A Mice

Among female-A mice, there were 73 early deaths (Table 4), occurring primarily in the groups administered 2,000 or 3,000 mg TMP/SMX per kg body weight in conjunction with 200 or 400 mg AZT/kg body weight. Only one of these deaths was a gavage accident. Folinic acid had no obvious impact on mortality or clinical findings in the female-A groups.

Female-A mice exhibited a higher frequency of clinical findings compared to male and female-B mice. This is likely due to a higher total dose in female-A mice resulting from increased duration of treatment as well as the increased maternal body weight that occurred late in gestation. In addition to pallor and piloerection, which were significantly increased in most groups administered AZT and TMP/SMX, significant occurrences of labored breathing, decreased motor activity, and emaciation were noted.

### Female-B Mice

There were nine early deaths in the female-B group (Table 5), including one gavage accident. Most deaths occurred in mice administered 3,000 mg TMP/SMX per kg body weight, regardless of the dose of AZT.

The only significant incidences of clinical findings (pallor and piloerection) occurred in the 400 + 3,000 + 0 mg/kg group. As discussed earlier, the apparent difference in toxicity for the female-A mice and female-B mice results from a higher total dosage administered to the female-A mice late in gestation due to increased maternal weights and the fact that female-A mice were dosed for a longer period of time.

TABLE 4 Early Deaths of Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Number of Deaths | Day of Death | Type of Death | Clinical Findings
400 + 0 + 10 | 1 | 17 | Moribund | Piloerection, pallor, paralysis
0 + 2,000 + 10 | 1 | 3 | Gavage accident | Decreased motor activity, labored breathing
0 + 2,000 + 10 | 2 | 15, 17 | Moribund | Mass, pallor, decreased motor activity, cold to touch, tremors
200 + 2,000 + 0 | 7 | 17 - 31 | Moribund | Labored breathing, pallor, decreased motor activity, hunched, cold to touch, emaciation, piloerection
400 + 2,000 + 0 | 8 | 21 - 28 | Moribund | Decreased motor activity, labored breathing, pallor, cold to touch, hunched, piloerection
400 + 2,000 + 10 | 10 | 17 - 31 | Moribund | Decreased motor activity, labored breathing, pallor, piloerection, cold to touch, emaciated, hunched
400 + 2,000 + 10 | 1 | 30 | Found dead | Piloerection, pallor
0 + 3,000 + 0 | 2 | 3, 29 | Found dead | Piloerection, pallor
0 + 3,000 + 10 | 3 | 4 - 30 | Found dead | Piloerection, pallor
0 + 3,000 + 10 | 1 | 16 | Moribund | Piloerection, pallor, decreased motor activity, labored breathing
200 + 3,000 + 0 | 2 | 16, 29 | Found dead | Piloerection, pallor
200 + 3,000 +0 | 16 | 17 - 30 | Moribund | Piloerection, pallor, decreased motor activity, emaciation, hunched, labored breathing
400 + 3,000 + 0 | 2 | 14, 5 | Found dead | Piloerection, pallor
400 + 3,000 + 0 | 17 | 13 - 30 | Moribund | Piloerection, pallor, labored breathing, emaciation, decreased motor activity

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

TABLE 5 Early Deaths of Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Number of Deaths | Day of Presumed Gestation | Type of Death | Clinical Findings
0 + 2,000 + 0 | 1 | 16 | Gavage accident | Decreased motor activity, cold to touch, labored breathing
0 + 3,000 + 0 | 1 | 15 | Found dead | None
0 + 3,000 + 10 | 2 | 3, 14 | Found dead | None
0 + 3,000 + 10 | 1 | 14 | Moribund | Labored breathing, pallor, piloerection
200 + 3,000 + 0 | 1 | 19 | Found dead | None
400 + 3,000 + 0 | 2 | 14, 16 | Moribund | Labored breathing, pallor, piloerection
400 + 3,000 + 0 | 1 | 16 | Found dead | Piloerection, pallor

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

## Body and Organ Weights

### Male Mice

Administration of AZT, TMP/SMX, or folinic acid alone or in combination did not affect mean body weights or body weight gains during the study (Figure 1). No biologically important differences occurred. The average body weight gain for the 0 + 3,000 + 10 mg/kg group was significantly increased (P≤0.05) for days 5 to 21; this was not considered biologically important, as the difference from the control value was small.

The right epididymis weights and epididymis-to-body-weight ratios were comparable among dose groups.

### Female-A Mice

Mean body weights and body weight gains were generally comparable among all groups for days 0 to 16 (Figure 2). The 200 + 3,000 + 0 mg/kg and 400 + 3,000 + 0 mg/kg groups did exhibit significant decreases in mean body weight gains during this interval.

FIGURE 1 Mean Body Weights of Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid (TSAC=terminal sacrifice)

FIGURE 2 Mean Body Weights of Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

(Plots A and C show body weights from day 0 through terminal sacrifice [TSAC]. Plots B and D show the identical data, except that body weights at TSAC are after gravid uterine weights have been subtracted. Group final mean body weights and corrected body weights include only values for dams that were actually pregnant and were sacrificed and caesarean-sectioned as scheduled on presumed day 18 of gestation.)

(Plots E and G show body weights from day 0 through terminal sacrifice [TSAC]. Plots F and H show the identical data, except that body weights at TSAC are after gravid uterme weights have been subtracted. Group final mean body weights and corrected body weights include only values for dams that were actually pregnant and were sacrificed and caesarean-sectioned as scheduled on presumed day 18 of gestation.)

During study days 20 to 26, significant decreases in mean body weights and/or body weight gains occurred for the following groups: 200 + 0 + 0 mg/kg, 400 + 0 + 0 mg/kg, 400 + 0 + 10 mg/kg, 200 + 1,000 + 0 mg/kg, 400 + 1,000 + 0 mg/kg, 200 + 2,000 + 0 mg/kg, 400 + 2,000 + 0 mg/kg, 400 + 2,000 + 10 mg/kg, 200 + 3,000 + 0 mg/kg, and 400 + 3,000 + 0 mg/kg. These decreases in mean body weight represented resorption of conceptuses and changes in gravid uterine weight.

Gravid uterine weights were significantly (P≤0.05) reduced by administration of AZT (200 or 400 mg/kg) with or without folinic acid (Table 6). Final mean body weights, gravid uterine weights, or corrected mean body weights were not evaluated for the following groups due to the lack of viable fetuses: 400 + 1,000 + 0 mg/kg, 200 + 2,000 + 0 mg/kg, 400 + 2,000 + 0 mg/kg, 400 + 2,000 + 10 mg/kg, 200 + 3,000 + 0 mg/kg, and 400 + 3,000 + 0 mg/kg. Final mean body weights, gravid uterine weights, and corrected maternal mean body weights for those groups with viable fetuses were comparable to control values or significantly decreased

TABLE 6 The Effect of Oral Administration of AZT, TMP/SMX, and Folinic Acid on Final Mean Body Weights (FMBW) and Gravid Uterine Weights (GUW) of Female-A Mice in the Reproductive, Developmental, and General Toxicity Study in Swiss (CD-1®) Mice

Dose^a^ | Number | Mean Body Weights
| | FMBW | GUW | CBW^b^
0 + 0 + 0 | 8 | 52 9 ± 5 5 | 17 4 ± 4 9 | 35 5 ± 4 0
0 + 0 + 10 | 14 | 52 9 ± 5 7 | 18 1 ± 4 1 | 34 8 ± 2 5
200 + 0 + 0 | 9 | 45 4 ± 8 8 | 8 8 ± 6 7 | 36 6 ± 3 8
400 + 0 + 0 | 4 | 38 2 ± 3 1 | 3 0 ± 1 9^▲^ | 35 2 ± 2 2
400 + 0 + 10 | 6 | 36 5 ± 5 2^*^ | 3 7 ± 3 6^*^ | 32 8 ± 3 7
0 + 1,000 + 0 | 10 | 50 9 ± 6 7 | 16 3 ± 4 8 | 34 6 ± 3 0
200 + 1,000 + 0 | 6 | 33 8 ± 6 7^*^ | 0 8 ± 0 5^*^ | 33 0 ± 6 4
0 + 2,000 + 0 | 13 | 49 9 ± 3 6 | 15 1 ± 2 1 | 34 8 ± 2 3
0 + 2,000 + 10 | 7 | 53 7 ± 2 7 | 16 2 ± 1 0 | 37 5 ± 2 3
0 + 3,000 + 0 | 10 | 45 3 ± 4 7^*^ | 13 6 ± 2 7 | 31 7 ± 3 4
0 + 3,000 + 10 | 9 | 45 9 ± 5 8 | 12 4 ± 3 9 | 33 4 ± 4 1

* Significantly different from the control group (P≤0.05) by Dunnett’s or Dunn’s test

▲ Not statistically significant, probably due to small sample size

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day), data include only groups with viable fetuses

b Corrected body weight = final mean body weight minus gravid uterine weight

(P≤0.05) compared to the control group. Final mean body weights were significantly decreased (P≤0.05) in the following groups: 400 + 0 + 0 mg/kg, 400 + 0 + 10 mg/kg, 200 + 1,000 + 0 mg/kg, and 0 + 3,000 + 0 mg/kg. Gravid uterine weights were significantly decreased in the 400 + 0 + 10 mg/kg and the 200 + 1,000 + 0 mg/kg groups.

### Female-B Mice

Mean body weights on day 15 of gestation were significantly decreased (P≤0.05) in the following groups: 200 + 2,000 + 0 mg/kg, 400 + 2,000 + 0 mg/kg, 400 + 2,000 + 10 mg/kg, 200 + 3,000 + 0 mg/kg, and 400 + 3,000 + 0 mg/kg. Mean body weights for days 0, 8, and 12 for all groups and day 15 for groups other than those listed above were not different from those of the control group (Figure 3).

Mean body weight gains for all groups for days 0 to 8 were comparable to control values. Mean body weight gains during the intervals day 8 to 12 and/or day 12 to 15 were decreased in the following groups: 400 + 0 + 10 mg/kg, 200 + 1,000 + 0 mg/kg, 400 + 1,000 + 0 mg/kg, 200 + 2,000 + 0 mg/kg, 400 + 2,000 + 0 mg/kg, 400 + 2,000 + 10 mg/kg, 200 + 3,000 + 0 mg/kg, and 400 + 3,000 + 0 mg/kg. For days 0 to 15 of gestation, the following groups had decreased mean body weight gains: 400 + 0 + 10 mg/kg, 400 + 1,000 + 0 mg/kg, 200 + 2,000 + 0 mg/kg, 400 + 2,000 + 0 mg/kg, 400 + 2,000 + 10 mg/kg, 200 + 3,000 + 0 mg/kg, and 400 + 3,000 + 0 mg/kg.

For groups with viable pups, mean pup weights on day 0 of lactation were decreased in the following groups: 400 + 0 + 0 mg/kg, 400 + 0 + 10 mg/kg, 0 + 2,000 + 0 mg/kg, 0 + 2,000 + 10 mg/kg, 0 + 3,000 + 0 mg/kg, and 0 + 3,000 + 10 mg/kg. For pups that survived until day 4 of lactation, pup weights were comparable among the groups, with the exception of the 400 + 0 + 10 mg/kg group, for which mean pup weight was decreased (P≤0.05) compared to pups in the control group.

FIGURE 3 Mean Body Weights of Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid (GD=gestation day; LD=lactation day)

Note: Data exclude values for dams that had no live or surviving pups at weighing.

## Clinical Pathology

### Hematology

Although difficulties arise when comparing results of males and females or of groups dosed differently, it appears that the duration of dosing had a major impact on the severity of the hematology results. The severity was greatest in the female-A groups dosed for approximately 30 days. Alterations were not as prominent in the males dosed for approximately 20 days, and the female-B groups dosed for approximately 10 days had rather mild alterations. Specific details for males and females are discussed in the following sections.

#### Male Mice

In general, male mice administered AZT alone developed a slight anemia, neutropenia, and thrombocytosis. TMP/SMX alone resulted in a mild anemia only in the 3,000 mg/kg group and a treatment-related monocytosis. Administration of folinic acid alone resulted in no biologically significant alterations.

Combination therapy with AZT and TMP/SMX resulted in a severe anemia, a marked reticulocytopenia, a prominent leukopenia, and a significant thrombocytosis. The severity of the anemia was far greater than that observed subsequent to treatment with either compound alone. An unexpected decrease in mean cell volume (MCV) values and an elevation in mean cell hemoglobin concentration (MCHC) values accompanied the anemia.

With the exception of a marginal decrease in the severity of the AZT-induced anemia and thrombocytosis, administration of folinic acid had no major protective impact on any of the hematology parameters evaluated.

##### AZT Alone

The most significant alteration detected subsequent to the administration of AZT alone to male mice was a dose-related anemia. Respective mean erythrocyte (RBC) counts (Figure 4 and Table A1) of male mice receiving 200 or 400 mg AZT/kg body weight were approximately 20% (7.98 × 10^6^/μL; P≤0.01) and 32% (6.79 × 10^6^/μL; P≤0.01) lower than the mean RBC count (9.96 × 10^6^/μL) of the control group. Reduced hemoglobin (Hgb) and hematocrit (Hct) values paralleled the dose-related declines in RBC counts. Increases in MCV and mean cell hemoglobin (MCH) values also accompanied the dose-related anemia. Significant alterations were not present in the MCHC values or reticulocyte counts (Figure 5 and Table A1).

Although not statistically significant, the leukocyte (WBC) count (Figure 6 and Table A1) of male mice administered AZT alone was lower than that of the control group. Evaluation of the corresponding differential data revealed that the marginal leukopenia was predominately neutrophilic. Respective mean segmented neutrophil counts for males receiving 200 or 400 mg/kg AZT were approximately 50% (0.61 × 10^3^/μL; P≤0.05) and 38% (0.76 × 10^3^/μL) lower than the mean segmented neutrophil count (1.22 × 10^3^/μL) of the control group. Significant alterations were not encountered in the other leukocyte differential parameters.

FIGURE 4 Mean Erythrocyte Values for Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

FIGURE 5 Mean Reticulocyte Values for Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

FIGURE 6 Mean Leukocyte Values for Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

A treatment-related elevation in platelet count (Figure 7 and Table A1) was also evident in male mice administered AZT alone. The mean platelet count of male mice receiving 400 mg/kg AZT alone was approximately 40% (1,517 × 10^3^/μL; P≤0.05) higher than the mean platelet count (1,094 × 10^3^/μL) of the control group.

##### TMP/SMX Alone

A mild anemia was evident in male mice administered 3,000 mg TMP/SMX per kg body weight. The mean RBC count (Figure 4 and Table A1) of male mice administered 3,000 mg/kg was approximately 20% (8.01 × 10^6^/μL; P≤0.01) lower than the mean RBC count (9.96 × 10^6^/μL) of the control group. Reduced Hgb and Hct values paralleled the decline in RBC counts. Statistically significant alterations were not evident in MCV, MCH, or MCHC values. Significant alterations were not detected in any of the hematology parameters evaluated in male mice receiving 1,000 or 2,000 mg/kg, and reticulocyte counts (Figure 5 and Table A1) were not altered in any of the treatment groups.

A mild elevation in platelet count (Figure 7 and Table A1) was detected in male mice administered 3,000 mg/kg. Although not statistically significant, the mean platelet count of male mice administered 3,000 mg/kg was approximately 30% (1,397 × 10^3^/μL) higher than the mean platelet count (1,094 × 10^3^/μL) of the control group. Significant alterations did not occur in the mean platelet count of male mice administered 1,000 or 2,000 mg/kg.

Significant alterations were not evident in the WBC counts (Figure 6 and Table A1) of male mice administered TMP/SMX. Evaluation of the corresponding differential data, however, revealed a significant elevation in the number of monocytes of the 3,000 mg/kg group. Male mice administered 3,000 mg/kg had a mean monocyte count approximately 90% (0.29 × 10^3^/μL; P≤0.05) higher than the mean monocyte count (0.15 × 10^3^/μL) of the control group. Biologically significant alterations were not detected in the other differential parameters.

FIGURE 7 Mean Platelet Values for Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

##### Folinic Acid Alone

Administration of 10 mg folinic acid/kg body weight alone to male mice did not result in any biologically significant alterations in an any of the hematological parameters evaluated during this study.

##### AZT and TMP/SMX Combinations

A distinct treatment-related anemia resulted from the administration of AZT and TMP/SMX combinations, and the severity of the anemia was far greater than that due to either compound alone. Respective mean RBC counts (Figure 4 and Table A1) in male mice receiving 200 mg AZT/kg body weight + 1,000, 2,000, or 3,000 mg TMP/SMX per kg body weight were approximately 46% (5.39 × 10^6^/μL; P≤0.01), 51% (4.85 × 10^6^/μL; P≤0.01), or 59% (4.12 × 10^6^/μL; P≤0.01) lower than the mean RBC count (9.96 × 10^6^/μL) of the control group. Administration of 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX resulted in respective RBC counts approximately 49% (5.09 × 10^6^/μL; P≤0.01), 60% (3.97 × 10^6^/μL; P≤0.01), or 60% (3.95 × 10^6^/μL; P≤0.01) lower than the mean RBC count of the control group. Reduced Hgb and Hct values paralleled the treatment-related declines in RBC counts. Significant declines in MCV values and elevations in MCHC values occurred in some of the treatment groups that had severe anemia.

Although significant alterations in reticulocyte counts (Figure 5 and Table A1) were not observed in male mice administered AZT alone or TMP/SMX alone, a marked reticulocytopenia was evident subsequent to combination therapy. Respective mean reticulocyte counts obtained from male mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 35% (2.8 × 10^5^/μL), 70% (1.3 × 10^5^/μL; P≤0.01), or 63% (1.6 × 10^5^/μL; P≤0.01) lower than the mean reticulocyte count (4.3 × 10^5^/μL) of the control group. Respective mean reticulocyte counts detected in male mice receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 51% (2.1 × 10^5^/μL; P≤0.01), 72% (1.2 × 10^5^/mm^3^; P≤0.01), or 72% (1.2 × 10^5^/mm^3^; P≤0.01) lower than the mean reticulocyte count of the control group.

Although not statistically significant, a mild decrease in mean WBC counts (Figure 6 and Table A1) was evident in male mice receiving 200 or 400 mg/kg AZT + 1,000 or 2,000 mg/kg TMP/SMX. A distinct leukopenia (P≤0.01) occurred in male mice receiving the AZT and 3,000 mg/kg TMP/SMX combination. Respective mean WBC counts detected in male mice receiving 200 or 400 mg/kg AZT + 3,000 mg/kg TMP/SMX were approximately 49% (3.71 × 10^3^/μL) or 50% (3.64 × 10^3^/μL) lower than the mean WBC count (7.25 × 10^3^/μL) of the control group. Evaluation of the corresponding differential data revealed statistically significant declines in segmented neutrophil counts of groups receiving AZT + 1,000 or 2,000 mg/kg TMP/SMX and a statistically significant lymphopenia (Table A1) in males receiving AZT + 3,000 mg/kg TMP/SMX. Respective mean segmented neutrophil counts for male mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 62% (0.46 × 10^3^/μL; P≤0.01), 58% (0.51 × 10^3^/μL; P≤0.05), or 43% (0.69 × 10^3^/μL) lower than the mean segmented neutrophil count (1.22 × 10^3^/μL) of the control group. Respective mean segmented neutrophil counts for male mice receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 63% (0.45 × 10^3^/μL; P≤0.01), 69% (0.38 × 10^3^/μL; P≤0.01), or 40% (0.73 × 10^3^/μL) lower than the mean segmented neutrophil count (1.22 × 10^3^/μL) of the control group. Mean lymphocyte counts of male mice receiving 200 or 400 mg/kg AZT + 3,000 mg/kg TMP/SMX were approximately 50% (2.81 × 10^3^/μL; P≤0.05) or 51% (2.79 × 10^3^/μL; P≤0.05) lower than the mean lymphocyte count (5.65 × 10^3^/μL) of the control group. A statistically significant eosinopenia was also evident in male mice receiving AZT and 3,000 mg/kg TMP/SMX. Respective mean eosinophil counts in male mice receiving 200 or 400 mg/kg AZT + 3,000 mg/kg TMP/SMX were approximately 72% (0.05 × 10^3^/μL; P≤0.05) or 89% (0.02 × 10^3^/μL; P≤0.01) lower than the mean eosinophil count (0.18 × 10^3^/μL) of the control group. Statistically significant alterations were not evident in any of the other differential parameters.

A marked treatment-related thrombocytosis occurred in male mice receiving AZT and TMP/SMX combinations. Respective mean platelet counts (Figure 7 and Table A1) of male mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX levels were approximately 60% (1,708 × 10^3^/μL; P≤0.01), 60% (1,717 × 10^3^/μL; P≤0.01), or 90% (2,077 × 10^3^/μL; P≤0.01) higher than the mean platelet count (1,094 × 10^3^/μL) of the control group. Respective mean platelet counts of male mice receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX levels were approximately 50% (1,595 × 10^3^/μL; P≤0.01), 70% (1,818 × 10^3^/μL; P≤0.01), or 70% (1,866 × 10^3^/μL; P≤0.01) higher than the mean platelet count (1,094 × 10^3^/μL) of the control group.

##### AZT and Folinic Acid Combination

Administration of 10 mg/kg folinic acid in conjunction with 400 mg/kg AZT resulted in a marginal decrease in the severity of the anemia when compared to male mice administered 400 mg/kg AZT alone. The RBC count (Figure 4 and Table A1) of males administered 400 mg/kg AZT alone was approximately 32% (6.79 × 10^6^/μL) lower than the control group (9.96 × 10^6^/μL). The RBC count of the group receiving AZT and 10 mg/kg folinic acid was approximately 21% (7.84 × 10^6^/μL) lower than that of the control group.

Alterations in MCV and MCH values were not as pronounced in male mice receiving AZT + folinic acid as they were in mice administered AZT alone.

A significant thrombocytosis did not occur in male mice receiving AZT + folinic acid, whereas a significant elevation in platelet count (Figure 7 and Table A1) was evident in mice administered 400 mg/kg AZT alone. The platelet count of the group receiving combination therapy (AZT + folinic acid) was approximately 20% (1,353 × 10^3^/μL) higher than in the control group (1,094 × 10^3^/μL), whereas mice administered 400 mg/kg AZT alone had a mean platelet count approximately 40% (1,517 × 10^3^/μL; P≤0.05) higher than the control group (1,094 × 10^3^/μL).

Biologically significant differences were not observed in the reticulocyte count (Figure 5 and Table A1), WBC count (Figure 6 and Table A1), or differential values when mice receiving AZT + folinic acid were compared to mice administered AZT alone. The statistically significant decline in the mean segmented neutrophil count observed in mice receiving 400 mg/kg AZT + 10 mg/kg folinic acid was similar to the decline observed in mice administered 200 mg/kg AZT alone.

##### TMP/SMX and Folinic Acid Combinations

Administration of 10 mg/kg folinic acid in conjunction with 2,000 or 3,000 mg/kg TMP/SMX had no significant impact on any of the RBC parameters when compared to the values obtained subsequent to the administration of TMP/SMX alone (Figure 4 and Table A1). Significant differences in reticulocyte (Figure 5), total WBC (Figure 6), and platelet counts (Figure 7) likewise did not occur. Augmentation of the previously described monocytosis, however, did occur with folinic acid supplementation (Table A1). The significance of these elevated monocyte counts is not clear. No other biologically significant alterations were observed when mice receiving TMP/SMX were supplemented with folinic acid.

##### AZT, TMP/SMX, and Folinic Acid Combination

Administration of 10 mg/kg folinic acid in conjunction with AZT and TMP/SMX resulted in no significant differences in any of the parameters evaluated when compared to the group receiving 400 mg/kg AZT + 2,000 mg/kg TMP/SMX. This group of mice had a marked anemia (Figure 4 and Table A1) accompanied by an elevated MCHC. Reticulocytopenia and thrombocytosis (Figures 5 and 7) were also evident. Although a statistically significant decline in the WBC count was not evident (Figure 6), evaluation of the corresponding differential data revealed a significant granulocytopenia (Table A1).

#### Female-A Mice

In general, the anemia, neutropenia, and thrombocytosis induced by AZT was slightly more severe in female-A mice than in males. TMP/SMX alone resulted in a slight anemia, thrombocytosis, and monocytosis with trends similar to those observed in male mice. No biologically significant alterations occurred subsequent to folinic acid administration alone.

Combination therapy with AZT and TMP/SMX resulted in a severe anemia, a marked reticulocytopenia, a prominent leukopenia, and a significant thrombocytosis. As with the males, the severity of the anemia was far greater than that observed subsequent to administration of either compound alone. Low MCV values and elevated MCHC values accompanied the anemia.

Administration of folinic acid in combination with AZT and TMP/SMX resulted in no protective effects.

##### AZT Alone

Administration of AZT alone to female-A mice resulted in a dose-related anemia (P≤0.01), and the severity of the anemia was slightly greater than in males. Respective mean RBC counts (Figure 8 and Table A2) of female-A mice receiving 200 or 400 mg/kg AZT were approximately 28% (6.26 × 10^6^/μL) or 39% (5.27 × 10^6^/μL) lower than the mean RBC count (8.64 × 10^6^/μL) in the control group. Reduced Hgb and Hct values paralleled the dose-related declines in RBC counts. Elevations in MCV and MCH values also accompanied the dose-related anemia. Significant alterations in MCHC values were not observed, and reticulocyte counts (Figure 9 and Table A2) were within the normal range.

Administration of AZT alone to female-A mice also resulted in a compound-related leukopenia. Respective mean WBC counts (Figure 10 and Table A2) in female-A mice receiving 200 or 400 mg/kg AZT were approximately 32% (4.57 × 10^3^/μL; P≤0.01) or 25% (5.00 × 10^3^/μL; P≤0.05) lower than the mean WBC count (6.69 × 10^3^/μL) of the control group. Evaluation of the corresponding differential data revealed significant declines in segmented neutrophils (P≤0.01) and monocytes (P≤0.01). Respective mean segmented neutrophil counts for the female-A mice receiving 200 or 400 mg/kg AZT were approximately 54% (0.72 × 10^3^/μL) or 68% (0.50 × 10^3^/μL) lower than the mean segmented neutrophil count (1.56 × 10^3^/μL) of the control group. Respective mean monocyte counts for the same treatment groups were approximately 47% (0.09 × 10^3^/μL) or 53% (0.08 × 10^3^/μL) lower than the mean monocyte count (0.17 × 10^3^/μL) of the control group. Statistically significant alterations in basophil counts were not considered to be biologically significant, and no other treatment-related alterations were evident in the other differential parameters evaluated.

FIGURE 8 Mean Red Blood Cell Values for Female Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

FIGURE 9 Mean Reticulocyte Values for Female Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

FIGURE 10 Mean Leukocyte Values for Female Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

A distinct dose-related thrombocytosis was evident in female-A mice administered AZT alone. Respective mean platelet counts (Figure 11 and Table A2) for female-A mice receiving 200 or 400 mg/kg AZT alone were approximately 20% (1,325 × 10^3^/μL) or 60% (1,819 × 10^3^/μL; P≤0.01) higher than the mean platelet count (1,149 × 10^3^/μL) in the control group.

No other biologically significant alterations were observed in any of the other hematology parameters evaluated in female-A mice administered AZT alone.

##### TMP/SMX Alone

A mild anemia (P≤0.01) occurred in the female-A mice administered the highest dose of TMP/SMX alone. The mean RBC count (Figure 8 and Table A2) in the female-A mice administered 3,000 mg/kg was approximately 12% (7.64 × 10^6^/μL) lower than the mean RBC count (8.64 × 10^6^/μL) of the control group. Reduced Hgb and Hct values paralleled the decline in the mean RBC counts. Statistically significant alterations were not observed in MCV, MCH, or MCHC values. Significant alterations were not observed in any of the RBC parameters in female-A mice receiving 1,000 or 2,000 mg/kg TMP/SMX.

Significant alterations were not evident in the total WBC count (Figure 10 and Table A2) of female-A mice administered TMP/SMX alone. Evaluation of the corresponding differential data, however, revealed a treatment-related elevation in mean monocyte counts of the two highest dose groups (P≤0.01). Respective mean monocyte counts of female-A mice receiving 2,000 or 3,000 mg/kg TMP/SMX were approximately 60% (0.27 × 10^3^/μL) and 70% (0.28 × 10^3^/μL) higher than that (0.17 × 10^3^/μL) of the control group. The mean eosinophil count of the 3,000 mg/kg TMP/SMX group was approximately 64% (0.05 × 10^3^/μL; P≤0.05) lower than the mean (0.14 × 10^3^/μL) of the control group. Significant alterations were not evident in the other differential parameters evaluated.

##### Folinic Acid Alone

Administration of 10 mg/kg folinic acid to female-A mice did not result in any biologically significant alterations in any of the hematological parameters evaluated during this study.

FIGURE 11 Mean Platelet Values for Female Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

##### AZT and TMP/SMX Combinations

A distinct treatment-related anemia (P≤0.01) resulted from the administration of AZT and TMP/SMX combinations, and the severity of the anemia was far greater than that observed subsequent to the administration of either compound alone. Respective mean RBC counts (Figure 8 and Table A2) in female-A mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 66% (2.94 × 10^6^/μL), 71% (2.49 × 10^6^/μL), or 68% (2.79 × 10^6^/μL) lower than the mean RBC count (8.64 × 10^6^/μL) of the control group. Respective mean RBC counts of female-A mice receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 75% (2.16 × 10^6^/μL), 72% (2.40 × 10^6^/μL), or 72% (2.43 × 10^6^/μL) lower than the mean RBC count in the control group. It should be noted that the groups receiving 200 or 400 mg/kg AZT + 3,000 mg/kg TMP/SMX had, respectively, four and two survivors available for hematology evaluations at the end of the study. The anemia was accompanied by reduced Hgb and Hct values, significant treatment-related declines in MCV and MCH values, and consistent elevations in MCHC values (Table A2), suggestive of a hemolytic process.

A distinct treatment-related reticulocytopenia (Figure 9 and Table A2) occurred in mice receiving the AZT and TMP/SMX combinations. Respective mean reticulocyte values in female-A mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 37% (1.9 × 10^5^/μL), 63% (1.1 × 10^5^/μL; P≤0.01), or 60% (1.2 × 10^5^/μL) lower than the mean reticulocyte count (3.0 × 10^5^/μL) of the control group. Respective mean reticulocyte counts for mice receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 80% (0.6 × 10^5^/μL; P≤0.01), 60% (1.2 × 10^5^/μL; P≤0.01), or 97% (0.1 × 10^5^/μL; P≤0.01) lower than the mean reticulocyte count of the control group.

A statistically significant thrombocytosis was evident only in female-A mice receiving 200 mg/kg AZT + 1,000 mg/kg TMP/SMX. The platelet count (Figure 11 and Table A2) of this treatment group was approximately 80% (2,010 × 10^3^/μL; P≤0.01) higher than the mean (1,149 × 10^3^/μL) of the control group.

A prominent treatment-related leukopenia (P≤0.01) resulted from combination therapy with AZT and TMP/SMX. Respective mean WBC counts (Figure 10 and Table A2) of the female-A mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 39% (4.09 × 10^3^/μL), 61% (2.62 × 10^3^/μL), or 67% (2.18 × 10^3^/μL) lower than the mean WBC count (6.69 × 10^3^/μL) of the control group. Respective mean WBC counts in female-A mice receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX levels were approximately 51% (3.26 × 10^3^/μL), 63% (2.49 × 10^3^/μL), or 86% (0.94 × 10^3^/μL) lower than the mean WBC count of the control group. Evaluation of the corresponding differential data revealed that granulocytes, as well as mononuclear cells, participated in the leukopenia, with granulocytopenia being especially prominent. Respective mean segmented neutrophil counts for female-A mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 86% (0.22 × 10^3^/μL; P≤0.01), 94% (0.09 × 10^3^/μL; P≤0.01), or 88% (0.18 × 10^3^/μL; P≤0.05) lower than the mean segmented neutrophil count (1.56 × 10^3^/μL) of the control group. Respective mean segmented neutrophil counts of groups receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 95% (0.08 × 10^3^/μL; P≤0.01), 94% (0.10 × 10^3^/μL; P≤0.05), or 99% (0.02 × 10^3^/μL) lower than the mean segmented neutrophil count of the control group.

The concurrent lymphopenia in mice receiving AZT and TMP/SMX combinations was not as severe as the decreases in neutrophils. Respective mean lymphocyte counts (Table A2) for female-A mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were 23% (3.70 × 10^3^/μL), 48% (2.48 × 10^3^/μL; P≤0.01), or 59% (1.94 × 10^3^/μL; P≤0.05) lower than the mean lymphocyte count (4.79 × 10^3^/μL) of the control group. For the groups receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX, respective mean lymphocyte counts were approximately 35% (3.13 × 10^3^/μL; P≤0.01), 51% (2.33 × 10^3^/μL; P≤0.01), or 81% (0.91 × 10^3^/μL; P≤0.05) lower than the mean lymphocyte count of the control group. Reduced monocyte counts (Table A2) were evident in all of the combination treatment groups. Monocyte counts ranged from 65% (0.06 × 10^3^/μL; P≤0.01) lower than the control group (0.17 × 10^3^/μL) in the lowest AZT and TMP/SMX dose group to 0% in the group receiving the highest AZT and TMP/SMX combination. A similar reduction was evident in the eosinophil counts (Table A2), with a range from 36% (0.09 × 10^3^/μL) lower than the control group (0.14 × 10^3^/μL) in the low combination group to 0% in the group receiving the highest doses of AZT and TMP/SMX.

##### AZT and Folinic Acid Combination

Administration of 10 mg/kg folinic acid in conjunction with 400 mg/kg AZT had no significant impact on any of the hematological alterations caused by 400 mg/kg AZT alone. Alterations in RBC, Hgb, Hct, WBC, MCV, MCH, platelet, segmented neutrophil, and monocyte values were similar in female-A mice receiving AZT alone and AZT + folinic acid.

##### TMP/SMX and Folinic Acid Combinations

Administration of 10 mg/kg folinic acid in conjunction with 2,000 or 3,000 mg/kg TMP/SMX had no biologically significant impact on any of the hematological alterations induced by the administration of TMP/SMX alone. Mild declines in RBC, Hgb, and Hct values and significant elevations in monocyte counts occurred with remarkable similarity in female-A mice administered TMP/SMX alone and in groups receiving TMP/SMX +folinic acid.

##### AZT, TMP/SMX, and Folinic Acid Combination

Administration of 10 mg/kg folinic acid to female-A mice receiving the AZT and TMP/SMX combinations did not prevent the anemia, leukopenia, or reticulocytopenia (Figures 8, 9, and 10 and Table A2) induced by the administration of AZT and TMP/SMX. In fact, mice receiving 400 mg/kg AZT + 2,000 mg/kg TMP/SMX + 10 mg/kg folinic acid had a lower RBC count than any other group. The mean RBC count of this group was approximately 77% (2.00 × 10^6^/μL; P≤0.01) lower than the mean RBC count (8.64 × 10^6^/μL) of the control group. No protection was evident and no biologically significant differences occurred subsequent to the addition of folinic acid.

#### Female-B Mice

In general, hematological alterations in female-B mice were not as prominent as previously described for female-A mice. Administration of AZT alone did not result in overt anemia. A marginal decline in the RBC count did occur in female-B mice administered 400 mg/kg AZT alone, and elevated MCV and MCH values were evident. TMP/SMX administered alone produced no alterations, and changes did not occur subsequent to the administration of folinic acid alone.

Combination therapy with AZT and TMP/SMX resulted in anemia in the highest dose group, and in contrast to the hematological fmdings described in male and female-A mice, significant elevations in MCV values were evident. Treatment-related elevations in lymphocyte and monocyte counts were also evident, and MCHC values tended to be lower.

Administration of 10 mg/kg folinic acid appeared to inhibit the reticulocytosis induced by AZT alone but had no significant impact on other hematological parameters. Folinic acid administered in combination with TMP/SMX resulted in only a minor elevation in platelet counts. Folinic acid administration in conjunction with AZT + TMP/SMX produced only minor degrees of protection against the elevated MCV and MCH values. Anemia was not prevented.

##### AZT Alone

Hematological alterations encountered in female-B mice were considerably less severe than those previously described. Although overt anemia did not occur, a mild decrease in the RBC count (Figure 8 and Table A3) was evident in female mice receiving the highest dose of AZT. The mean RBC count of female-B mice receiving 400 mg/kg AZT was approximately 6% (7.77 × 10^6^/μL) lower than the mean (8.31 × 10^6^/μL) of the control group. Significant alterations in Hgb and Hct values were not present. Marginal elevations in MCV and MCH values accompanied the slight decline in the RBC count. The reticulocyte count (Figure 9 and Table A3) of the 400 mg/kg group was approximately 68% (7.9 × 10^5^/μL; P≤0.05) higher than the mean reticulocyte count (4.7 × 10^5^/μL) of the control group. Significant alterations were not detected in MCHC values, platelet counts (Figure 11 and Table A3), WBC counts (Figure 10 and Table A3), or any of the differential parameters of female-B mice administered AZT alone.

##### TMP/SMX Alone

Administration of 1,000, 2,000, or 3,000 mg/kg TMP/SMX to female-B mice did not result in any biologically significant alterations in any of the hematological parameters evaluated during this study.

##### Folinic Acid Alone

Administration of 10 mg/kg folinic acid to female-B mice did not result in any biologically significant alterations in any of the hematological parameters evaluated during this study.

##### AZT and TMP/SMX Combinations

Administration of 400 mg/kg AZT and 3,000 mg/kg TMP/SMX to female-B mice resulted in a mild anemia. The mean RBC count (Figure 8 and Table A3) of female-B mice receiving 400 mg/kg AZT + 3,000 mg/kg TMP/SMX was approximately 22% (6.48 × 10^6^/μL; P≤0.01) lower than the mean RBC count (8.31 × 10^6^/μL) of the control group. Mild declines in Hgb and Hct values paralleled the diminished RBC counts. The administration of 200 or 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX resulted in a 4% to 11% increase in MCV and MCH values as compared to the controls.

Treatment-related increases in reticulocyte counts (P≤0.01) correlated with the elevations in MCV values. Respective mean reticulocyte counts (Figure 9 and Table A3) of female-B mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 80% (8.4 × 10^5^/μL), 90% (8.8 × 10^5^/μL), or 110% (10.0 × 10^5^/μL) higher than the mean reticulocyte count (4.7 × 10^5^/μL) of the control group. Respective mean reticulocyte counts of female-B mice receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 100% (9.3 × 10^5^/μL), 150% (11.8 × 10^5^/μL), or 200% (14.2 × 10^5^/μL) higher than the mean of the control group.

Treatment-related increases in total WBC counts (Figure 10 and Table A3) were especially prominent in female-B mice receiving combination therapy with AZT and TMP/SMX. Respective mean WBC counts in mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX were approximately 60% (7.05 × 10^3^/μL; P≤0.05), 80% (8.20 × 10^3^/μL; P≤0.01), or 110% (9.32 × 10^3^/μL; P≤0.01) higher than the mean WBC count (4.47 × 10^3^/μL) of the control group. Respective mean WBC counts in female-B mice receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX levels were approximately 80% (8.14 × 10^3^/μL; P≤0.01), 90% (8.42 × 10^3^/μL; P≤0.01), or 90% (8.31 × 10^3^/μL; P≤0.01) higher than the mean of the control group. Evaluation of the corresponding differential data revealed that the leukocytosis was predominately mononuclear in origin. Respective mean lymphocyte counts for female-B mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX levels were approximately 70% (5.29 × 10^3^/μL; P≤0.05), 110% (6.54 × 10^3^/μL; P≤0.01), or 140% (7.61 × 10^3^/μL; P≤0.01) higher than the mean lymphocyte count (3.19 × 10^3^/μL) of the control group. Respective mean lymphocyte counts for female-B mice receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX levels were approximately 100% (6.40 × 10^3^/μL; P≤0.01), 110% (6.70 × 10^3^/μL; P≤0.01), or 100% (6.44 × 10^3^/μL; P≤0.01) higher than the mean of the control group. Although not always statistically significant, marked elevations in monocyte counts were also evident. Respective mean monocyte counts for female-B mice receiving 200 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX levels were approximately 110% (0.23 × 10^3^/μL; P≤0.01), 160% (0.28 × 10^3^/μL; P≤0.05), or 140% (0.26 × 10^3^/μL) higher than the mean (0.11 × 10^3^/μL) of the control group. Respective mean monocyte counts in female-B mice receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX levels were approximately 110% (0.23 × 10^3^/μL; P≤0.01), 100% (0.22 × 10^3^/μL), or 150% (0.27 × 10^3^/μL; P≤0.05) higher than the mean monocyte count of the control group. Biologically significant alterations were not observed in the other differential parameters.

##### AZT and Folinic Acid Combination

Administration of 10 mg/kg folinic acid to female-B mice in combination with 400 mg/kg AZT had no significant impact on the RBC alterations induced by the administration of 400 mg/kg AZT alone. Both treatment groups had statistically significant elevations in MCV and MCH values of a similar severity. Significant differences did occur, however, in reticulocyte counts (Figure 9 and Table A3). Mice administered AZT alone had a mild statistically significant elevation in the reticulocyte count, whereas mice receiving AZT and folinic acid had a reticulocyte count similar to that of the controls.

##### TMP/SMX and Folinic Acid Combinations

Administration of 10 mg/kg folinic acid in combination with 2,000 or 3,000 mg/kg TMP/SMX had no impact on RBC, WBC, or reticulocyte parameters. A mild elevation in the platelet count (Figure 11 and Table A3) was observed in mice receiving 3,000 mg/kg TMP/SMX + 10 mg/kg folinic acid. The mean platelet count of this treatment group was approximately 33% (1,870 × 10^3^/μL; P≤0.05) higher than the mean (1,403 × 10^3^/μL) of the control group.

##### AZT, TMP/SMX, and Folinic Acid Combination

Administration of 400 mg/kg AZT + 2,000 mg/kg TMP/SMX + 10 mg/kg folinic acid did not significantly alter the mild anemia, reticulocytosis, or lymphocytosis that occurred in mice administered only AZT and TMP/SMX. Although values were slightly elevated, statistically significant increases in MCV and MCH levels were not evident in mice receiving AZT + TMP/SMX + folinic acid. A statistically significant increase in these parameters did occur in female-B mice administered AZT and TMP/SMX alone. The differences in the MCV and MCH values between the two treatment groups was minor.

### Clinical Chemistry

#### Male Mice

##### AZT Alone

Administration of 200 or 400 mg/kg produced no biologically significant alterations in any of the clinical chemistry parameters evaluated (Tables 7 and A1).

##### TMP/SMX Alone

Administration of 1,000 or 2,000 mg/kg TMP/SMX resulted in no biologically significant alterations in any of the clinical chemistry parameters evaluated (Tables 7 and A1). However, the mean alanine aminotransferase (ALT) activity for male mice receiving 3,000 mg/kg TMP/SMX was 100 IU/L as compared to 21 IU/L for the control group. This significant (P≤0.01) increase is suggestive of hepatotoxicity. The statistically significant decline in alkaline phosphatase (ALP) activity was not considered to be biologically significant.

##### Folinic Acid Alone

Administration of 10 mg/kg folinic acid resulted in no biologically significant alterations in any of the clinical chemistry parameters evaluated (Tables 7 and A1).

##### AZT and TMP/SMX Combinations

Biologically significant alterations in clinical chemistry parameters were limited to the two treatment groups receiving AZT in combination with 3,000 mg/kg TMP/SMX. Respective mean creatinine levels (Tables 7 and A1) for male mice receiving 200 or 400 mg/kg AZT + 3,000 mg/kg TMP/SMX were 0.68 mg/dL (P≤0.01) or 0.61 mg/dL (P≤0.01) compared to the mean creatinine level (0.26 mg/dL) of the control group. Corresponding elevations in blood urea nitrogen (BUN) values (Table A1) were not evident. Although not statistically significant, minor elevations in ALT activity (Tables 7 and A1) in the same treatment groups were suggestive of hepatotoxicity. Respective mean ALT values in male mice receiving 200 or 400 mg/kg AZT + 3,000 mg/kg TMP/SMX were 51 IU/L or 42 IU/L compared to the mean ALT value (21 IU/L) of the control group. Minor statistically significant declines in ALP activity were not considered to be biologically significant.

TABLE 7 Summary of Principal Alterations in Clinical Chemistry Parameters for the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in in Swiss (CD-1®) Mice

Treatment Regimen | Male Mice | Female-A Mice | Female-B Mice
AZT alone | – | – | –
TMP/SMX alone | ALT elevations | ALT elevations, mild increases in creatinine | –
Folinic acid alone | – | – | –
AZT + folinic acid | – | – | –
TMP/SMX + folinic acid | ALT elevations | Mild increases in creatinine | –
AZT + TMP/SMX | ALT elevations, mild increases in creatinine | Mild increases in creatinine | –
AZT + TMP/SMX + folinic acid | – | Mild increase in creatinine | –

##### AZT and Folinic Acid Combination

Administration of 10 mg/kg folinic acid in combination with 400 mg/kg AZT resulted in no significant alterations in any of the clinical chemistry parameters (Tables 7 and A1) evaluated during this study.

##### TMP/SMX and Folinic Acid Combinations

Administration of 10 mg/kg folinic acid in combination with 2,000 mg/kg TMP/SMX resulted in no significant alterations. A minor elevation in ALT activity (P≤0.05) was observed in male mice receiving 3,000 mg/kg TMP/SMX + 10 mg/kg folinic acid (Tables 7 and A1). The mean ALT value of this group was 53 IU/L compared to the mean (21 IU/L) of the control group. This minor elevation was compatible with a minor degree of hepatotoxicity and was of a lesser severity than in mice administered 3,000 mg/kg TMP/SMX alone.

##### AZT, TMP/SMX, and Folinic Acid Combination

Male mice receiving 400 mg/kg AZT + 2,000 mg/kg TMP/SMX + 10 mg/kg folinic acid had no biologically significant alterations in any of the clinical chemistry parameters evaluated (Tables 7 and A1).

#### Female-A Mice

##### AZT Alone

Administration of 200 or 400 mg/kg AZT to female-A mice resulted in no biologically significant elevations in any of the clinical chemistry parameters evaluated. Minor statistically significant declines encountered in ALT and aspartate aminotransferase (AST) activities (Table A2) were considered to be biologically insignificant.

##### TMP/SMX Alone

Administration of 1,000 mg/kg TMP/SMX alone resulted in no significant elevations in any of the clinical chemistry parameters evaluated (Table A2), whereas 2,000 or 3,000 mg/kg TMP/SMX alone produced minor statistically significant elevations in creatinine concentrations and ALT activities (Tables 7 and A2). Respective mean creatinine concentrations for female-A mice receiving 2,000 or 3,000 mg/kg TMP/SMX were 0.53 mg/dL (P≤0.01) or 0.52 mg/dL (P≤0.05) compared to the mean creatinine concentration (0.37 mg/dL) of the control group. Corresponding elevations in BUN values did not occur. Respective mean ALT activities for female-A mice receiving 2,000 or 3,000 mg/kg TMP/SMX were 44 IU/L (P≤0.01) or 66 IU/L (P≤0.01), compared to the mean ALT activity (22 IU/L) of the control group. A minor statistically significant decline in AST activity of the 1,000 mg/kg TMP/SMX group was not considered to be biologically significant.

##### Folinic Acid Alone

Administration of 10 mg/kg folinic acid to female-A mice did not result in biologically significant alterations in any of the clinical chemistry parameters evaluated (Tables 7 and A2).

##### AZT and TMP/SMX Combinations

Administration of 200 or 400 mg/kg AZT + 1,000 mg/kg TMP/SMX did not result in biologically significant elevations in any of the clinical chemistry parameters evaluated (Table A2). Minor statistically significant declines in AST activity were considered to have no biological importance.

Minor elevations in BUN and serum creatinine values were evident in female-A mice receiving AZT and 2,000 mg/kg TMP/SMX. Respective mean creatinine levels of female-A mice receiving 200 or 400 mg/kg AZT + 2,000 mg/kg TMP/SMX were 0.56 mg/dL (P≤0.01) or 0.55 mg/dL (P≤0.05), compared to the mean (0.37 mg/dL) of the control group. Respective mean BUN values for the same treatment groups were 24.1 mg/dL or 25.4 mg/dL, compared to the mean BUN value (15.9 mg/dL) of the control group. Minor statistically significant declines in ALP activity observed in the same treatment groups were not considered to be biologically relevant. Statistically significant alterations in mice receiving AZT and 3,000 mg/kg TMP/SMX were considered to be irrelevant because of the limited number of survivors.

##### AZT and Folinic Acid Combination

Biologically significant alterations were not detected in any of the clinical chemistry parameters (Tables 7 and A2) evaluated in female-A mice receiving 400 mg/kg AZT + 10 mg/kg folinic acid. Statistically significant alterations in ALP and AST activities were not considered to be biologically significant.

##### TMP/SMX and Folinic Acid Combinations

Female-A mice receiving 3,000 mg/kg TMP/SMX + 10 mg/kg folinic acid had a minor significant elevation in the serum creatinine concentration (P≤0.01). The mean creatinine concentration was 0.56 mg/dL, compared to the mean (0.37 mg/dL) of the control group. A corresponding elevation in BUN was not evident (Tables 7 and A2).

##### AZT, TMP/SMX, and Folinic Acid Combination

Female-A mice receiving 400 mg/kg AZT + 2,000 mg/kg TMP/SMX + 10 mg/kg folinic acid had a minor elevation in the creatinine concentration (P≤0.01). Creatinine concentration of this group was 0.64 mg/dL, compared to the mean (0.37 mg/dL) of the control group. The corresponding BUN value was 24.0 mg/dL, compared to the mean (15.9 mg/dL) of the control group. A statistically significant decline in ALP activity was not considered to be biologically significant (Tables 7 and A2).

#### Female-B Mice

##### AZT Alone

Female-B mice receiving 200 or 400 mg/kg AZT had no biologically significant alterations in any of the clinical chemistry parameters evaluated during this study (Tables 7 and A3).

##### TMP/SMX Alone

Administration of 1,000, 2,000, or 3,000 mg/kg TMP/SMX alone resulted in no biologically significant alterations in any of the parameters evaluated (Table 7). Statistically significant declines in BUN values have no known biological relevance (Table A3).

##### Folinic Acid Alone

Female-B mice receiving 10 mg/kg folinic acid had no biologically significant alterations in any of the parameters evaluated (Tables 7 and A3).

##### AZT and TMP/SMX Combinations

Female-B mice receiving AZT and TMP/SMX combinations had no biologically significant alterations in any of the clinical chemistry parameters evaluated in this study (Tables 7 and A3). A statistically significant increase in the ALT activity of the group receiving 200 mg/kg AZT + 1,000 mg/kg TMP/SMX was not considered to be biologically significant because a dose-related pattern was not evident. Decreased BUN and creatinine values observed in many treatment groups were not considered to be biologically significant.

##### AZT and Folinic Acid Combination

Biologically significant alterations did not occur in any of the chemistry parameters evaluated in mice receiving 400 mg/kg AZT + 10 mg/kg folinic acid (Tables 7 and A3).

##### TMP/SMX and Folinic Acid Combinations

Female-B mice receiving combinations of TMP/SMX and folinic acid had no biologically significant alterations in clinical chemistry parameters (Tables 7 and A3). Lower BUN values of the group receiving 3,000 mg/kg TMP/SMX + 10 mg/kg folinic acid were considered to be within a normal range.

##### AZT, TMP/SMX, and Folinic Acid Combination

Administration of 400 mg/kg AZT + 2,000 mg/kg TMP/SMX + 10 mg/kg folinic acid did not result in any biologically significant alterations in any of the clinical chemistry parameters evaluated (Tables 7 and A3). Lower BUN and creatinine values have no known biological significance.

## Necropsy Observations

In general, there was good correlation between gross and microscopic lesions. The presence or increased incidence of gross lesions probably due to administration of one or more of the test chemicals was observed in the spleen, thymus, and thyroid gland. These lesions included enlarged or small spleen, small thymus, and enlarged thyroid gland.

### Spleen

Gross lesions of the spleen were observed in a total of only 4 of the 170 male mice in the study. The incidences of gross splenic lesions in males were too low to be considered meaningful.

Among the female-B groups receiving AZT, there was a dose-related increase in the incidences of enlarged spleens. Among the female-A groups, very few mice (a total of 6 of 340 mice) showed splenic enlargement. Considering all mice in all groups together, a total of 57 mice showed splenic enlargement at necropsy, and of those 57 mice, 48 had been receiving AZT. Within the female-B groups, the highest incidence of splenic enlargement occurred in the groups receiving 400 mg/kg AZT + 2,000 or 3,000 mg/kg TMP/SMX. TMP/SMX given alone had little if any meaningful effect on the incidence of splenic enlargement. Folinic acid appeared to have no meaningful effect on the occurrence of splenic enlargement.

Small spleens were observed in some mice receiving TMP/SMX, with or without additional treatment of AZT. Almost all of the mice with small spleens were in the female-A group except one mouse in each of the two male groups receiving 200 or 400 mg/kg AZT + 3,000 mg/kg TMP/SMX. Treatment with AZT alone did not result in small spleens in any mouse group. There was no consistent effect of folinic acid on the occurrence of small spleens.

### Thymus

Small thymuses were observed in mice in many of the treatment groups. Corresponding with the duration of treatment, small thymuses were most frequent among the female-A mice, less frequent among males, and least frequent among female-B mice. AZT given alone at either dose had no apparent effect on thymus size in any group. In every group of the female-A mice receiving TMP/SMX, small thymuses in some mice were observed. In the female-A group, administration of 200 or 400 mg/kg AZT + 2,000 or 3,000 mg/kg TMP/SMX caused increased incidences of small thymuses, as compared to mice dosed only with TMP/SMX at the respective doses. Among males, trends seen in response to treatment with the test compounds were similar to those seen in female-A mice, but the effects in males were generally less pronounced and less consistent. Small thymuses were observed among dosed female-B mice at incidences no greater than that observed in the control group.

Folinic acid administration had no consistent effect on the incidence of small thymuses.

### Thyroid Gland

Thyroid glands of many mice receiving TMP/SMX were observed to be enlarged at necropsy (Plate 1). In the two mice not receiving TMP/SMX in which thyroid gland enlargement was reported at necropsy, no microscopic correlate (such as hyperplasia of the follicular epithelium) was found on microscopic examination of the thyroid gland. Between the 1,000 and 2,000 mg/kg TMP/SMX groups, there was a dose-related effect on the incidence of thyroid gland enlargement; the maximum effect on the incidence of thyroid gland enlargement was reached at 2,000 mg/kg TMP/SMX. There was no evidence that administration of either folinic acid or AZT modified the effect of TMP/SMX in causing thyroid gland enlargement, except where treatment with some of the higher-dose combinations of AZT + TMP/SMX apparently contributed to a reduced incidence of thyroid gland enlargement by causing death before thyroid gland enlargement had time to develop.

## Histopathologic Observations

Microscopic examinations of compound-related lesions are summarized in Table 8 and shown in Plates 1 through 13. Suspected or actual target organs for microscopic lesions caused by the test chemicals included the bone marrow, liver, spleen, thymus, and thyroid gland.

Among female mouse groups, histopathologic examination of the bone marrow and liver was done only in some females that died early. However, the bone marrow and liver were routinely examined in all male mice. Therefore, the histopathologic effects of compound treatment on bone marrow and liver were more readily assessed in males than in females. The spleen, thymus, and thyroid gland were routinely examined in all male and female groups, irrespective of the time of death.

### Bone Marrow Lesions

Some cellular depletion (depletion of hematopoietic cells) of bone marrow was observed in all male groups receiving AZT and/or TMP/SMX (Table 9). Criteria for severity grades of bone marrow lesions are as follows:

Minimal severity - Depletion of approximately 5% or less of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region when available.

Mild severity - Depletion of approximately 6% to 20% of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region where available.

Moderate severity - Depletion of approximately 21% to 50% of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region where available.

Marked severity - Depletion of more than 50% of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region where available.

PLATE 1 Thyroid glands of two female Swiss (CD-1®) mice. Enlarged thyroid gland at left is from a female-A mouse given 2,000 mg TMP/SMX per kg body weight per day for 5 weeks by gavage. Normal thyroid gland at right is from a control female. H&E; 3.35×

PLATE 2 Thyroid gland of a female-A Swiss (CD-1®) mouse given 2,000 mg TMP/SMX per kg body weight per day for 5 weeks by gavage showing diffuse hyperplasia of follicular epithelium. H&E; 220× (same animal as pictured at left in Plate 1)

PLATE 3 Thyroid gland of a control female Swiss (CD-1®) mouse showing no lesions. H&E; 220× (same animal as pictured at right in Plate 1)

PLATE 4 Bone marrow of a control male Swiss (CD-1®) mouse showing no lesions. H&E; 220×

PLATE 5 Bone marrow of a male Swiss (CD-1®) mouse given 400 mg AZT/kg body weight per day for 3 weeks by gavage showing cellular depletion. H&E; 220×

PLATE 6 Bone marrow of a male Swiss (CD-1®) mouse given 400 mg AZT and 3,000 mg TMP/SMX per kg body weight per day for 3 weeks by gavage showing cellular depletion (advanced). H&E; 220×

PLATE 7 Liver of a control male Swiss (CD-1®) mouse showing no lesions. H&E; 220×

PLATE 8 Liver of a male Swiss (CD-1®) mouse given 400 mg AZT/kg body weight per day for 3 weeks by gavage showing centrilobular hypertrophy of hepatocytes. H&E; 220×

PLATE 9 Liver of a male Swiss (CD-1®) mouse given 400 mg AZT and 3,000 mg TMP/SMX per kg body weight per day for 3 weeks by gavage showing centrilobular hypertrophy of hepatocytes. H&E; 220×

PLATE 10 Liver of a male Swiss (CD-1®) mouse given 3,000 mg TMP/SMX per kg body weight per day for 3 weeks by gavage showing focal necrosis of hepatocytes. H&E; 440×

PLATE 11 Spleen of a control male Swiss (CD-1®) mouse showing no lesions. H&E; 220×

PLATE 12 Spleen of a male Swiss (CD-1®) mouse given 400 mg AZT/kg body weeks per day for 3 weeks by gavage showing increased hematopoietic cell proliferation. H&E; 220×

PLATE 13 Spleen of a male Swiss (CD-1®) mouse given 400 mg AZT and 3,000 mg TMP/SMX per kg body weight per day for 3 weeks by gavage showing decreased hematopoietic cell proliferation. H&E; 220×

PLATE 14 Photograph of cleft palate (right) of a Swiss (CD-1®) pup given 400 mg AZT and 3,000 mg TMP/SMX and 10 mg folinic acid per kg body weight per day by gavage. Normal palate (left) of control pup shown for comparison

TABLE 8 Summary of Compound-Related Lesions (Gross and Microscopic) in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Tissue | Magnification | Plate Number | Compound-Related Lesions
0 + 2,000 + 0, 0 + 0 + 0 | Thyroid gland of both mice | Gross photograph (3 35x) | 1 | Thyroid of DF169 (on left) is enlarged; thyroid of VF91 (on right) is normal
0 + 2,000 + 0 | Thyroid gland | 220x | 2 | Hyperplasia, diffuse, follicle, epithelium
0 + 0 + 0 | Thyroid gland | 220x | 3 | None
0 + 0 + 0 | Bone marrow | 220x | 4 | None
400 + 0 + 0 | Bone marrow | 220x | 5 | Cellular depletion
400 + 3,000 + 0 | Bone marrow | 220x | 6 | Cellular depletion (advanced)
0 + 0 + 0 | Liver | 220x | 7 | None
400 + 0 + 0 | Liver | 220x | 8 | Hypertrophy, hepatocyte, centrilobular
400 + 3,000 + 0 | Liver | 220x | 9 | Hypertrophy, hepatocyte, centrilobular
0 + 3,000 + 0 | Liver | 440x | 10 | Necrosis, focal, hepatocyte
0 + 0 + 0 | Spleen | 220x | 11 | None
400 + 0 + 0 | Spleen | 220x | 12 | Increased hematopoietic cell proliferation
400 + 3,000 + 0 | Spleen | 220x | 13 | Decreased hematopoietic cell proliferation

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

Cellular depletion of bone marrow occurred in 100% of male mice receiving AZT, regardless of any other test compound administered along with AZT. The highest dose of 400 mg/kg AZT resulted in a greater mean severity of cellular depletion of bone marrow, as compared to the effect of the lowest dose of 200 mg/kg AZT.

In males, TMP/SMX caused dose-related increases in the incidence and severity of cellular depletion of bone marrow, and these increases were of lesser magnitude than those in male mice receiving only AZT. Treatment of males with both AZT and TMP/SMX had a much greater effect on the severity of cellular depletion of bone marrow as compared to the effect of AZT or TMP/SMX alone.

TABLE 9 Incidence and Mean Severity of Cellular Depletion of Bone Marrow in Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Group Incidence | Mean Severity^b^
0 + 0 + 0 | 0/10 | —
0 + 0 + 10 | 0/10 | —
200 + 0 + 0 | 10/10 | 1.6
400 + 0 + 0 | 10/10 | 2.0
400 + 0 + 10 | 10/10 | 1.4
0 + 1,000 + 0 | 4/10 | 0.4
0 + 2,000 + 0 | 6/10 | 0.7
0 + 2,000 + 10 | 7/10 | 0.8
0 + 3,000 + 0 | 7/10 | 1.0
0 + 3,000 + 10 | 7/10 | 0.7
200 + 1,000 + 0 | 10/10 | 2.2
400 + 1,000 + 0 | 10/10 | 2.8
200 + 2,000 + 0 | 10/10 | 2.0
400 + 2,000 + 0 | 10/10 | 2.8
400 + 2,000 + 10 | 10/10 | 3.4
200 + 3,000 + 0 | 10/10 | 2.7
400 + 3,000 + 0 | 9/9 | 3.6

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

b Mean severity is based on numerical scale of. 1=minimal, 2=mild, 3=moderate, 4=marked

Regression analysis of mean severity grades for bone marrow depletion in male mice indicated no interaction effect (Figure 12) between AZT and TMP/SMX. The dose response, as indicated by similar positive slopes (+0.004 to +0.006), appears to be the result of an additive effect of AZT and TMP/SMX.

In the female-A group, 400 mg/kg AZT + 3,000 mg/kg TMP/SMX caused marked severity (mean severity of 4.0) of cellular depletion of bone marrow. Treatment with folinic acid had no discernible histopathologic effect on bone marrow in males or females.

FIGURE 12 Severity of Cellular Depletion of Bone Marrow versus Dose for Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

### Liver Lesions

The principal test compound-related lesion of the liver was hypertrophy of hepatocytes in the centrilobular areas (Table 10). The diagnosis of hypertrophy was applied to livers in which most of the centrilobular hepatocytes were larger, with larger nuclei, as compared to hepatocytes in the periportal areas. Criteria for severity grades for hepatocyte hypertrophy were as follows:

Minimal severity - Average size of hepatocytes and hepatocyte nuclei are typically larger (estimated 1½ times average diameter) in centrilobular regions as compared to hepatocytes in other parts of the liver lobules. Staining intensity of hepatocytes is usually similar throughout liver lobule. Homogeneity of cytoplasm (degree of cytoplasmic vacuolization) of hepatocytes in centrilobular regions may differ in comparison with hepatocytes in other parts of the liver lobules.

Mild severity - Average size of hepatocytes and hepatocyte nuclei are typically larger (about 1½ to 2 times average diameter) in centrilobular regions as compared to hepatocytes in other parts of the liver lobules. Staining intensity of hepatocytes is usually similar throughout liver lobule. Homogeneity of cytoplasm (degree of cytoplasmic vacuolization) may differ in comparison with hepatocytes in other parts of the liver lobules.

Moderate severity - Average size of hepatocytes and hepatocyte nuclei are typically much larger (about 2 times average diameter or greater) in centrilobular regions as compared to hepatocytes in other parts of the liver lobules. Also, hepatocytes in centrilobular regions usually show distinct contrasts in homogeneity of cytoplasm (degree of cytoplasmic vacuolization) and/or staining intensity of cytoplasm as compared to hepatocytes elsewhere in liver lobules.

Relatively larger hepatocytes in the centrilobular areas, as compared to the periportal areas of the same liver, may be seen in toxicity studies in some normal control mice. This change was diagnosed in one of the control mice in this study. In all male groups receiving AZT and TMP/SMX, there were increased incidences and mean severity of hepatocyte hypertrophy in comparison with the control group, and those effects tended to be dose related. There was also a dose related increase in the incidence and mean severity of hepatocyte hypertrophy in male mice administered TMP/SMX alone.

Treatment with AZT alone also caused a dose-related increase in hepatocyte hypertrophy, which was of a lesser severity than that caused by treatment with TMP/SMX alone.

Male groups receiving various combinations of AZT and TMP/SMX had increased incidences and severity of hepatocyte hypertrophy when compared to the control group. Statistical analysis was performed on the mean severity grades (Table 11 and Figure 13) to determine if interaction occurred when the compounds were administered in combination.

TABLE 10 Incidence and Mean Severity of Hepatocyte Hypertrophy in Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Group Incidence | Mean Severity^b^
0 + 0 + 0 | 1/10 | 0 1
0 + 0 + 10 | 1/10 | 0 1
200 + 0 + 0 | 3/10 | 0 4
400 + 0 + 0 | 6/10 | 1 0
400 + 0 + 10 | 4/10 | 0 7
0 + 1,000 + 0 | 4/10 | 0 8
0 + 2,000 + 0 | 8/10 | 1 2
0 + 2,000 + 10 | 8/10 | 1 7
0 + 3,000 + 0 | 9/10 | 2 5
0 + 3,000 + 10 | 10/10 | 2 3
200 + 1,000 + 0 | 4/10 | 0 6
400 + 1,000 + 0 | 5/10 | 1 2
200 + 2,000 + 0 | 10/10 | 2 4
400 + 2,000 + 0 | 10/10 | 2 0
400 + 2,000 + 10 | 7/10 | 1 1
200 + 3,000 + 0 | 10/10 | 2 0
400 + 3,000 + 0 | 8/10 | 2 0

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

b Mean severity is based on numerical scale of 1=minimal, 2=mild, 3=moderate, 4=marked

TABLE 11 Statistical Analysis of Mean Severity of Hepatocyte Hypertrophy in Male Mice Administered Combinations of AZT and TMP/SMX in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice^a^

AZT (mg/kg) | Number | TMP/SMX (mg/kg)
AZT (mg/kg) | Number | 0 | 1,000 | 2,000 | 3,000
0 | 10 | 0.10 ± 0.10 | 0.80 ± 0.33 | 1.20 ± 0.29^**^ | 2.50 ± 0.31^**^
200 | 10 | 0.40 ± 0.22 | 0.70 ± 0.30 | 2.40 ± 0.22^**^ | 2.00 ± 0.00^**^
400 | 10 | 1.00 ± 0.30 | 1.20 ± 0.42 | 2.00 ± 0.15^*^ | 2.00 ± 0.37^*^

* Significantly different from the control group (P≤0.05) by Williams’ or Dunnett’s test

** P≤0.01

a Data are presented as mean ± standard error. Mean severity is based on numerical scale of: 1=minimal, 2=mild, 3=moderate, 4=marked

FIGURE 13 Severity of Hypertrophy of Centrilobular Hepatocytes versus Dose for Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

Administration of AZT alone resulted in a minor degree of hepatocyte hypertrophy that was not statistically significant. Administration of 2,000 or 3,000 mg/kg TMP/SMX alone resulted in significant (P≤0.01) hepatocyte hypertrophy. When administered in combination, interaction occurred, as AZT appeared to diminish the effects of TMP/SMX, especially in groups receiving the highest combinations.

Administration of folinic acid appeared to offer some protection against the effect of AZT in the liver. The mean severity grade for hepatocyte hypertrophy was lowest in the group receiving 400 mg/kg AZT + 10 mg/kg folinic acid, and the interaction was statistically significant (P=0.0314) (Table 12).

Among female groups, data on microscopic examination of livers was insufficient to allow meaningful comparisons of the occurrence of hepatocyte hypertrophy.

Focal necrosis of hepatocytes generally occurred at a very low incidence in all male groups, including the control group. The initiating agent of the focal necrosis may have been some infectious microorganism of low pathogenicity.

In most instances, the liver lesion diagnosed as focal necrosis consisted of one to a very few hepatocytes undergoing nuclear pyknosis and fragmentation with shrinkage and hyalinization of cytoplasm and, as the necrotic process advanced, some fragmentation of affected hepatocytes. Typically, there was a localized infiltration of mixed inflammatory cells adjacent to the necrotic cell remnants. A minor portion of lesions diagnosed as focal necrosis consisted of more extensive focal areas of coagulative necrosis of hepatocytes, in which major portions of affected liver lobules consisted of well-defined areas of hyalinized hepatocytes with nuclei in various stages of disintegration or with nuclei missing entirely. Often the borders of such lesions contained mixed inflammatory cells and fibroblasts. Criteria for severity grades were as follows:

Minimal severity - The presence of focal necrosis of hepatocytes in which the size or number of the necrotic foci is insufficient to warrant a severity grade of mild.

Mild severity - (a) One or more of the necrotic foci are of a diameter approximately equivalent to ½ or more of the diameter of a typical liver lobule, or (b) multiple necrotic foci (usually more than five) are present in the liver sections.

TABLE 12 Statistical Analysis of Mean Severity of Hepatocyte Hypertrophy in Male Mice Given AZT and Folinic Acid in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice^a^

AZT (mg/kg) | Folinic Acid (mg/kg)
AZT (mg/kg) | 0 | 10
0 | 1 15 ± 0 19 (40) | 1.37 ± 0.23 (30)
400 | 1.55 ± 0 17 (40) | 0.90 ± 0.20 (20)^*^

* Significantly different from the control group (P≤0 05) by Williams’ or Dunnett’s test

a Data are presented as mean ± standard error. Number of mice per group is given in parentheses Mean severity is based on numerical scale of: 1=minimal, 2=mild, 3=moderate, 4=marked

As compared to the control group, there appeared to be a slight increase in the incidence and severity of focal necrosis of hepatocytes in male mice in groups receiving 3,000 mg/kg TMP/SMX, including those groups also receiving AZT and/or folinic acid. Folinic acid caused an apparent reduction in the incidence or severity of liver necrosis caused by 3,000 mg/kg TMP/SMX.

Data on the occurrence of focal necrosis of hepatocytes in females were inconclusive.

### Spleen Lesions

The spleen was examined routinely in males and females as a possible target organ. Hematopoietic cell proliferation was diagnosed in all spleens; some splenic hematopoiesis normally occurs in the spleen of normal mice. Comparison of the splenic lesion among groups was by necessity a comparison only of mean severity, inasmuch as the incidence was 100% within every group. Criteria for severity grades for hematopoietic cell proliferation follow:

Minimal severity - Approximately 15% or less of the red pulp is occupied by hematopoietic cells of the types normally found in bone marrow.

Mild severity - Approximately 16% to 50% of the red pulp is occupied by hematopoietic cells of the types normally found in bone marrow.

Moderate severity - Approximately 51% to 90% of the red pulp is occupied by hematopoietic cells of the types normally found in bone marrow.

Marked severity - Approximately 91% to 100% of the red pulp is occupied by hematopoietic cells of the types normally found in bone marrow.

As compared to the control group, TMP/SMX given alone at any dose concentration to males caused an increase in the mean severity of splenic hematopoiesis (Table 13). AZT given alone at the highest dose (400 mg/kg AZT) also caused an increase in splenic hematopoiesis. However, AZT administered to males in any combination with TMP/SMX appeared to cause a slight reduction in the severity of splenic hematopoiesis in comparison with the control group.

TABLE 13 Severity of Splenic Hematopoiesis in Male Mice in the Reproductive, Developmental, and Genera] Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Mean Severity^b^
0 + 0 + 0 | 1.8
0 + 0 + 10 | 1.8
200 + 0 + 0 | 1.8
400 + 0 + 0 | 2.2
400 + 0 + 10 | 1.8
0 + 1,000 + 0 | 2.2
0 + 2,000 + 0 | 2.5
0 + 2,000 + 10 | 2.3
0 + 3,000 + 0 | 2.4
0 + 3,000 + 10 | 2.4
200 + 1,000 + 0 | 1.7
400 + 1,000 + 0 | 1.2
200 + 2,000 + 0 | 1.5
400 + 2,000 + 0 | 1.4
400 + 2,000 + 10 | 1.1
200 + 3,000 + 0 | 1.5
400 + 3,000 + 0 | 1.3

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

b Mean severity is based on numerical scale of: 1=minimal, 2=mild, 3=moderate, 4=marked

Among female-B mice, in which dosing occurred for a period of 10 days and ceased about 9 days prior to sacrifice, the degree of severity of splenic hematopoiesis in comparison with the control group was greater in the group administered 400 mg/kg AZT alone and in the groups receiving 400 mg/kg AZT + 1,000, 2,000, or 3,000 mg/kg TMP/SMX.

Apparently, treatment of female-B mice with AZT at the highest dose, with or without simultaneous treatment with TMP/SMX, caused a slight increase in the severity of splenic hematopoiesis.

The results were different with female-A mice (Table 14), which were dosed continuously until one day prior to sacrifice, for a total dosing period of 27 to 31 consecutive days. Among female-A mice, in comparison with the control group, all groups receiving AZT and/or TMP/SMX had a reduced severity of splenic hematopoiesis. The greatest reductions were seen in female-A mice receiving the highest dose combinations of AZT with TMP/SMX.

TABLE 14 Mean Severity of Splenic Hematopoiesis in Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Mean Severity^b^
0 + 0 + 0 | 2.7
0 + 0 + 10 | 2.1
200 + 0 + 0 | 2.4
400 + 0 + 0 | 2.4
400 + 0 + 10 | 2.3
0 + 1,000 + 0 | 2.3
0 + 2,000 + 0 | 2.4
0 + 2,000 + 10 | 2.6
0 + 3,000 + 0 | 2.4
0 + 3,000 + 10 | 2 3
200 + 1,000 + 0 | 1.9
400 + 1,000 + 0 | 1 5
200 + 2,000 + 0 | 1 6
400 + 2,000 + 0 | 1.5
400 + 2,000 + 10 | 1 7
200 + 3,000 + 0 | 1 4
400 + 3,000 + 0 | 1 3

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

b Mean severity is based on numerical scale of. 1=minimal, 2=mild, 3=moderate, 4=marked

A statistical analysts of mean severity grades for splenic hematopmests reveals promment differences between female-A and female-B mice (Table 15). Although complicated by pregnancy, the differences were believed to reflect the duration of treatment with the test compounds. Female-A mice were dosed continuously for approximately 30 days until the day prior to necropsy. Female-B mice were dosed for approximately 10 days followed by a short recovery period prior to necropsy. Trends in hematopoietic cell activity in male mice dosed for approximately 20 days were Similar to those in female-A mice dosed for approximately 30 days.

TABLE 15 Statistical Analysis of Mean Severity of Hematopoietic Cell Proliferation in the Spleen in Swiss (CD-1®) Mice Administered Combinations of AZT and TMP/SMX in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid^a^

AZT (mg/kg) | TMP/SMX (mg/kg)
AZT (mg/kg) | 0 | 1,000 | 2,000 | 3,000
Male Mice
n | 10 | 10 | 10 | 10
0 | 1 80 ± 0 20 | 2 20 ± 0 13 | 2 50 ± 0 17^*^ | 2 40 ± 0 16^*^
200 | 1 80 ± 0 25 | 1 70 ± 0 26 | 1 50 ± 0 17 | 1 50 ± 0 17
400 | 2 20 ± 0 20 | 1 20 ± 0 13^**^ | 1 40 ± 0 16^**^ | 1 30 ± 0 15^**^
Female-A Mice
n | 20 | 20 | 20 | 20
0 | 2 70 ± 0 11 | 2 30 ± 0 11^*^ | 2 40 ± 0 11 | 2 39 ± 0 12^b^
200 | 2 40 ± 0 15 | 1 90 ± 0 18^*^ | 1 60 ± 0 15^**^ | 1 40 ± 0 13^**^
400 | 2 35 ± 0 13 | 1 50 ± 0 15^**^ | 1 45 ± 0 15^**^ | 1 25 ± 0 10^**^
Female-B Mice
n | 14 | 15 | 16 | 14
0 | 2 79 ± 0 11 | 2 93 ± 0 15 | 2 27 ± 0 12^*^,^c^ | 2 43 ± 0 14^*^
200 | 2 64 ± 0 13 | 3 13 ± 0 13^*^,^b^ | 3 06 ± 0 11 | 2 79 ± 0 19
400 | 3 00 ± 0 00^b^ | 3 27 + 0 15 | 2 88 + 0 09 | 3 19 + 0 23^b^

* Significantly different from the control group (P≤0 05) by Williams’ or Dunnett’s test

** P≤0 01

a Data are presented as mean ± standard error Mean severity is based on numerical scale of 1=minimal, 2=mild, 3=moderate, 4=marked

b n=16

c n=15

Regression analysis of mean severity grades for spleen hematopoietic activity in males (Figure 14) indicated a significant interaction between AZT and TMP/SMX. Administration of AZT alone resulted in increased hematopoietic activity. Although not statistically significant, the corresponding slope was positive (+0.001). When the compounds were administered in combination, statistically significant declines in hematopoietic activity were evident, and the corresponding negative slope (−0.003) indicated significant interaction between AZT and TMP/SMX.

Regression analysis of mean severity grades for hematopoietic activity in the spleen of female-A mice (Figure 15) was probably complicated somewhat by pregnancy; however, a compound interaction similar to that in males was evident.

FIGURE 14 Severity of Splenic Hematopoiesis versus Dose for Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

FIGURE 15 Severity of Splenic Hematopoiesis versus Dose for Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

Statistically significant declines in hematopoietic activity in the spleen were evident in all female-A groups receiving the test compound combinations, and the dose response, as indicated by the steep negative slope (−0.0024), indicate interaction between AZT and TMP/SMX. Although not statistically significant and in contrast to the male and female-A groups, female-B groups receiving the highest combinations had increased hematopoietic activity that was believed to reflect the short duration of treatment (10 days).

The diminished splenic hematopoiesis in male and female-A mice caused by treatment with AZT + TMP/SMX combinations corresponds with the increased severity of cellular depletion of bone marrow observed in males receiving AZT + TMP/SMX combinations.

Administration of folinic acid had no discernible effect on spleen morphology.

### Thymus Lesions

In general, there was a distinct increase in the incidence and severity of thymic atrophy (depletion of cells, mainly lymphocytes) in male and female-A mice receiving AZT and/or TMP/SMX as compared to the control groups.

In the milder forms, thymic atrophy was recognized as a thinning of the thymic cortex mainly due to loss of small lymphocytes. There was accentuation of the normal process of necrobiosis of lymphocytes, with the presence of apparently increased numbers of macrophages, focally distributed, which contained remnants of necrotic lymphocytes including nuclear debris. In the more severe forms of thymic atrophy, there was complete or almost complete loss of identifiable cortex, due principally to loss of lymphocytes. The remaining thymic tissue consisted mainly of some thymic epithelium and stroma, including vascular endothelium, reticular tissue, and fibrous tissue, with some macrophages and a paucity of large and small lymphocytes. Criteria for severity grades of thymic atrophy follow:

Minimal severity - A barely detectable reduction in viable lymphocytes in the cortex. Basic architecture of thymus, including clear distinction between cortex and medulla, is preserved.

Mild severity - A readily apparent reduction in viable lymphocytes in the cortex, but distinction between cortex and medulla is usually preserved.

Moderate severity - Lymphocytes fairly plentiful in thymus, but sufficient lymphocytes depleted from cortex such that concentration of lymphocytes in cortex and medulla is similar, thereby causing blurring of the distinction between cortex and medulla.

Marked severity - Substance of thymic tissue (cortex and medulla) greatly diminished, including lymphocytic, other mesenchymal, and epithelial components. Poor distinction between cortical and medullary zones of thymus.

As compared to the control group, either AZT or TMP/SMX given alone caused dose-related increases in the incidence and severity of thymic atrophy in males (Table 16). Likewise, the AZT + TMP/SMX combinations caused generally dose-related and even greater increases in the incidence and mean severity of thymic atrophy in males.

TABLE 16 Incidence and Mean Severity of Thymic Atrophy in Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Group Incidence | Mean Severity^b^
0 + 0 + 0 | 0/10 | —
0 + 0 + 10 | 0/9 | —
200 + 0 + 0 | 4/10 | 0.5
400 + 0 + 0 | 8/10 | 0.9
400 + 0 + 10 | 5/10 | 0.6
0 + 1,000 + 0 | 1/10 | 0.1
0 + 2,000 + 0 | 2/10 | 0.4
0 + 2,000 + 10 | 5/10 | 0.6
0 + 3,000 + 0 | 3/10 | 0.5
0 + 3,000 + 10 | 1/10 | 0.1
200 + 1,000 + 0 | 6/10 | 1.1
400 + 1,000 + 0 | 9/10 | 1.0
200 + 2,000 + 0 | 10/10 | 2.1
400 + 2,000 + 0 | 10/10 | 2.1
400 + 2,000 + 10 | 9/9 | 2.6
200 + 3,000 + 0 | 10/10 | 2.4
400 + 3,000 + 0 | 8/8 | 3.3

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

b Mean severity is based on numerical scale of: 1=minimal, 2=mild, 3=moderate, 4=marked

In female-A mice, AZT alone had no detectable effect at either dose on the incidence or severity of thymic atrophy (Table 17) as compared to the control group. TMP/SMX alone or in combination with AZT caused an increase in the severity of thymic atrophy, which was especially severe at the highest dose combinations of AZT and TMP/SMX. In general, thymic atrophy was more severe in female-A mice than in male mice.

TABLE 17 Incidence and Mean Severity of Thymic Atrophy in Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Group Incidence | Mean Severity^b^
0 + 0 + 0 | 15/20 | 1.6
0 + 0 + 10 | 17/20 | 1.6
200 + 0 + 0 | 13/20 | 1.0
400 + 0 + 0 | 15/18 | 1.3
400 + 0 + 10 | 18/20 | 1.7
0 + 1,000 + 0 | 18/18 | 1.8
0 + 2,000 + 0 | 18/18 | 2.6
0 + 2,000 + 10 | 18/19 | 1.7
0 + 3,000 + 0 | 15/17 | 2.1
0 + 3,000 + 10 | 14/19 | 1.8
200 + 1,000 + 0 | 20/20 | 2.0
400 + 1,000 + 0 | 19/19 | 3.3
200 + 2,000 + 0 | 18/18 | 2.8
400 + 2,000 + 0 | 20/20 | 3.0
400 + 2,000 + 10 | 18/18 | 3.3
200 + 3,000 + 0 | 18/18 | 3.6
400 + 3,000 + 0 | 19/19 | 3.6

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

b Mean severity is based on numerical scale of: 1=minimal, 2=mild, 3=moderate, 4=marked

Among female-B mice, no consistent trend in the severity of thymic atrophy due to treatment with AZT or TMP/SMX could be discerned (Table 18), except that in the highest group (400 mg/kg AZT + 3,000 mg/kg TMP/SMX), there was an increase in the incidence (15/16) and mean severity (1.8) as compared to the control group (incidence, 10/13, and mean severity, 0.8). Evaluation of the data in Table 18 reveals, again, a prominent difference between female-B mice dosed for approximately 10 days when compared to male and female-A mice dosed for approximately 20 and 30 days, respectively.

For the male mice, regression analysis of the mean severity grades for thymic atrophy (Figure 16) indicated that a test compound interaction was present that potentiated the development of thymic atrophy. The effects were more than additive.

TABLE 18 Statistical Analysis of Mean Severity of Thymic Atrophy in Swiss (CD-1®) Mice Administered Combinations of AZT and TMP/SMX in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid^a^

AZT (mg/kg) | TMP/SMX (mg/kg)
AZT (mg/kg) | 0 | 1,000 | 2,000 | 3,000
Male Mice
n | 10 | 10 | 10 | 10
0 | 0.00 ± 0.00 | 0.10 ± 0.10 | 0.40 ± 0.31 | 0.50 ± 0.31
200 | 0.50 ± 0.22 | 1.10 ± 0.38 | 2.10 ± 0.23^**^,^b^ | 2.40 ± 0.27^**^
400 | 0.90 ± 0.18 | 1.00 ± 0.15 | 2.10 ± 0.28^**^ | 3.25 ± 0.25^**^,^c^
Female-A Mice
n | 20 | 20 | 18 | 16
0 | 1.55 ± 0.23 | 1.83 ± 0.20^d^ | 2.61 ± 0.16^**^ | 2.06 ± 0.31^e^
200 | 0.95 ± 0.18 | 1.95 ± 0.17^**^ | 2.83 ± 0.15^**^ | 3.56 ± 0.12^**^
400 | 1.28 ± 0.19^d^ | 3.26 ± 0.15^**^,^f^ | 2.95 ± 0.05^**^,^b^ | 3.63 ± 0.11^**^,^f^
Female-B Mice
n | 13 | 13 | 16 | 14
0 | 0.77 ± 0.12 | 1.00 ± 0.30 | 0.53 ± 0.22^g^ | 0.43 ± 0.23
200 | 0.93 ± 0.16^d^ | 0.21 ± 0.11^**^,^h^ | 0.38 ± 0.13^**^ | 0.21 ± 0.21^**^
400 | 0.63 ± 0.15^i^ | 0.53 ± 0.17^g^ | 0.81 ± 0.14 | 1.75 ± 0.27^**^,^i^

* Significantly different from the control group (P≤0.05) by Williams’ or Dunnett’s test

** P≤0.01

a Data are presented as mean ± standard error. Mean severity is based on numerical scale of: 1=minimal, 2=mild, 3=moderate, 4=marked

b n=20

c n=8

d n=18

e n=17

f n=19

g n=15

h n=14

i n=16

FIGURE 16 Severity of Thymic Atrophy versus Dose for Male Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

For the female-A mice, the stress of pregnancy complicated the statistical analysis of the thymic lesions; however, similar trends indicative of test compound interaction were evident (Figure 17). Administration of AZT alone did not produce thymic atrophy in female-A mice, and the corresponding slope is negative (−0.0007). Administration of combinations of AZT and TMP/SMX resulted in statistically significant elevations (P≤0.01) in all treatment groups receiving the combinations. Test compound interaction was most evident in the group receiving the highest doses of each compound, and the corresponding dose response had a positive slope (+0.0039).

For the female-B mice dosed for approximately 10 days, thymic atrophy was statistically significant (P≤0.01) only in the group receiving the highest combinations of AZT and TMP/SMX.

Thymic atrophy was a relatively common occurrence in the control groups and was more severe in the female-A control group than in the female-B control group. Female-A mice were sacrificed near the end of the gestation period. There was a strong association between the number of fetuses in the uterus of each female-A control mouse and the presence and severity of thymic atrophy in the same individual (Table 19).

TABLE 19 Association Between the Occurrence of Thymic Atrophy and the Number of Fetuses in Female-A Control Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Animal Number | Severity | Number of Fetuses in Uterus
86 | 0 | 0
87 | 2 | 14
88 | 2 | 10
89 | 2 | 14
90 | 2 | 14
91 | 2 | 12
92 | 1 | 0
93 | 0 | 0
94 | 2 | 13
95 | 3 | 10
511 | 0 | 3
512 | 2 | 12
513 | 1 | 7
514 | 2 | 8
515 | 2 | 14
516^a^ | 3 | 8
517 | 3 | 13
518 | 0 | 0
519 | 2 | 10
520 | 0 | 0

a Animal 516 delivered.

FIGURE 17 Severity of Thymic Atrophy versus Dose for Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid

A similar but less pronounced correlation was seen in the female-B control group between the number of pups nursing each female and the presence of thymic atrophy in the dam. The occurrence of thymic atrophy in the control group must be considered in interpreting the importance of thymic atrophy in the dosed female groups. No effect of folinic acid on the incidence or severity of thymic atrophy was discernible in males or females.

### Thyroid Gland Lesions

Diffuse hyperplasia of the follicular epithelium of the thyroid gland was seen in most of the mice receiving TMP/SMX. Often, the hyperplasia was of sufficient degree to be grossly observable at necropsy as thyroid gland enlargement. In comparison with thyroid glands in the control groups, follicular epithelium of affected thyroid glands was thicker, and individual epithelial cells were enlarged, with larger nuclei. Instead of being low cuboidal or squamous (as in normal thyroid glands of control animals), the follicular epithelial cells in hyperplastic thyroid glands were generally cuboidal or low columnar in shape. The nuclei and cytoplasm of dosed mice with enlarged thyroid glands typically were finely vacuolated. The colloid in each affected follicle in comparison with colloid of thyroid glands of normal control mice was typically less dense and less homogeneous. Criteria for severity grades of thyroid gland hyperplasia follow:

Minimal severity - Majority of follicular epithelial cells are low cuboidal. Colloid has about same color and texture as in normal gland.

Mild severity - Majority of follicular epithelial cells are cuboidal or low cuboidal (about equal distribution of cuboidal and low cuboidal). Colloid shows some rarefaction and vacuolization.

Moderate severity - Majority of follicular epithelial cells are cuboidal but are only rarely thrown up into folds or multilayered papillary projections. Colloid in essentially all follicles is rarefied and vacuolated.

Marked severity - Majority of follicular epithelial cells are cuboidal, and are frequently thrown up in folds or multilayered papillary projections. Follicles contain only sparse remnants of colloid.

AZT given alone at either dose did not cause thyroid gland hyperplasia in any male or female mice. However, most mice in every group (male or female) receiving TMP/SMX, with or without the addition of AZT, developed thyroid gland hyperplasia.

There appeared to be a slight increase in the mean severity of thyroid gland hyperplasia in males with increasing doses of TMP/SMX; however, this was not a consistent trend.

In female-A mice, the severities of thyroid gland hyperplasia (Table 20) appeared to depend mainly on the dosage of TMP/SMX, regardless of whether AZT was also administered. The higher doses of TMP/SMX had similar effects on the severities of thyroid gland hyperplasia but caused somewhat greater mean severities of thyroid gland hyperplasia than that observed at the lowest dose (1,000 mg/kg) of TMP/SMX.

Incidences and severities of thyroid gland hyperplasia in female-B mice (Table 20) were considerably lower than among female-A mice, which were dosed over a longer time period. The addition of 400 mg/kg AZT to the 3,000 mg/kg TMP/SMX dose caused an apparent increase in the incidence and severity of thyroid gland hyperplasia.

No meaningful effect of folinic acid on the occurrence of thyroid gland hyperplasia was observed in this study.

TABLE 20 Incidence and Mean Severity of Thyroid Gland Hyperplasia in Female Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1^®^) Mice^a^

Dose | Female-A Mice | | Female-B Mice
| Group Incidence | Mean Severity | Group Incidence | Mean Severity
0 + 0 + 0 | 0/20 | — | 0/14 | —
0 + 0 + 10 | 0/20 | — | 0/14 | —
200 + 0 + 0 | 0/20 | — | 0/13 | —
400 + 0 + 0 | 0/20 | — | 0/16 | —
400 + 0 + 10 | 0/19 | — | 0/16 | —
0 + 1,000 + 0 | 19/20 | 2 5 | 5/15 | 0 3
0 + 2,000 + 0 | 20/20 | 3 0 | 4/14 | 0 3
0 + 2,000 + 10 | 17/17 | 3 0 | 8/15 | 0 7
0 + 3,000 + 0 | 19/19 | 3 0 | 7/14 | 0 6
0 + 3,000 + 10 | 18/18 | 3 0 | 7/15 | 0 9
200 + 1,000 + 0 | 20/20 | 2 5 | 5/16 | 0 4
400 + 1,000 + 0 | 20/20 | 2 9 | 5/15 | 0 3
200 + 2,000 + 0 | 19/19 | 3 0 | 6/16 | 0 4
400 + 2,000 + 0 | 20/20 | 3 0 | 8/16 | 0 6
400 + 2,000 + 10 | 19/19 | 3 0 | 7/14 | 0 9
200 + 3,000 + 0 | 14/14 | 3 0 | 5/14 | 0 5
400 + 3,000 + 0 | 13/14 | 2 8 | 13/15 | 1 5

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day) Mean severity is based on numerical scale of 1=minimal, 2=mild, 3=moderate, 4=marked

A remarkable similarity was found (Table 21) in the mean severity grades of males and female-A mice dosed for approximately 20 and 30 days, respectively. In contrast, the mean severity grades in female-B groups dosed for approximately 10 days, although statistically significant, were considerably lower. This difference emphasizes the impact of duration of treatment on the development of the lesion.

Chronic inflammation of the thyroid gland, which was focally distributed or involved the wall and adventitia of blood vessels, was seen in 15 mice with hyperplastic thyroid glands. All 15 mice received either 1,000, 2,000, or 3,000 mg/kg TMP/SMX, usually without AZT. All affected mice were in the female-B group; none were in the female-A group. The degree of severity was not affected by increasing doses of TMP/SMX.

No influence of folinic acid on the incidence or severity of inflammation of the thyroid gland was discernible.

TABLE 21 Statistical Analysis of Mean Severity of Hyperplasia of the Thyroid Gland in Swiss (CD-1^®^) Mice Administered TMP/SMX in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid^a^

Group | TMP/SMX^b^ (mg/kg)
| 0 | 1,000 | 2,000 | 3,000
Male Mice
n | 29 | 30 | 30 | 28
Mean severity | 0.00 ± 0.00 | 2.50 ± 0 12^**^ | 2.93 ± 0.07^**^ | 2.93 ±0 11
Female-A Mice
n | 60 | 60 | 59 | 47
Mean severity | 0.00 ± 0.00 | 2 58 ± 0 09^**^ | 3 00 + 0 00^**^ | 2.94 ± 0.06^**^
Female-B Mice
n | 43 | 46 | 46 | 43
Mean severity | 0.00 ± 0.00 | 0.37 ± 0 08^**^ | 0.44 ± 0.09^**^ | 0.88 + 0.14^**^

** Significantly different from the control group (P≤0 01) by Williams’ or Dunnett’s test

a Data are presented as mean ± standard error Mean severity is based on numerical scale of 1=minimal, 2=mild, 3=moderate, 4=marked

b Since there were no AZT effects, data for all groups with the same TMP/SMX dose were collapsed for statistical evaluation

### Other Lesions

Occasional lesions not caused by administered test compounds occurred with random distribution in the various groups of males and females. The only neoplasms observed in the study were a malignant lymphoma of the thymus and an alveolar/bronchiolar adenoma.

Calluses of the rib or vertebra in some mice were attributed to accidental trauma associated with the gavage procedure. Also, inflammation or perforation of the esophagus in a few mice was attributed to the gavage procedure.

Inflammatory changes and/or foreign bodies in the lungs of a few mice, inflammation or foreign bodies in skin or subcutaneous tissue, and lesions of the mucosa or epithelium of the stomach were all attributed to the gavage procedure.

## Sperm Endpoints

AZT (200 or 400 mg/kg) and TMP/SMX (2,000 or 3,000 mg/kg) caused decreased sperm motility (Table B1); coadministration of AZT and TMP/SMX further decreased sperm motility. Left testis weight, spermatid heads per testis, and average spermatid counts (Table B1) were significantly decreased by all doses of TMP/SMX alone. Folinic acid did not appear to alleviate or diminish the parameters examined. Left caudal weights (Table B1) showed a significant interaction of all three chemicals, indicating that the dose response relationship of AZT differs across doses of the other two chemicals, TMP/SMX and folinic acid.

## Natural Delivery Data

The administration of AZT, TMP/SMX, or folinic acid alone or in any combination did not affect the incidence of pregnancy in the female-B mice (Table 22). The lack of pregnancy in the female-B mice dosed with 400 mg/kg AZT + 1,000 mg/kg TMP/SMX was not considered to be test article related because no effects on pregnancy were noted in dose groups receiving high doses of AZT, TMP/SMX, or both. The number of litters delivered was significantly decreased (P≤0.01) in the groups that received ≥ 2,000 mg/kg TMP/SMX in combination with 200 or 400 mg/kg AZT. In addition, the 200 + 1,000 + 0 mg/kg group also had a significantly reduced number of litters. The combination of AZT and TMP/SMX, with or without folinic acid, appeared to potentiate the effect of TMP/SMX; this is supported by the presence of smaller decreases in numbers of litters of groups that received 2,000 or 3,000 mg/kg TMP/SMX alone.

TABLE 22 Occurrence of Pregnancy in Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Number Assigned | Number Pregnant (%) | Number Delivered (%)
0 + 0 + 0 | 14 | 14 (100.0%) | 14 (100.0%)
0 + 0 + 10 | 14 | 14 (100.0%) | 13 (92.8%)
200 + 0 + 0 | 14 | 13 (92.8%) | 13 (100.0%)
400 + 0 + 0 | 16 | 15 (93.8%) | 14 (93.3%)
400 + 0 + 10 | 16 | 14 (87.5%) | 11 (78.6%)
0 + 1,000 + 0 | 15 | 12 (80.0%) | 12 (100.0%)
200 + 1,000 + 0 | 16 | 13 (81.2%) | 6 (46.2%)^**^
400 + 1,000 + 0 | 20 | 0^**^ | —
0 + 2,000 + 0 | 15 | 13 (86.7%) | 12 (92.3%)
0 + 2,000 + 10 | 15 | 14 (93.3%) | 14 (100.0%)
200 + 2,000 + 0 | 20 | 15 (75.0%) | 4 (26.6%)^**^
400 + 2,000 + 0 | 16 | 16 (100.0%) | 0^**^
400 + 2,000 + 10 | 15 | 15 (100.0%) | 0^**^
0 + 3,000 + 0 | 14 | 12 (85.7%) | 10 (83.3%)
0 + 3,000 + 10 | 15 | 15 (100.0%) | 12 (80.0%)
200 + 3,000 + 0 | 14 | 12 (85.7%) | 0^**^
400 + 3,000 + 0 | 16 | 15 (93.8%) | 0^**^

** Significantly different (P≤0.01) from the control group by the Cochran-Armitage and Fisher exact tests

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

The duration of gestation was not significantly affected by AZT, TMP/SMX, or folinic acid; a statistically significant increase noted in the 0 + 3,000 + 10 mg/kg group was not considered biologically significant, as similar values were observed in other dosed groups.

The number of implantation sites was not affected by the administration of any test article alone or in combination. The number of dams with stillborn pups was significantly increased in the following groups: 400 + 0 + 10 mg/kg, 200 + 2,000 + 0 mg/kg, 0 + 3,000 + 0 mg/kg, and 0 + 3,000 + 10 mg/kg (Table 23). The number of dams with all liveborn pups dying between days 0 and 4 was significantly increased in the 0 + 2,000 + 0 mg/kg, 0 + 3,000 + 0 mg/kg, and 0 + 3,000 + 10 mg/kg groups.

TABLE 23 Summary of Natural Delivery Litter Data for Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Dams with Stillborn Pups (% of Dams that Delivered) | Dams with All Pups Dying on Days 0-4 (% of Dams with Liveborn Pups) | Mean Live Litter Size | Pups Dying on Days 1-4/Total Alive on Day 1 (%) | Survival/Live Litter Size^b^ on Day 4 Postpartum
0 + 0 + 0 | 1 (7 1) | 0 (0 0) | 11 3 | 1/147 (0 7) | 11 2/11 3
0 + 0 + 10 | 1 (7 7) | 1 (7 7) | 11 1 | 13/144 (9 0)^**^ | 10 1/10 9
200 + 0 + 0 | 3 (23 1) | 1 (8 3) | 9 7 | 6/116 (5 2) | 9 2/10 0
400 + 0 + 0 | 6 (42 8) | 2 (14 3) | 7 8 | 8/109 (7 3)^*^ | 7 2/8 4
400 + 0 + 10 | 6 (54 4)^*^ | 1 (10 0) | 7 9 | 7/79 (8 9)^**^ | 7 2/7 9
0 + 1 000 + 0 | 3 (25 0) | 0 (0 0) | 12 2 | 16/145 (11 0)^**^ | 10 8/10 8
200 + 1,000 + 0 | 3 (50 0) | 0 (0 0) | 8 7 | 3/26 (11 5)^*^ | 7 7/7 7
400 + 1,000 + 0 | —^c^ | — | — | — | —
0 + 2,000 + 0 | 5 (41 7) | 5 (45 4)^*^ | 11 3 | 77/116 (66 4)^**^ | 3 5^*^/6 5
0 + 2,000 + 10 | 4 (28 6) | 4 (28 6) | 10 7 | 102/148 (68 9)^**^ | 3 3^**^/4 6^*^
200 + 2,000 + 0 | 3 (75 0)^*^ | 1 (33 3) | 3 7 | 5/11 (45 4)^**^ | 2 0/3 0
400 + 2,000 + 0 | — | — | — | — | —
400 + 2,000 + 10 | — | — | — | — | —
0 + 3 000 + 0 | 6 (60 0)^*^ | 8 (100 0)^**^ | 7 4 | 68/68 (100 0)^**^ | 0^**^/-
0 + 3,000 + 10 | 11 (91 7)^**^ | 10 (100 0)^**^ | 5 8 | 52/52 (100 0)^**^ | 0^**^/-
200 + 3,000 + 0 | — | — | — | — | —
400 + 3 000 + 0 | — | — | — | — | —

* Significantly different (P≤0 05) from the control group by the Cochran-Armitage and Fisher exact tests

** P≤0 01

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

b Excludes values for litters that had no surviving pups

c No litters were delivered

AZT (200 or 400 mg/kg) alone and TMP/SMX (3,000 mg/kg) alone reduced live litter sizes, with or without folinic acid (Table 23). For the remaining combination dose groups that had surviving pups, live litter sizes were also reduced Significant increases in the number of pups dying on days 1 to 4 occurred in groups administered 400 mg/kg AZT alone or with folinic acid, 1,000 mg/kg TMP/SMX alone, 2,000 or 3,000 mg/kg TMP/SMX alone or with folinic acid, or 200 mg/kg AZT in combination with TMP/SMX. Although pups from the dose group receiving folinic acid alone had a significantly increased incidence of death, this effect was not considered to be related to folinic acid because 12 of the 13 deaths that occurred were from a single litter. Significantly decreased values for survival and/or live litter size for groups with surviving litters were noted in the following groups: 0 + 2,000 + 0 mg/kg, 0 + 2,000 + 10 mg/kg, 0 + 3,000 + 0 mg/kg, and 0 + 3,000 + 10 mg/kg. Statistically significant differences in sex ratios (percent males per litter) that occurred were due to the small numbers of surviving litters in a particular group and are not, therefore, considered biologically significant.

Mean pup body weights per litter were decreased (P≤0.05) in the following groups: 400 + 0 + 0 mg/kg, 400 + 0 + 10 mg/kg, 200 + 1,000 + 0 mg/kg, 0 + 2,000 + 0 mg/kg, 0 + 2,000 + 10 mg/kg, 200 + 2,000 + 0 mg/kg, 0 + 3,000 + 0 mg/kg, and 0 + 3,000 + 10 mg/kg (Figure 18).

FIGURE 18 Mean Body Weights of Pups of Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid (LD=lactation day)

## Caesarean Section Data

The administration of 200 or 400 mg/kg AZT alone or in combination with any dose of TMP/SMX or folinic acid reduced the number of pregnant mice per group (Table 24). For pregnant dams, the average number of corpora lutea and implantations per litter was not affected by treatment with the test articles. The apparent reduction in corpora lutea and implantation sites per litter in the 200 + 1,000 + 0 mg/kg group was likely related to the absence of live fetuses in this group and the difficulty in counting corpora lutea and implantations of total resorbed litters.

TABLE 24 Occurrence of Pregnancy in Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Number Pregnant (%)^b^
0 + 0 + 0 | 15 (75.0)
0 + 0 + 10 | 17 (85.0)
200 + 0 + 0 | 10 (50.0)
400 + 0 + 0 | 4 (20.0)^**^
400 + 0 + 10 | 8 (40.0)
0 + 1,000 + 0 | 11 (55.0)
200 + 1,000 + 0 | 6 (30.0)^*^
400 + 1,000 + 0 | 0^**^
0 + 2,000 + 0 | 17 (85.0)
0 + 2,000 + 10 | 10 (50.0)
200 + 2,000 + 0 | 0^**^
400 + 2,000 + 0 | 0^**^
400 + 2,000 + 10 | 0^**^
0 + 3,000 + 0 | 11 (55.0)
0 + 3,000 + 10 | 11 (55.0)
200 + 3,000 + 0 | 0^**^
400 + 3,000 + 0 | 0^**^

* Significantly different (P≤0.05) from the control group by the Cochran-Armitage and Fisher exact tests

** P≤0.01

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

b n = 20

Administration of AZT (200 or 400 mg/kg) alone or in combination with TMP/SMX and/or folinic acid resulted in significant decreases (P≤0.05) in the number of live fetuses per litter (Table 25). The average number of dead fetuses per litter was increased in groups administered TMP/SMX alone or in combination with folinic acid but was not affected by doses of AZT or folinic acid.

Significant increases in the average number of early and/or late resorptions were noted in the following groups: 200 + 0 + 0 mg/kg, 400 + 0 + 0 mg/kg, and 400 + 0 + 10 mg/kg (Table 25). The 200 + 1,000 + 0 mg/kg group had increases (P≤0.05) only in early resorptions.

The number of dams with all conceptuses resorbed (Table 25) increased in groups administered 200 or 400 mg/kg AZT.

TABLE 25 Summary of Caesarean-Sectioning Litter Data for Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Litter Sizes Mean ± SD^b^ | Live Fetuses | | Dead Fetuses | | Resorptions
Dose^a^ | Litter Sizes Mean ± SD^b^ | No. | Mean ± SD | No. | Mean ± SD | No. | Mean ± SD
0 + 0 + 0^c^ | 11 0 ± 3 2 | 154 | 11 0 ± 3 2 | 0 | 0 0 ± 0 0 | 15 | 1 1 ± 1 4
0 + 0 + 10^d^ | 10 8 ± 2 8 | 172 | 10 8 ± 2 7 | 1 | 0 1 ± 0 2 | 16 | 1 0 ± 1 2
200 + 0 + 0 | 4 8 ± 5 5^*^ | 48 | 4 8 ± 5 5^*^ | 0 | 0 0 ± 0 0 | 83 | 8 3 ± 4 7^**^
400 + 0 + 0 | 0 8 ± 1 5^*^ | 3 | 0 8 ± 1 5^*^ | 0 | 0 0 ± 0 0 | 36 | 9 0 ± 1 8^*^
400 + 0 + 10 | 0 4 ± 0 7^**^ | 3 | 0 4 ± 0 7^**^ | 0 | 0 0 ± 0 0 | 79 | 9 9 + 2 6^**^
0 + 1,000 + 0 | 9 5 ± 3 2 | 102 | 9 3 ± 3 1 | 3 | 0 3 ±0 5 | 15 | 1 4 ± 1 4
200 + 1,000 + 0 | 0 0 ± 0 0^**^ | 0 | 0 0 ± 0 0^**^ | 0 | 0 0 ± 0 0 | 44 | 7 3 ± 4 6^*^
400 + 1,000 + 0 | —^e^ | — | — | — | — | — | —
0 + 2,000 + 0^c^ ^d^ | 10 4 ± 1 5 | 141 | 10 1 ± 1 7 | 5 | 0 4 ± 0 6 | 20 | 1 4 ± 1 0
0 + 2,000 + 10^c,d,f^ | 10 8 ± 1 1 | 70 | 10 0 ± 1 3 | 6 | 0 8 ± 0 9^*^ | 9 | 1 3 ± 1 0
200 + 2,000 + 0 | — | — | — | — | — | — | —
400 + 2,000 + 0 | — | — | — | — | — | — | —
400 + 2,000 + 10 | — | — | — | — | — | — | —
0 + 3,000 + 0^g^ | 10 0 ± 2 1 | 92 | 9 2 ± 1 5 | 8 | 0 8 ± 1 1 | 15 | 1 5 ± 1 7
0 + 3,000 + 10 | 8 8 ± 3 3 | 77 | 8 6 ± 3 2 | 2 | 0 2 ± 0 4 | 25 | 2 8 ± 2 4
200 + 3,000 + 0 | — | — | — | — | — | — | —
400 + 3,000 + 0 | — | — | — | — | — | — | —

* Significantly different (P≤0 05) from the control group by the Cochran-Armitage and Fisher exact tests

** P≤0 01

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

b SD=standard deviation

c Excludes dams that delivered or began to deliver litters before scheduled sacrifice

d Excludes dams that were sacrificed on an estimated day 14 of gestation, due to gestational age of fetuses, genders and viability could not be determined

e No pregnancies were detected in this group

f Excludes dam that was sacrificed moribund on day 17 of the study

g Excludes values for dams that were found dead

Significant reductions (P≤0.05) in the mean fetal body weight per litter (Table 26) were noted in the groups administered 200 or 400 mg/kg AZT alone or in combination with folinic acid or administered 2,000 or 3,000 mg/kg TMP/SMX alone or in combination with folinic acid.

TABLE 26 Body Weights of Fetuses from Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Dose^a^ | Mean Fetal Weight (g)
0 + 0 + 0 | 1.34
0 + 0 + 10 | 1.33
200 + 0 + 0 | 0.92^**^
400 + 0 + 0 | 0.81^*^
400 + 0 + 10 | 0.66^**^
0 + 1,000 + 0 | 1.40
200 + 1,000 + 0 | —^b^
400 + 1,000 + 0 | —
0 + 2,000 + 0 | 1.06^**^
0 + 2,000 + 10 | 1.09^*^
200 + 2,000 + 0 | —
400 + 2,000 + 0 | —
400 + 2,000 + 10 | —
0 + 3,000 + 0 | 0.90^**^
0 + 3,000 + 10 | 0.94^**^
200 + 3,000 + 0 | —
400 + 3,000 + 0 | —

* Significantly different (P≤0.05) from the control group by Dunnett’s or Dunn’s test

** P≤0.01

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

b No fetuses were present.

## Gross External Alterations (Female-B Litters)

Administration of 1,000 to 3,000 mg/kg TMP/SMX produced significant increases (P≤0.01) in the number of fetuses with cleft palate (Table 27 and Plate 14) as well as in the number of litters and the average percentage of fetuses per litter with this alteration. Doses of 2,000 or 3,000 mg/kg TMP/SMX produced cleft palate in 100% of the litters and at least 80% of the fetuses obtained from caesarean section. The frequency of cleft palate was also associated with the presence of distended abdomens (Table 27) in pups of female-B mice. The incidence of cleft palate in pups from examined female-B mice was similar to the incidence observed in the fetuses of female-A mice.

TABLE 27 Association of Cleft Palate and Distended Abdomen in Pups from Female-B Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice^a^

Dose^b^ | Incidence^c^ of Cleft Palate | Incidence^c^ of Distended Abdomen
0 + 0 + 0 | 0/0 | 0/0
0 + 0 + 10 | 0/0 | 0/0
200 + 0 + 0 | 1/6 | 0/6
400 + 0 + 0 | 6/11 | 1/11
400 + 0 + 10 | 2/2 | 0/2
0 + 1,000 + 0 | 2/2 | 2/2
200 + 1,000 + 0 | 0/2 | 0/2
400 + 1,000 + 0 | 0/0 | 0/0
0 + 2,000 + 0 | 77/81 | 71/81
0 + 2,000 + 10 | 57/62 | 59/62
200 + 2,000 + 0 | 5/5 | 0/0
400 + 2,000 + 0 | 0/0 | 0/0
400 + 2,000 + 10 | 0/0 | 0/0
0 + 3,000 + 0 | 47/47 | 27/47
0 + 3,000 + 10 | 88/91 | 46/91
200 + 3,000 + 0 | 0/0 | 0/0
400 + 3,000 + 0 | 0/0 | 0/0

a Data obtained from gross necropsy of selected pups

b Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day)

c Number of pups with observation/number of pups in dose group

The fetal incidence of open eyes was also increased in some of these dose groups. Administration of folinic acid did not ameliorate the effects of TMP/SMX. Other alterations not considered to be test article related included hematomas of the head and body, body edema, kyphosis, and club foot. These anomalies are common in this strain of mouse.