# Materials and Methods

## Procurement and Characterization of Chemicals

3′-Azido-3′-deoxythymidine (AZT; lot 1401-R-9) was manufactured by Raylo Chemicals (Edmonton, Alberta) and supplied as a powder. Trimethoprim/sulfamethoxazole (TMP/SMX; lot 7493-150-01) was manufactured by Napp Chemicals (Lodi, NJ) and received as a 1:5 TMP/SMX mixture. Folinic acid pentahydrate, calcium salt (lot 11H0858) was obtained from Sigma Chemical Company (St. Louis, MO).

The purity of the AZT was determined to be 99.7% by high-performance liquid chromatography. Infrared and nuclear magnetic resonance spectrometry analyses performed on TMP and SMX produced spectra which were consistent with the structures of trimethoprim and sulfamethoxazole and agreed with the reference spectra. Purity of TMP and SMX as determined by HPLC was greater than 99%. The control vehicle used in this study was corn oil.

## Dose Formulations

The required amounts of the test articles were combined with the required amount of control vehicle. The dose formulation was then stirred until visually homogeneous.

The folinic acid used in this study was not identified at receipt as a pentahydrate. This form of the chemical contains approximately 12% water by weight. Therefore, the actual dose concentration of folinic acid administered was approximately 8.8 mg folinic acid/kg body weight, or 88 times the recommended daily requirement for mice (NRC, 1978).

Stability studies at refrigeration and ambient temperature for AZT/TMP/SMX formulations in corn oil indicated that the dose formulations were stable for 32 days when stored refrigerated. Dose formulations were stored under refrigeration, protected from light, and used within 7 days.

Samples at each dose concentration from the initial and final dose formulations were analyzed. Residual dose formulations taken from the animal room after dosing were also analyzed. Additionally, samples taken from the top, middle, and bottom of the dose formulations at the highest (20.0 mg/mL) and the lowest (10.0 mg/mL) concentrations of AZT and the dose formulation with the highest concentration of AZT in combination with the highest concentration of TMP/SMX were analyzed in conjunction with the first analysis to confirm homogeneity. The homogeneity analyses (AZT only) resulted in standard deviations that ranged from 0.76% to 6.3%. Prior to dosing, the concentrations of AZT in the final mix were within 10% of theoretical values with the exception of two of the dose formulations at 20.0 mg/mL (400 mg/kg) that assayed at 71.5% and 85.5% of the target concentrations. Post-dosing results for these same dose formulations ranged from 105% to 118% of the target concentrations. The dose formulations were not assayed for TMP/SMX or folinic acid because of interference by the corn oil vehicle.

## Study Design

Swiss (CD-1®) mice were obtained from Charles River Laboratories, Raleigh, NC (Areas R10 and R16), and were approximately 15 weeks old when placed on study. The mice were housed five males or five females per cage during quarantine before randomization and were individually housed after randomization, except during cohabitation.

The mice were housed in polycarbonate cages with solid bottoms and sides. Average temperature in the animal rooms was 7l.2° F, with a standard deviation of 0.6° F; average relative humidity was 54.4%, with a standard deviation of 6.3%.

At terminal sacrifice, blood samples were collected from five male and five female sentinel animals as part of the animal disease screening program. Results indicated that all animals were free of viral antibodies.

Folinic acid is the active form of folic acid used as an antidote to folic acid antagonists. Folic acid is a dietary essential required for DNA synthesis, chromosomal replication, and cell division. A deficiency in folic acid primarily affects cells with rapid turnover, such as the hematopoietic system cells. Folic acid deficiency is manifested morphologically by megaloblastic anemia and is also associated with fetal anomalies. TMP is a folic acid antagonist, and SMX prevents the synthesis of this vitamin by inhibiting the incorporation of para-aminobenzoic acid into the molecule. In addition, AZT therapy is associated with macrocytosis. Therefore, based on the known toxic effects of these compounds given alone, an additive or synergistic toxicity may occur with combination therapy. It was predicted that the supplementation of folinic acid to selected dose groups in this study might decrease the hematopoietic and reproductive toxicity associated with these compounds that inhibit the synthesis or action of folic acid.

AIDS patients are receiving combination therapy with TMP/SMX and AZT as well as supplementation with folinic acid. Controlled laboratory data are required to evaluate the potential toxicity of this combination therapy. At present, there are no alternatives to whole animal models for this purpose. The Swiss (CD-1®) mouse chosen for this study is one of the mouse models routinely used for reproductive and developmental toxicity studies by the NIEHS.

The basic premise for dose concentration recommendations is that the high dose concentration should induce some measurable evidence of toxicity (e.g., anemia, weight loss, target organ toxicity). In a number of studies conducted with this protocol, AZT at the doses selected (200 and 400 mg/kg) caused resorptions and decreased litter sizes. The human dose is 10 mg/kg per day (PDR, 1994). The selected doses are 20 and 40 times the human doses, but on a body surface area basis, the doses are close to two and four times the therapeutic dose (Freireich et al., 1966).

The clinical dose of TMP/SMX for Pneumocystis carinii pneumonia (PCP) therapy in AIDS patients is 120 (20 mg/kg TMP + 100 mg/kg SMX) mg/kg per day (Wofsy, 1987). The equivalent mouse dose would be 1,500 mg/kg. The recommended dose for control of pneumocystis infection in severe combined immunodeficiency mice is 600 (100 mg/kg TMP + 500 mg/kg SMX) mg/kg per day, and 1,000 mg/kg is the therapeutic dose for treatment of toxoplasmosis in mice. The selected doses (1,000, 2,000, and 3,000 mg/kg TMP/SMX) are 1 to 1.6 times, 2 to 3.3 times, and 3 to 5 times the therapeutic dose for mice and 8.3 times, 16.6 times, and 25 times the human therapeutic dose. On a body surface area basis, the selected doses of TMP/SMX (1,000, 2,000, and 3,000 mg/kg) are close to 0.75 to 2 times the human therapeutic dose (Freireich et al., 1966).

Limited information on the reproductive toxicity of TMP/SMX is available. “In rats, oral doses of 533 mg/kg sulfamethoxazole or 200 mg/kg trimethoprim produced teratologic effects manifested mainly as cleft palates. The highest dose which did not cause cleft palates in rats was 512 mg/kg sulfamethoxazole or 192 mg/kg trimethoprim when administered separately … cleft palates were observed in one litter out of nine when 355 mg/kg of sulfamethoxazole was used in combination with 88 mg/kg of trimethoprim” (PDR, 1994).

The dose selected for folinic acid in this study was 10 mg/kg, equivalent to 100 times the minimum daily requirement of folic acid for the mouse (NRC, 1978). However, the folic acid content of NIH-07 diet varies from 1.8 to 3.7 mg/kg (NTP, 1998), equivalent to 0.36 to 0.75 mg/kg body weight.

The recommended daily requirement for folic acid in humans is 200 μg per day (Goodman and Gilman’s, 1990). The total dose of folinic acid administered following methotrexate therapy (36 mg/kg) is 150 mg (PDR, 1994). This dose, given over 2.5 days (60 mg per day), is equivalent to 300 times the daily requirement.

The dose of folinic acid is based on clinical and experimental reports in the literature. The clinical dose for AIDS patients is 5 mg per day (PDR, 1994), which is equivalent to 1 mg/kg in the mouse (Freireich et al., 1966). The dose of folinic acid used in the rat to prevent cytopenias induced by TMP/SMX is 1 mg per day (5 mg/kg for a 200 g rat), which is equivalent to 10 mg/kg in the mouse.

The design of this study is a modification of a design published elsewhere (Harris et al., 1992). A brief summary of the study design is provided in Table 2. The oral route of administration was selected because it is the route used in humans, and the study was conducted in Swiss (CD-1®) mice because this strain is routinely used for reproductive and developmental toxicity evaluations. Combinations of AZT (200 or 400 mg/kg), TMP/SMX (1,000, 2,000, or 3,000 mg/kg), and/or folinic acid (10 mg/kg) were administered by gavage as a single formulation in corn oil. Total daily doses of 20 mL/kg were divided into two equal doses of 10 mL/kg given approximately 6 hours apart. Mice were divided into three groups as follows:

Male Mice: Ten males were assigned to each dose group. Prior to dosing, male mice were cohabited with female-B mice on study days 0 to 4. Males were dosed from study day 5 to the day prior to sacrifice. Males were cohabited with female-A mice on study days 9 to 13 to identify any effects of treatment on mating behavior. On study day 25 or 26, all male mice were weighed, and blood samples were obtained from the retroorbital sinus for hematology and clinical chemistry evaluations. The males were euthanized with CO_2_, necropsy was conducted, and the testes and epididymides were collected and prepared for evaluation of sperm parameters as described in the Sperm Function Evaluation section.

Female-A Mice: Twenty females were assigned to each dose group. Female-A mice were dosed from study day 0 to the day prior to sacrifice. Males were cohabited with female-A mice on study days 9 to 13 to identify any effects of treatment on mating behavior, fertilization, implantation, or the initial stages of development. During the cohabitation period, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually, and that day was designated as day 0 of gestation. At the end of the cohabitation period, all animals were housed individually. Prior to parturition on day 18 of presumed gestation (study days 28 to 32), all female-A mice were weighed, and blood samples were taken from the retroorbital sinus for hematology and clinical chemistry evaluations. The female-A mice were then euthanized with CO_2_, and necropsy and caesarean section evaluations were conducted. Live fetuses were removed, weighed, anesthetized on ice, and preserved in Bouin’s fixative. The uteri of all sperm-negative females were examined for evidence of unsuccessful pregnancy and then press-plated between two heavy plates of glass to visualize implantation sites. Additional endpoints for all female-A mice included gravid uterine weight and number of implantation sites, resorptions, corpora lutea, and dead and live fetuses.

Female-B Mice: Twenty females were assigned to each dose group. Prior to dosing, female-B mice were cohabited with males on study days 0 to 4. During the cohabitation period, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually, and that day was designated as day 0 of gestation. At the end of the cohabitation period, sperm-negative female-B mice were euthanized with CO_2_ and discarded without necropsy; all other animals were housed individually. Sperm-positive female-B mice were assigned evenly across dose groups prior to gestation day 6. Female-B mice were subsequently dosed during gestation days 6 to 15, during the fetal organogenesis period, to identify effects on fetal development. Residual effects on parturition and the beginning of lactation were also evaluated. After gestation day 16, the bedding material and feeders were no longer changed. From gestation day 17 until the litters were delivered, female-B mice were observed twice daily for evidence of labor or delivery. The day of completed delivery was determined to the nearest day and designated as postnatal day 0. On postnatal days 0 and 1, dam body weights were recorded along with the number of live and dead pups, the number of male and female pups, the incidence of any gross malformations, and live pup weights. Dead pups were discarded. On postnatal day 4, all female-B mice, including any that did not deliver, were weighed, and blood samples were collected from the retroorbital sinus for hematology and clinical chemistry evaluations. These mice were then euthanized with CO_2_, and complete necropsies were performed. The uterus was removed and press-plated. All pups were weighed and given a thorough external examination for lesions and malformations, and the gender was recorded. The pups were then euthanized with CO^2^ and preserved in Bouin’s fixative.

### Clinical Pathology

All blood samples were collected from the retroorbital sinus under CO_2_:O_2_ anesthesia. Blood for hematology analyses was collected in a tube containing EDTA, and blood for clinical chemistry analyses was collected in a tube without anticoagulant. Animals were selected in random order for blood collection, and samples were analyzed in the order collected.

Erythrocyte, platelet, and leukocyte counts; hematocrit; hemoglobin concentration; mean cell hemoglobin; mean cell volume; mean cell hemoglobin concentration; and leukocyte differentials were determined in whole blood using a Technicon H·™ automated hematology analyzer. Reticulocyte counts were conducted using a Coulter Model Elite® Flow Cytometer. Blood smears were prepared to manually verify reticulocyte counts, leukocyte differentials, and morphologies if necessary.

Blood urea nitrogen, creatinine, alanine aminotransferase, alkaline phosphatase, and aspartate aminotransferase were determined using the Roche Cobas Fara® automated analyzer. Priority for clinical chemistry tests was assigned in the order listed above.

### Sperm Function Evaluation

Sperm motility was evaluated at necropsy in the following manner. The left epididymis was isolated and weighed. The tail of the epididymis (cauda epididymis) was then removed from the epididymal body (corpus epididymis). Modified Tyrode’s buffer was applied to slides, and a small incision was made at the distal border of the cauda epididymis. The sperm effluxing from the incision were dispersed in the buffer on the slides, and the numbers of motile and nonmotile spermatozoa were counted for five fields per slide by two observers.

Following completion of sperm motility estimates, each left cauda epididymis was placed in buffered neutral saline solution. Caudae were finely minced, and the tissue was incubated in the saline solution and then heat fixed at 65° C. Sperm density was then determined microscopically with the aid of a hemocytometer. To quantify spermatogenesis, a testicular spermatid head count was determined by removing the tunica albuginea and homogenizing the left testis in phosphate-buffered saline containing 10% dimethyl sulfoxide. Homogenization-resistant spermatid nuclei were counted with a hemocytometer.

### Histopathology

A gross necropsy was performed on all animals (except sperm-negative female-B mice), and histopathology was conducted on the tissues listed in Table 2. The tissues were fixed in formalin, trimmed to a maximum thickness of 0.3 em for processing, embedded in paraffin, sectioned to a thickness of 4 to 6 microns, stained with hematoxylin and eosin, and examined by light microscopy.

TABLE 2 Experimental Design and Materials and Methods in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid in Swiss (CD-1®) Mice

Study Laboratory; Southern Research Institute, Birmingham, AL
Strain and Species; Swiss (CD-1®) mice
Animal Source; Charles River Laboratories, Raleigh, NC
Time Held Before Studies; 24 days
Average Age When Studies Began; 102 days
Date of First Dose; Male mice 1 or 8 June 1994; Female-A mice 27 May or 3 June 1994; Female-B mice 2-6 or 9-13 June 1994
Duration of Dosing; Male mice day 5 to day prior to sacrifice; Female-A mice day 0 to day prior to sacrifice; Female-B mice gestation days 6 to 15
Days of Cohabitation; Male mice and female-A mice days 9 to 13; Male mice and female-B mice days 0 to 4; When possible, 1 male and 2 females within the same dose group were housed together by consecutive animal number
Date of Last Dose; Male mice 26 June or 3 July 1994; Female-A mice 23-27 June or 30 June-4 July 1994; Female-B mice 11-15 or 18-22 June 1994
Necropsy Dates; Male mice days 25 to 26; Female-A mice days 28 to 32; Female-B mice days 24 to 28 of presumed gestation (sperm-positive, not delivered), postnatal day 4 (sperm-positive, delivered)
Average Age at Necropsy; Male mice 127-128 days; Female-A mice 130-134 days; Female-B mice 126-130 days
Size of Study Groups; Male mice 10 per dose group; Female-A mice 20 per dose group; Female-B mice 20 per dose group
Method of Animal Distribution; Animals were distributed randomly into groups of approximately equal initial mean body weights
Animals per Cage; One animal per cage, except during cohabitation
Method of Animal Identification; Tail tattoo
Diet; NIH-07 pelleted feed, available ad libitum
Water Distribution; Tap water (Birmingham, AL), available ad libitum
Cages; Polycarbonate cages with solid bottoms and sides
Bedding; Heat-treated hardwood chips (Sam-Chips®, P J Murphy Forest Products Corporation, Montville, NJ)
Cage Filters; Reemay® spun-bonded polyester (Andico, Birmingham, AL)
Racks; Stainless steel (Lab Products, Maywood, NJ)
Animal Room Environment; Temperature 71 2° ± 0 6° F; Relative humidity 54 4% ± 6 3%; Fluorescent light 12 hours fluorescent light/day; Room air minimum of 10 changes/hour
Doses; Daily doses in corn oil gavage; 0 mg AZT + 0 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 0 mg AZT + 0 mg TMP/SMX + 10 mg folinic acid per kg body weight per day; 200 mg AZT + 0 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 400 mg AZT + 0 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 400 mg AZT + 0 mg TMP/SMX + 10 mg folinic acid per kg body weight per day; 0 mg AZT + 1,000 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 200 mg AZT + 1,000 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 400 mg AZT + 1,000 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 0 mg AZT + 2,000 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 0 mg AZT + 2,000 mg TMP/SMX + 10 mg folinic acid per kg body weight per day; 200 mg AZT + 2,000 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 400 mg AZT + 2,000 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 400 mg AZT + 2,000 mg TMP/SMX + 10 mg folinic acid per kg body weight per day; 0 mg AZT + 3,000 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 0 mg AZT + 3,000 mg TMP/SMX + 10 mg folinic acid per kg body weight per day; 200 mg AZT + 3,000 mg TMP/SMX + 0 mg folinic acid per kg body weight per day; 400 mg AZT + 3,000 mg TMP/SMX + 0 mg folinic acid per kg body weight per day
Type and Frequency of Observation; Mortality/moribundity twice daily; Clinical findings once daily; Vaginal plugs days 10 to 14 for female-A mice, days 1 to 5 for female-B mice; Body weights days 3, 5, 9, 13, 17, 21, 23, and sacrifice for male mice, days 0, 4, 12, 16, 20, 23, 26, and sacrifice for female-A mice, gestation days 0, 8, 12, 15, and postnatal days 0, 1, and 4 for female-B mice, postnatal days 0, 1, and 4 for pups
Method of Sacrifice; CO_2_ O_2_ asphyxiation
Necropsy; Complete necropsies were performed on all breeder animals except sperm-negative female-B mice
Histopathology; Complete histopathology was performed on all mice. In addition to gross lesions and associated lymph nodes, the following tissues were examined: bone marrow, brain, heart, kidneys, liver, thyroid gland, lungs and bronchi, spleen, testes with epididymis and tunica vaginalis, and thymus (male mice), bone marrow, brain, femur, kidneys, liver, lungs, spleen, thymus, and thyroid gland (female mice). Pups were examined externally only
Clinical Pathology; Hematology and clinical chemistry evaluations were conducted on all animals at terminal sacrifice
Sperm Function Evaluation; Conducted on all males at terminal sacrifice

## Statistical Methods

Paternal and maternal body weight evaluations were analyzed using Bartlett’s test of homogeneity of variances and the analysis of variance (Snedecor and Cochran, 1967). If Bartlett’s test was not significant (P>0.05) and the analysis of variance was significant (P≤0.05), then Dunnett’s test (Dunnett, 1955) was used to identify the statistical significance of individual groups. If Bartlett’s test was significant (P≤0.05), the Kruskal-Wallis test (Hollander and Wolfe, 1973) was used; in cases in which the Kruskal-Wallis test was significant (P≤0.05), Dunn’s (1964) method of multiple comparisons was used to identify the statistical significance of individual groups. These methods were also used to analyze fetal body weight and pup body weight (per litter) as well as all other evaluations involving continuous data. For F_0_ generation sires and dams, the analysis of covariance (Snedecor and Cochran, 1967) was used to evaluate mean body weight changes and mean maternal body weight changes. Observations for delivered and dead conceptuses of the female-A dams and for fetuses from female-A dams caesarean-sectioned on an estimated day 14 of gestation were excluded from fetal body weight summaries and statistical analyses.

Group means and standard deviations were calculated for hematology and clinical chemistry parameters and for final mean body and epididymis weights. Epididymis/body weight ratios were also calculated. Final mean body weights of males and females and mean epididymis weights and epididymis/body weight ratios of males for each dosed group were compared to those of the control group by a two-tailed Student’s t-test. The standard deviations used in the t-tests were obtained by pooling the individual values for the control and dosed groups. Hematology and clinical chemistry data were evaluated using Dunnett’s test.

All target organ (bone marrow, liver, spleen, thymus, and thyroid) endpoints were analyzed for test compound interaction using a three-way analysis of variance; male reproductive endpoints were analyzed for compound interaction using a two-way analysis of variance. If a significant interaction was observed for target organs, mean values were plotted to graphically display the interaction between the compounds. If no interaction was detected for target organs or reproductive parameters, averages were taken at each dose concentration of a compound over all levels of the other test compounds. Control and dosed group means were compared using either Williams’ (1971, 1972) or Dunnett’s (1955) multiple comparison procedures. The choice between the two tests was based on the evidence of a dose-related trend in the data as assessed by Jonckheere’s (1954) test. Williams’ test was applied if there was an indication of trend (P<0.01), and Dunnett’s test was used in the absence of a trend. In selected cases in which interaction was found to be significant, the multiple comparison tests described above were used to detect treatment-related effects.

Proportion data (e.g., clinical findings and incidences of pregnancy, resorption, death, and total resorption) for mice presumed pregnant were analyzed using the Cochran-Armitage test for a linear trend in proportions (Snedecor and Cochran, 1967) and Fisher’s exact test (Siegel, 1956).