# Introduction

AIDS is a lethal multi-system disease that has become a major public health problem since its recognition in 1981 (Gottlieb et al., 1981; Masur et al., 1981; Siegal et al., 1981). The etiological agent of AIDS is a retrovirus now referred to as HIV (Coffin, 1986). To date, the most effective single agent in the treatment of HIV has been the first dideoxynucleoside analogue used in clinical trials, zidovudine (3′-azido-3′-deoxythymidine, AZT, Retrovir, azidothymidine, compound S, BW A509U, CAS No. 30516-87-1), commonly referred to as AZT (Vince et al., 1988; Amin, 1989).

AZT therapy produces numerous beneficial effects in AIDS patients, including decreases in morbidity and increases in lifespan (Amin, 1989; Jeffries, 1989). The most important adverse effects of AZT are anemia and granulocytopenia, which are believed to reflect bone marrow toxicity (Richman, 1988; Amin, 1989). Two types of anemia may occur with AZT therapy: macrocytic megaloblastic anemia and normocytic normochromic anemia.

Several subacute and subchronic rodent toxicity studies have demonstrated that the primary toxicity of AZT is myelosuppression. Male Swiss (CD-1®) mice were administered 100, 250, 500, or 1,000 mg AZT/kg body weight by gavage for 30 days (Mansuri et al., 1990). No mortality or body weight effects were evident from AZT treatment. Erythropenia and increased mean cell volume were observed at all doses, and anemia was observed at the 1,000 mg/kg dose. Pathologic findings in the AZT-treated mice were consistent with the hematological results and included lymphoid depletion, reticuloendothelial hyperplasia in the spleen and thymus, and bone marrow hypocellularity.

In a 14-week subchronic study (NTP, 1998), B6C3F_1_ mice were treated with 0, 25, 50, 100, 400, or 1,000 mg AZT/kg body weight in 0.5% methylcellulose by gavage twice daily. On day 5, statistically significant dose-related decreases were observed in reticulocyte counts in both males and females. Dose-related anemia was evident on days 23 and 93. To evaluate the ability of treated animals to reverse any compound-related effects when treatment is stopped, additional groups were administered 0, 50, 400, or 1,000 mg/kg AZT twice daily for 92 days and then held without additional treatment for 29 days. Improvement of hematology parameters indicated recovery of the bone marrow after treatment stopped. An apparently nontoxic, treatment-related clinical finding that affected AZT-treated B6C3F_1_ mice was a darkening of the skin on the tail, feet, and/or muzzle.

Oral bioavailability of AZT was determined in female B6C3F_1_ mice by comparison of the area under the curve obtained from an oral dose to that of an intravenous dose at the same concentration (Trang et al., 1993). Bioavailability was found to be 0.86, 0.78, and 0.97 for the 15, 30, and 60 mg/kg oral doses. The mean elimination half-life values ranged from 17.3 to 19.9 minutes for the three intravenous doses and from 16.5 to 21.9 minutes for the three oral doses. Based on these results, the internal dose of AZT was linear and dose proportional over the oral-dose concentration range administered.

Standard teratology studies of AZT have been performed in rats and rabbits (Ayers, 1988). Rats were dosed orally with 125 to 500 mg/kg on gestation days 6 to 15. No fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 61 μg/g or 76 times the antiviral inhibitory dose for 50% of the viral population being tested (ID_50_). Rabbits were dosed orally at 125 to 500 mg/kg on gestation days 6 to 18, and no fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 40.2 μg/g, or 50 times the antiviral ID_50_.

Female Wistar rats were dosed three times orally with 100 mg/kg AZT at 5-hour intervals on gestation day 10 for a total dose of 300 mg/kg (Greene et al., 1990). No adverse effects on maternal body weight gain, feed consumption, fertility, and hematological parameters or growth and survival of offspring were observed. AZT concentration measurements 30 minutes after the last dose were 62.6 μg/mL in maternal plasma and 21.1 μg/g in fetal tissue.

Studies in C_3_H/He mice concluded that AZT has a direct toxic effect on the developing mouse embryo (Toltzis et al., 1991). Female mice were exposed to 0, 0.25, 0.5, or 2.5 mg AZT/mL drinking water for 8 weeks during mating and throughout gestation. All AZT groups had fewer pregnant mice per group, fewer pups per litter, and increased resorptions per mouse. Dose-related embryolethality was observed.

Since AIDS is a disease of immune suppression, the majority of AIDS patients actually die from characteristic opportunistic infections (Hardy, 1991; Harkins and Herriot, 1992), and the treatment of AIDS is increasingly one of combination therapy of anti-AIDS drugs and anti-infective drugs (Goldschmidt and Dong, 1992). The most common opportunistic infection and the leading cause of death in AIDS patients is Pneumocystis carinii pneumonia (PCP), which is found in 60% to 80% of AIDS patients (Harkins and Herriott, 1992).

Although drugs that are very active against pneumocystis are available, they are associated with a high incidence of adverse reactions in AIDS patients, requiring withdrawal of therapy in as many as 50% of cases. Trimethoprim (TMP) in combination with sulfamethoxazole (SMX), designated as cotrimoxazole (TMP/SMX), is an example of a PCP therapy that is highly effective. TMP is a potent and selective competitive inhibitor of microbial dihydrofolate reductase, the enzyme that reduces dihydrofolate to tetrahydrofolate. TMP is, therefore, a folic acid antagonist. The microbial dihydrofolate reductase enzyme system is 50,000 times more sensitive to TMP than the mammalian enzyme system.

In humans, TMP is absorbed almost completely after oral administration, and levels are detectable in the bloodstream after 5 minutes (Gleckman et al., 1981; Salter, 1982). Peak serum concentrations of 2 to 4 μg/mL are achieved within 1 to 4 hours. The mean peak level of TMP is approximately 1.5 μg/mL. This concentration decreases to 0.75 to 1.0 μg/mL after 12 hours. The presence of food in the stomach does not appear to delay absorption. Effective levels of TMP persist in the blood for up to 24 hours after a therapeutic dose (100 mg TMP every 12 hours). Absorption in children does not appear to differ from that in adults. Steady-state serum concentrations occur within 72 hours of daily TMP administration (100 mg every 12 hours for 10 days). Approximately 85% to 90% of plasma TMP exists as the intact compound, 45% bound to protein (primarily albumin). TMP is absorbed completely from the gastrointestinal tract, resulting in minimal fecal excretion (Schwartz and Ziegler, 1969).

TMP is a weak base, with a pKa of 7.3, and is lipophilic (Salter, 1982). The compound is widely distributed in the body after oral administration; the volume of distribution of TMP is 14 to 21 L. This compound achieves therapeutic concentrations in body fluids (e.g., saliva, sputum, vaginal fluid, prostatic secretions, pleural effusions, aqueous humor, bile, and cerebrospinal fluid) and organs (e.g., skin, liver, lung, testis, and kidney). Amniotic fluid, cord blood, and fetal tissue concentrations approximate 50% to 75% of the maternal serum concentrations (Ylikorkala et al., 1973; Reid et al., 1975). TMP enters breast milk, but the significance of this observation remains undefined (Miller and Salter, 1973). Rieder (1973) has described the complex pharmacokinetic behavior of TMP in bile, where concentrations generally exceed those needed for therapeutic activity.

The elimination half-life value for TMP is 10 to 14 hours in adults and 2.5 to 6 hours in children with normal renal function (Gleckman et al., 1981). Urinary concentrations of TMP vary considerably, ranging from 10.9 to 206 μg/mL (Gleckman et al., 1979). Renal insufficiency prolongs the elimination half-life, reduces urinary concentrations, and augments the serum concentrations of intact TMP (Bergan et al., 1979). The clearance of TMP is not affected by the urine flow rate but is increased by lowering of the urine pH (Salter, 1982). Bergan and Brodwall (1972) showed that TMP is subject to passive nonionic tubular diffusion at pH values above 7.0.

Urinary excretion of TMP declines when the creatinine clearance is reduced below 30 mL/min (Sharpstone, 1969). However, even with advanced renal disease, urinary concentrations of TMP exceed the minimum inhibitory concentrations (MICs) for most urinary pathogens. Abnormal serum concentrations of TMP have not been experienced by patients with liver disease (Follath, 1979).

TMP can inhibit the elimination of creatinine by the kidney, thereby causing elevated serum creatinine concentrations (Berglund et al., 1975). The compound also interferes with the chemical analysis of serum creatinine.

Five metabolites of TMP have been found in dogs, rats, and humans (Sigel et al., 1973). Two of these metabolites are conjugated in both plasma and urine, whereas two others are conjugated and excreted in the urine, essentially in the form of glucuronides. Schwartz and Rieder (1970) reported that unchanged TMP accounted for 77.5% of compound-related radioactivity in 24-hour cumulative urine samples. Sigel and Brent (1973) reported a lower figure of 46%. The simultaneous administration of SMX does not alter the metabolic fate of TMP (Salter, 1982).

The concentration of unchanged TMP in the feces after daily doses of 0.5 or 1.0 g is usually about 1.0 μg/g feces (Romankiewicz, 1974). Studies with radiolabeled TMP indicate that less than 4% of the compound is found in human feces for at least 6 days after oral administration.

Sulfonamides, which are frequently used in combination with TMP, are structural analogs and competitive antagonists of para-aminobenzoic acid (PABA) and hence prevent the normal utilization of PABA for the synthesis of folic acid (pteroylglutamic acid) (Woods, 1940). The term sulfonamide is used in this report as a generic name for derivatives of PABA (i.e., sulfanilamide and sulfamethoxazole). More specifically, sulfonamides are competitive inhibitors of dihydropteroate synthase, the microbial enzyme responsible for the incorporation of PABA into dihydropteroic acid, the immediate precursor of folic acid. Sensitive microorganisms are those that must synthesize their own folic acid; microorganisms that can utilize preformed folate are not affected. Bacteriostasis induced by sulfonamides is competitively counteracted by PABA. Sulfonamides do not affect mammalian cells by this mechanism, since mammalian cells require preformed folic acid and cannot synthesize it. Mammalian cells are, therefore, comparable to sulfonamide-insensitive microorganisms that utilize preformed folate.

SMX is a sulfonamide that is frequently used in combination with TMP. SMX is a weak acid, with a pKa of 6.0, and is fairly well distributed; however, after an orally administered dose as a 1:5 ratio of TMP/SMX, the concentration of active SMX in tissue fluids is relatively lower than that of TMP (Salter, 1982). The concentration of active SMX in aqueous humor (Salmon et al., 1975), bile (Rieder et al., 1974), cerebrospinal fluid (Nicholls, 1972), sputum (Hughes, 1979), and interstitial fluid (Chisholm et al., 1973) is approximately 25% to 30% of the corresponding concentration in plasma. The lungs (Hausen et al., 1973) and kidneys (Craig and Kunin, 1973) contain especially high concentrations of SMX. Since renal tissue is usually contaminated with urine, it contains levels similar to those in urine, normally about 30 times the level in plasma (Salter, 1982). Levels in bone are adequate for antibacterial activity. Levels of SMX, however, are generally lower in tissues than in plasma (Schwartz and Rieder, 1970; Craig and Kunin, 1973).

The percentages of protein-bound SMX at total plasma concentrations of 91 and 253 μg/mL were 67.8% and 59%, respectively (Salter, 1982). At similar concentrations of N^4^-acetylsulfamethoxazole, 79.9% and 61% of the compound was bound. For pharmacokinetic calculations, 60% binding is a satisfactory approximation. The addition of SMX to plasma reduced the binding of TMP by 3% to 4%, but the protein binding of SMX was unchanged by TMP at therapeutically attainable concentrations of the two compounds (Schwartz and Ziegler, 1969).

The half-lives of TMP and SMX in plasma are not significantly different after single or multiple doses (Salter, 1982). The mean half-life of TMP is 10.1 ± 0.6 hours (mean ± standard error, n=36), and that of SMX is 11.4 ± 0.9 hours. The half-life of SMX in infants during the first 10 days of life is considerably longer than in adults. The half-life falls rapidly, however, being about 9 hours at 3 weeks of age and 4 to 5 hours at 1 year. It then increases toward the half-life characteristic for adults (approximately 10 to 12 hours).

SMX is primarily excreted by the kidneys, and high concentrations of the active compound are found in the urine (Schwartz and Rieder, 1970). It is excreted partly unchanged and partly as metabolites. About 60% of orally ingested SMX is excreted in the urine within 48 hours. Of the excreted compound, approximately half is N^4^-acetylsulfamethoxazole, one-fifth is the N^4^ conjugate, one-sixth is the unchanged parent compound, and one-tenth is another N^4^ free compound (Bagdon, 1964).

Renal clearance of SMX increases with a rising flow rate; it is independent of urine pH when this value is below 7.0 but increases with a rising pH at values above 7.0 (Salter, 1982). In patients with renal impairment, the clearance of SMX is not significantly affected; however, the clearance of N^4^-acetylsulfamethoxazole is prolonged in those with severe renal failure.

The clinical reasons for coadministration of TMP and SMX at a ratio of 1:5 are not entirely clear (Salter, 1982). However, Kremers et al. (1974) showed that in five healthy subjects receiving two tablets of TMP/SMX daily for 9 days, the ratio of the concentrations of TMP to that of active SMX in plasma was between 1:15 and 1:22. These plasma ratios are within the range in which the potentiation of antibacterial activity is optimal for most bacterial species (Bushby, 1973). Nevertheless, the 1:5 ratio is somewhat arbitrary, because the responses of individual organisms vary and the optimal ratio differs from species to species.

The pharmacokinetic profiles of TMP and SMX are closely but not perfectly matched to achieve a constant ratio of 1:20 in their concentrations in blood and tissues. The ratio in blood is often greater than 1:20 and that in tissues is frequently less. After a single oral dose of the combined preparation, TMP is absorbed more rapidly than SMX. The concurrent administration of the compounds appears to diminish the absorption of SMX. Peak blood levels of TMP usually occur within 2 hours in most patients, while peak concentrations of SMX occur within 4 hours after a single oral dose. As pointed out earlier, the half-lives of TMP and SMX are approximately 11 and 10 hours, respectively.

The clinical dose for treatment of PCP in AIDS patients is 20 mg TMP/kg body weight in combination with 100 mg SMX/kg body weight (Wofsy, 1987). The therapeutic dose for effective treatment of rats with experimental PCP is 50 mg/kg TMP administered in drinking water in combination with 250 mg/kg SMX (Hughes and Smith, 1984). Nguyen and Stadtsbaeder (1985) have reported that the therapeutic dose in mice for toxoplasmosis is 153 mg/kg TMP administered in drinking water in combination with 769 mg/kg SMX for 42 days. No toxic effects in the treated mice were reported.

In general, studies of chronic toxicity have not suggested many problems related to clinical use. One noteworthy point is that hypersensitivity reactions cannot be predicted in studies with animals. Prolonged administration (6 months) of relatively large doses of TMP (100 to 300 mg/kg) and SMX (100 to 1,200 mg/kg) to animals does affect blood-forming elements in bone marrow. This effect is probably caused by TMP (Salter, 1982).

Daily doses of 100 or 300 mg/kg TMP plus doses of 100 or 600 mg/kg SMX given by oral gavage to male and female rats for 6 months caused a decrease in body weight. Two of 20 rats in the low dose group and nine of 20 rats in the high dose group did not survive the 6-month study. Although the blood chemistry of the rats was normal, the white blood cell count, red blood cell count, and platelet count fell significantly (Salter, 1982).

In another study, Wistar rats and Patas monkeys received oral gavage doses of 300 mg/kg TMP plus 1,200 mg/kg SMX daily for 6 months. There was a decrease in white blood cell counts, but not platelets, at 1 month; by 6 months, bone marrow hypoplasia had occurred. Even severe changes were reversed when use of the test compounds was discontinued (Udall, 1969).

Of six monkeys that received 300 mg/kg TMP plus 600 mg/kg SMX, five had marked decreases in platelet count; in addition, four exhibited decreases in red blood cell and white blood cell counts. These animals also had an increased concentration of blood urea nitrogen, and one had an increased activity of aspartate aminotransferase in serum. Administration of folinic acid (2 mg/kg orally) reduced hematologic toxicity (Salter, 1982).

Swarm et al. (1973) reported that Charles River CD rats treated continuously with SMX or with TMP/SMX in the diet developed metastasizing thyroid carcinomas after 52 to 60 weeks. Treatment of rats with TMP for the same interval did not have this effect, nor did treatment of monkeys with TMP, SMX, or TMP/SMX for this period. Previous work (Udall, 1969) described a goitrogenic effect in rats with shorter-term administration (an effect already known to be caused by other sulfonamides) but no carcinomas (MacKenzie and MacKenzie, 1943). Since this pathologic effect is not seen in hypophysectomized animals, the thyroid hyperplasia appears to result from hyperproduction of thyroid-stimulating hormone secondary to long-term depression of thyroid function. This finding appears to be species specific and is unlikely to be of clinical importance in humans (Salter, 1982).

There is a paucity of studies reported on the reproductive toxicity of TMP in the mouse. Timmermans (1974) reported that eight daily doses of 100 mg/kg TMP (route not specified) in the rat resulted in incomplete or stoppage of spermatogonia divisions and perturbed meiosis in most spermatocytes. In addition, Kreutz (1981) reported that 750 to 1,500 mg/kg TMP given daily to pregnant rats from day 5 to day 13 of gestation resulted in toxicity in the mother as well as the fetus, including increased resorption rates, decreased fetal body weight, and skeletal anomalies that were “typical effects of folic acid antagonists.”

The oral lethal dose causing 50% mortality (LD_50_) values for TMP and SMX in mice is difficult to calculate because it is impossible to administer sufficient amounts of the two compounds to the animals (Salter, 1973). However, Yamamoto et al. (1973) calculated the LD_50_ to be 7,100 mg/kg TMP and 4,100 mg/kg SMX. The acute toxicity of these compounds is clearly very low (Salter, 1982). Reported mouse oral LD_50_ values for TMP/SMX (1:5) are 5,513 mg/kg (Merck Index, 1989) and 3,740 mg/kg (RTECS, 1989).

## Study Rationale

It is well documented in the literature that AZT administration, folate deficiency, and vitamin B_12_ deficiency all result in the inhibition of DNA synthesis with similar morphological manifestations such as macrocytosis, anemia, and granulcytopenia, and it was previously mentioned that TMP/SMX is an antifolate drug (Walzer et al., 1988). The changing etiology of macrocytosis in humans was discussed by Snower and Weil (1993). Whereas vitamin B_12_ and folic acid deficiency were previously quite significant in the etiology of macrocytosis, therapy with AZT is currently the leading cause of this condition in humans. Revell et al. (1991) demonstrated that absorption of folic acid was significantly impaired in HIV disease. Israel and Plaisance (1991) stated that bone marrow toxicity occurs more often and is enhanced in patients receiving AZT therapy if they have low serum vitamin B_12_ levels or low normal serum folic acid levels. Herzlich et al. (1990), studying human bone marrow cells in vitro, stated that some of what passes for “AZT damage” to bone marrow cells may in fact be coincident deficiency of vitamin B_12_ and that whether folate or vitamin B_12_ supplementation may partially overcome apparent “AZT inhibition” of DNA synthesis (hematologic toxicity) will require further study.

The objective of this study was to obtain controlled data on the general, reproductive, and developmental toxicity of AZT and TMP/SMX when administered in combination and to determine if supplementation with folinic acid would prevent or diminish toxicity. Folinic acid, also known as leucovorin, is a stable form of N^5^-formyl-H_4_ folate that can be used for administration of reduced folate (Stokstad and Koch, 1967). A study in rodents would provide useful information on the safety of the therapies (AZT, TMP/SMX, and folinic acid) used in AIDS treatment. The Swiss (CD-1®) mouse chosen for this study is one of the mouse models routinely used for evaluation of reproductive and developmental toxicity. The animal model used in this study was not folate deficient and lacks the variable of a viral infection that compromises the immune system.

Male and female Swiss (CD-1®) mice were treated orally with AZT (200 or 400 mg/kg) alone, with TMP/SMX (1,000, 2,000, or 3,000 mg/kg) alone, or with combinations of AZT and TMP/SMX. Selected AZT doses were two and four times the human therapeutic dose of 10 mg/kg per day (PDR, 1994; Freireich et al., 1966), and TMP/SMX doses were one, two, and three times the therapeutic dose in mice for treatment of toxoplasmosis (Nguyen and Stadtsbaeder, 1985). Selected groups were supplemented with folinic acid (10 mg/kg), which is equivalent to 100 times the minimum daily requirement of folic acid for the mouse (NRC, 1978). Because folinic acid is an active form of folic acid, it was predicted that supplementation might decrease the toxicity associated with TMP and SMX, which inhibit the synthesis or action of folic acid. Adult mice were evaluated for clinical findings, mean body weights, sperm function, pathology, and clinical pathology parameters. Offspring were evaluated for viability, external abnormalities, and mean body weights.