# APPENDIX B Reproductive Tissue Evaluations

TABLE B1 Summary of Reproductive Tissue Evaluations in Male Swiss (CD-1®) Mice in the Reproductive, Developmental, and Genera] Toxicity Study of AZT, TMP/SMX, and Folinic Acid^a^

| Vehicle Control | 0 + 0 + 10^b^ | 200 + 0 + 0 | 400 + 0 + 0 | 400 + 0 + 10^b^ | 0 + 2,000 + 10^b^ | 200 + 2,000 + 0 | 400 + 2,000 + 0 | 400 + 2,000 + 10^b^
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 9
Weights (g)
Necropsy body wt | 34 38 ± 0 99 | 34 50 ± 1 24 | 34 44 ± 1 06 | 34 07 ± 1 09 | 33 72 ± 0 78 | 34 45 ± 0 88 | 35.42 ± 0 88 | 34.64 ± 0.75 | 34 46 ± 1.28
L cauda^c^ | 0 019 ± 0 001 | 0 021 ± 0 001 | 0 021 ± 0 001 | 0 022 ± 0 001^d^ | 0 019 ± 0 001 | 0.021 ± 0.001 | 0 023 ± 0.002 | 0.021 ± 0 001 | 0.022 ± 0.001
L testis | 0 112 ± 0 004 | 0 121 ± 0 007 | 0 119 ± 0 004 | 0 109 ± 0 005^d^ | 0 119 ± 0 005^d^ | 0.108 ± 0.004^*^,^g^ | 0 101 ± 0.005^*^,^g^ | 0.101 ± 0.004^*^,^g^ | 0.105 ± 0.004^*^,^g^
Spermatid heads (10^7^/testis) | 1 57 ± 0 06 | 1 68 ± 0 07 | 1 60 ± 0 09 | 1 56 ± 0 10^d^ | 1 71 ± 0 05^d^ | 1 44 ± 0.05^h^ | 1 40 ± 0.09” | 1.45 ± 0.08^h^ | 1.49 ± 0.07^h^
Epididymal spermatozoal motility (%) | 86 52 ± 1 40 | 85 80 ± 0 95^d^ | 62 65 ± 8 17^*^,^e^ | 38 73 ± 11 59^*^,^d,e^ | 60 05 ± 12 01 | 59.85 ± 7 93 | 44 46 ± 10.16^*^,^e^ | 19.50 ± 8.00^*^,^e^ | 17.21 ± 4.05
| | 0 + 1,000 + 0 | 200 + 1,000 + 0 | 400 + 1,000 + 0 | 0 + 2,000 + 0 | 0 + 3,000 + 0 | 0 + 3,000 + 10 ^b^ | 200 + 3,000 + 0 | 400 + 3,000 + 0
n | | 10 | 10 | 10 | 9 | 8 | 10 | 10 | 7
Weights (g)
Necropsy body wt | | 35 03 ± 1 11 | 34 35 ± 1 18 | 33 81 ± 0 91 | 35 21 ± 0 94 | 33.95 ± 0.82 | 35.42 ± 0.84 | 32 05 ± 1.16 | 32.09 ± 0.98
L cauda^c^ | | 0 020 ± 0 001 | 0 020 ± 0 001 | 0 019 ± 0 001 | 0 023 ± 0 001 | 0.022 ± 0.001 | 0.019 ± 0 001 | 0 020 ± 0 001 | 0.018 ± 0.001
L testis | | 0 102 ± 0 003^*^,^g^ | 0 106 ± 0 004^*^,^g^ | 0 112 ± 0 006^*^,^g^ | 0 109 ± 0 005^*^,^g^ | 0 108 ± 0.004^*^,^g^ | 0.102 ± 0.005^*^,^g^ | 0.108 ± 0.006^*^,^g^ | 0.094 ± 0.002^*^,^g^
Spermatid heads (10^7^/testis) | | 1 49 ± 0 08^h^ | 1 46 ± 0 05^h^ | 1 54 ± 0 08^d^ ^h^ | 1 35 ± 0 08^f,h^ | 1 37 ± 0 11^h^ | 1 47 ± 0.07^h^ | 1 50 ± 0.05^h^ | 1.44 ± 0.04^h^
Epididymal spermatozoal motility (%) | | 79 50 ± 2 17^d^ | 28 65 ± 11 12^*^,^e^ | 51 89 ± 10 00^*^,^d,e^ | 66 27 ± 9 03^*^,^e^ ^f^ | 66 44 ± 9.89^*^,^e^ | 68 25 ± 8.44 | 3.50 ± 1.04^*^,^e^ | 44.26 ± 14.28^*^,^e^

* Significantly different (P≤0.05) from the vehicle control group by Williams’ or Dunnett’s test

a Daily gavage doses are given as AZT + TMP/SMX + folinic acid (mg/kg per day). Data are given as mean ± standard error

b Folinic acid did not influence fertility parameters with either AZT, TMP/SMX, or combinations.

c All values showed a significant interaction of all three chemicals (P=0.01) by a two-way analysis of variance, indicating the dose response relationship of AZT differs across doses of TMP/SMX and folinic acid.

d n=9

e Significantly different (P≤0 01) from the vehicle control group by Williams’ or Dunnett’s test for the 200 and 400 mg/kg AZT and the 2,000 and 3,000 mg/kg TMP/SMX groups when data were collapsed over levels of TMP/SMX + folinic acid exposure and AZT + folinic acid exposure, respectively

f n=10

g Significantly different (P≤0.01) from the vehicle control group by Williams’ or Dunnett’s test for the 1,000, 2,000, and 3,000 mg/kg TMP/SMX groups when data were collapsed over levels of AZT + folinic acid exposure.

h Significantly different from the vehicle control group by Williams’ or Dunnett’s test for the 1,000 mg/kg TMP/SMX group (P≤0.05) and the 2,000 and 3,000 mg/kg TMP/SMX groups (P≤0 01) when data were collapsed over levels of AZT + folinic acid exposure