# APPENDIX A Clinical Pathology Results

TABLE A1 Hematology and Clinical Chemistry Data for Male Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid^a^

| Vehicle Control | 0 + 0 + 10 | 200 + 0 + 0 | 400 + 0 + 0 | 400 + 0 + 10 | 0 + 1,000 + 0 | 200 + 1,000 + 0 | 400 + 1,000 + 0 | 0 + 2,000 + 0 | 0 + 2,000 + 10 | 200 + 2,000 + 0 | 400 + 2,000 + 0 | 400 + 2,000 + 10 | 0 + 3,000 + 0 | 0 + 3,000 + 10 | 200 + 3,000 + 0 | 400 + 3,000 + 0
n | 10 | 10 | 10 | 10 | 10 | 10 | 9 | 10 | 9 | 10 | 10 | 10 | 9 | 8 | 10 | 10 | 7
Hematology
Hematocrit (%) | 45 5 ± 3 9 | 46 6 ± 3 9 | 39 3 ± 5 7 | 33 6 ± 7 7^**^ | 37 8 ± 5 8^*^ | 44 0 ± 3 3 | 25 9 ± 7 4^**^ | 23 3 ± 8 0^**^ | 41 5 ± 3 0 | 41 9 ± 2 7 | 21 2 ± 3 9^**^ | 17 5 ± 3 8^**^ | 16 2 ± 3 2^**^ | 37 4 ± 2 2^**^ | 39 3 ± 2 5^**^ | 17 4 ± 2 5^**^ | 16 7 ± 4 0^**^
Hemoglobin (g/dL) | 15 4 ± 1 4 | 15 8 ± 1 2 | 13 3 ± 1 6 | 11 4 ± 2 5^**^ | 12 8 ± 1 5^**^ | 14 8 ± 1 2 | 8 8 ± 2 2^**^ | 8 2 ± 2 5^**^ | 13 9 ± 1 1 | 14 0 ± 1 1^*^ | 7 6 ± 1 3^**^ | 6 1 ± 1 2^**^ | 5 8 ± 1 1^**^ | 12 5 ± 0 9^**^ | 13 0 ± 1 0^**^ | 6 2 ± 0 9^**^ | 5 9 ± 1 3^**^
Erythrocytes (10^6^/μL) | 9 96 ± 1 07 | 9 90 ± 0 82 | 7 98 ± 1 02^**^ | 6 79 ± 1 42^**^ | 7 84 ± 0 84^**^ | 9 58 ± 1 00 | 5 39 ± 1 13^**^ | 5 09 ± 1 22^**^ | 8 88 ± 0 63 | 8 85 ± 1 04^*^ | 4 85 ± 0 83^**^ | 3 97 ± 0 80^**^ | 3 79 ± 0 66^**^ | 8 01 ± 0 50^**^ | 8 13 ± 0 42^**^ | 4 12 ± 0 59^**^ | 3 95 ± 0 88^**^
Reticulocytes (10^5^/μL) | 4 3 ± 1 28^b^ | 4 2 ± 0 45 | 3 5 ± 0 96 | 3 2 ± 1 60 | 3 4 ± 0 96 | 5 0 ± 1 50 | 2 8 ± 2 04 | 2 1 ± 1 60^**^,^b^ | 5 2 ± 1 26 | 5 2 ± 1 67 | 1 3 ± 0 53^**^,^b^ | 1 2 ± 0 61^**^ | 0 9 ± 0 30^**^ | 5 1 ± 1 41^d^ | 5 4 ± 1 40 | 1 6 ± 1 05^**^,^b^ | 1 2 ± 0 41^**^
Mean cell volume (fL) | 45 9 ± 3 5 | 47 0 ± 2 1 | 49 1 ± 2 7 | 49 2 ± 3 6 | 48 0 ± 3 4 | 46 1 ± 2 5 | 47 4 ± 4 5 | 45 0 ± 4 1 | 46 8 ± 2 2 | 47 7 ± 3 8 | 43 7 ± 2 6 | 44 0 ± 2 4 | 42 9 ± 2 2 | 46 7 ± 2 0 | 48 5 ± 3 8 | 42 3 ± 1 9^*^ | 42 1 ± 2 1^*^
Mean cell hemoglobin (pg) | 15 5 ± 1 0 | 15 9 ± 07 | 16 7 ± 0 8^*^ | 16 7 ± 0 8^*^ | 16 3 ± 0 9 | 15 5 ± 0 8 | 16 3 ± 1 2 | 16 0 ± 1 0 | 15 6 ± 0 7 | 15 9 ± 1 0 | 15 6 ± 07 | 15 5 ± 07 | 15 2 ± 07 | 15 6 ± 0 6 | 16 0 ± 1 1 | 15 2 ± 0 8 | 14 9 ± 0 6
Mean cell hemoglobin concentration (g/dL) | 33 8 ± 1 4 | 33 9 ± 0 9 | 34 0 ± 1 3 | 34 0 ± 1 9 | 34 1 ± 1 3 | 33 7 ± 0 9 | 34 4 ± 1 8 | 35 5 ± 1 5 | 33 4 ± 1 1 | 33 4 ± 0 9 | 35 8 ± 1 3^**^ | 35 3 ± 1 0^*^ | 35 5 ± 1 3^*^ | 33 4 ± 1 1 | 33 0 ± 1 3 | 35 8 ± 0 9^**^ | 35 4 ± 1 1^*^
Platelets (10^3^/μL) | 1,094 ± 250 5 | 979 ± 206 2 | 1,161 ± 350 9 | 1,517 ± 314 0^*^ | 1,353 ± 402 7 | 1,010 ± 191 9 | 1,708 ± 450 1^**^ | 1,595 ± 448 0^**^ | 1,082 ± 278 5 | 1,252 ± 450 4 | 1,717 ± 353 0^**^ | 1,818 ± 434 2^**^ | 1,761 ± 423 4^**^ | 1,397 ± 358 9 | 1,360 ± 198 9 | 2,077 ± 740 5^**^ | 1,866 ± 289 9^**^
Leukocytes (10^3^/μL) | 7 25 ± 1 93 | 8 78 ± 3 13 | 5 99 ± 1 48 | 5 82 ± 2 51 | 5 77 ± 2 31 | 8 28 ± 2 91 | 5 86 ± 2 88 | 5 19 ± 1 95 | 8 00 ± 3 04 | 8 05 ± 2 80 | 5 07 ± 1 81 | 5 53 ± 2 14 | 5 42 ± 1 97 | 5 87 ± 1 95 | 8 02 ± 3 53 | 3 71 ± 1 49 | 3 64 ± 1 46
Segmented neutrophils (10^3^/μL) | 1 22 ± 0 40 | 1 28 ± 0 59 | 0 61 ± 0 25^*^ | 0 76 ± 0 53 | 0 63 ± 0 37^*^ | 1 47 ± 0 53 | 0 46 ± 0 25^**^ | 0 45 ± 0 46^**^ | 1 29 ± 0 48 | 1 87 ± 1 14 | 0 51 ± 0 17^*^ | 0 38 ± 0 29^**^ | 0 27 ± 0 11^**^ | 1 75 ± 0 50 | 1 79 ± 0 63 | 0 69 ± 0 38 | 0 73 ± 0 56
Lymphocytes (10^3^/μL) | 5 65 ± 1 73 | 7 04 ± 2 53 | 5 10 ± 1 35 | 4 76 ± 2 01 | 4 85 ± 1 92 | 6 41 ± 2 62 | 5 10 ± 2 52 | 4 51 ± 1 55 | 6 26 ± 2 56 | 5 66 ± 1 95 | 4 25 ± 1 78 | 4 94 ± 2 06 | 5 01 ± 1 95 | 3 62 ± 1 57 | 5 65 ± 3 04 | 2 81 ± 1 65^*^ | 2 79 ± 1 26^*^
Monocytes (10^3^/μL) | 0 15 ± 0 08 | 0 18 ± 0 13 | 0 11 ± 0 07 | 0 14 ± 0 11 | 0 09 ± 0 05 | 0 19 ± 0 05 | 0 14 ± 0 11 | 0 10 ± 0 12 | 0 25 ± 0 10 | 0 29 ± 0 17^**^ | 0 11 ± 0 05 | 0 06 ± 0 04 | 0 05 ± 0 02 | 0 29 ± 0 09^*^ | 0 34 ± 0 14^**^ | 0 10 ± 0 07 | 0 05 ± 0 06
Basophils (10^3^/μL) | 0 02 ± 0 011 | 0 03 ± 0 020 | 0 01 ± 0 008 | 0 02 ± 0 011 | 0 01 ± 0 013 | 0 03 ± 0 017 | 0 01 ±0 012 | 0 01 ± 0 009 | 0 03 ± 0 018 | 0 03 ± 0 016 | 0 02 ± 0 027 | 0 01 ± 0 008 | 0 01 ± 0 012 | 0 03 ± 0 020 | 0 03 ± 0 017 | 0 01 ± 0 012 | 0 01 ± 0 011
Eosinophils (10^3^/μL) | 0 18 ± 0 14 | 0 23 ± 0 14 | 0 15 ± 0 09 | 0 14 ± 0 10 | 0 16 ± 0 09 | 0 15 ± 0 10 | 0 13 ± 0 13 | 0 10 ± 0 10 | 0 13 ± 0 12 | 0 15 ± 0 12 | 0 13 ± 0 07 | 0 09 ± 0 14 | 0 05 ± 0 03^*^ | 0 13 ± 0 11 | 0 17 ± 0 08 | 0 05 ± 0 05^*^ | 0 02 ± 0 01^**^
Large unstained cell (10^3^/μL) | 0 03 ± 0 02^b^ | 0 03 ± 0 03^c^ | 0 02 ± 0 01^d^ | 0 02 ± 0 02^c^ | 0 02 ± 0 02^b^ | 0 04 ± 0 02^b^ | 0 03 ± 0 02^d^ | 0 03 ± 0 02^c^ | 0 05 ± 0 03^*^,^c^ | 0 05 ± 0 04^b^ | 0 06 ± 0 07^b^ | 0 07 ± 0 08^c^ | 0 03 ± 0 02^c^ | 0 06 ± 0 05 | 0 05 ± 0 02^c^ | 0 06 ± 0 04^b^ | 0 05 ± 0 03^f^
Clinical Chemistry
Urea nitrogen (mg/dL) | 18 3 ± 3 0 | 20 8 ± 2 8 | 17 0 ± 3 3 | 21 8 ± 3 2 | 19 9 ± 5 8 | 21 3 ± 27 | 17 7 ± 3 4^e^ | 17 0 ± 1 5^b^ | 20 0 ± 3 8 | 18 7 ± 3 9 | 19 7 ± 4 4 | 18 6 ± 3 0 | 18 6 ± 4 3 | 20 2 ± 3 5 | 21 7 ± 4 0 | 19 4 ± 5 6 | 19 2 ± 5 4
Creatinine (mg/dL) | 0 26 ± 0 09 | 0 31 ±0 12 | 0 31 ± 0 10 | 0 28 ± 0 07 | 0 31 ±0 11 | 0 30 ± 0 07 | 0 28 ± 0 08^e^ | 0 28 ± 0 05^b^ | 0 36 ± 0 17 | 0 32 ± 0 11 | 0 36 ± 0 10 | 0 30 ± 0 10 | 0 39 ± 0 08 | 0 41 ± 0 16 | 0 38 ± 0 20 | 0 68 ± 0 31^**^ | 0 61 ± 0 12^**^
Alanine aminotransferase (IU/L) | 21 ± 14 | 22 ± 10 | 19 ± 14 | 14 ± 4 | 22 ± 16 | 26 ± 13 | 14 ± 6^e^ | 23 ± 17^b^ | 34 ± 19 | 28 ± 19 | 31 ± 15 | 22 ± 12 | 26 ± 13 | 100 ± 59^**^ | 53 ± 27^*^ | 51 ± 33 | 42 ± 24
Alkaline phosphatase (IU/L) | 46 ± 22 | 39 ± 14 | 51 ± 41 | 50 ± 28 | 35 ± 12 | 36 ± 11 | 31 ± 15^e^ | 31 ± 7^b^ | 37 ± 14 | 30 ± 11 | 38 ± 15 | 26 ± 10^*^ | 29 ± 15 | 15 ± 7^**^ | 31 ± 13 | 30 ± 22 | 22 ± 8^**^
Aspartate aminotransferase (IU/L) | 53 ± 17 | 57 ± 21 | 57 ± 16 | 71 ± 29 | 59 ± 28 | 53 ± 10 | 53 ± 19^e^ | 64 ± 30^b^ | 46 ± 11 | 67 ± 30 | 61 ± 20 | 54 ± 19 | 45 ± 13 | 66 ± 21 | 67 ± 33 | 58 ± 25 | 55 ± 30

* Significantly different (P≤0.05) from the vehicle control group by Dunnett’s test

** P≤0 01

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day). Data are given as mean ± standard error. Statistical tests were performed on unrounded data

b n = 9

c n = 8

d n = 7

e n = 10

f n = 6

TABLE A2 Hematology and Clinical Chemistry Data for Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid^a^

| Vehicle Control | 0 + 0 + 10 | 200 + 0 + 0 | 400 + 0 + 0 | 400 + 0 + 10 | 0 + 1,000 + 0 | 200 + 1,000 + 0 | 400 + 1,000 + 0 | 0 + 2,000 + 0 | 0 + 2,000 + 10 | 200 + 2,000 + 0 | 400 + 2,000 + 0 | 400 + 2,000 + 10 | 0 + 3,000 + 0 | 0 + 3,000 + 10 | 200 + 3,000 + 0 | 400 + 3,000 + 0
n | 20 | 20 | 20 | 20 | 19 | 19 | 20 | 20 | 20 | 17 | 13 | 12 | 12 | 17 | 16 | 4 | 2
Hematology
Hematocrit (%) | 42 7 ± 2 1 | 42 3 ± 3 1 | 35 5 ± 8 9^**^ | 29 5 ± 12 0^**^ | 29 6 ± 10 5^**^ | 42.1 ± 3.9 | 14.9 ± 8.5^**^ | 9.1 ± 1.3^**^ | 39.8 ± 4.1 | 40 4 ± 3 3 | 11 6 ± 7 1^**^ | 11 6 ± 9 5^**^ | 8 4 ± 1 1^**^ | 38 1 ± 3 3^*^ | 38 7 ± 4 5 | 11 5 ± 2 8^**^ | 9 9 ± 0 6^**^
Hemoglobin (f/dL) | 14 6 ± 0 9 | 14 4 ± 1 2 | 11 9 ± 2 7^**^ | 9 8 ± 3 7^**^ | 10 0 ± 3 3^**^ | 14.5 ± 1.4 | 5.1 ± 2.6^**^ | 3.4 ± 0.5^**^ | 13.5 ± 1.5 | 13 9 ± 1 0 | 4 2 ± 2 3^**^ | 4 1 ± 2 8^**^ | 3 2 ± 0 4^**^ | 12 9 ± 1 1^**^ | 13 2 ± 1 6^*^ | 4 3 ± 0 8^**^ | 3 8 ± 0 4^**^
Erythrocytes (10^6^/μL) | 8 64 ± 0 49 | 8 65 ± 0 54 | 6 26 ± 1 42^**^ | 5 27 ± 1 77^**^ | 5 32 ± 1 55^**^ | 8.78 ± 0.92 | 2.94 ± 1.24^**^ | 2.16 ± 0.33^**^ | 8.00 ± 0.90 | 8 04 ± 0 68 | 2 49 ± 1 17^**^ | 2 40 ± 1 36^**^ | 2 00 ± 0 30^**^ | 7 64 ± 0 66^**^ | 7 68 ± 0 95^**^ | 2 79 ± 0 49^**^ | 2 43 ± 0 13^**^
Reticulocytes (10^5^/μL) | 3 0 ± 0 82 | 3 5 ± 1 24 | 3 4 ± 1 75 | 3 6 ± 2 00 | 3 0 ± 1 38^b^ | 2.9 ± 0.85 | 1.9 ± 2.14^c^ | 0.6 ± 0.51^**^ | 2.8 ± 1.16 | 3 0 ± 1 32^i^ | 1 1 ± 1 63^**^,^j^ | 1 2 ± 1 60^**^,^j^ | 0 4 ± 0 38^**^,^k^ | 2 8 ± 0 78 | 2 8 ± 0 65 | 1 2 ± 0 64^n^ | 0 1^*^,^o^
Mean cell volume (fL) | 49 5 ± 1 4 | 48 9 ± 2 2 | 56 3 ± 6 7^**^ | 54 0 ± 6 7^*^ | 54 3 ± 5 7^**^ | 48.1 ± 2.4 | 48.6 ± 7.1 | 42.4 ± 1.6^**^ | 49.9 ± 2.4 | 50 3 ± 2 7 | 44 7 ± 5 2^**^ | 44 9 ± 8 2^**^ | 42 1 ± 1 3^**^ | 50 0 ± 2 6 | 50 4 ± 2 7 | 40 9 ± 3 0^**^ | 40 7 ± 0 3^*^
Mean cell hemoglobin (pg) | 16 9 ± 0 5 | 16 7 ± 0 8 | 18 9 ± 1 6^**^ | 18 3 ± 1 4^**^ | 18 6 ± 1 4^**^ | 16.6 ± 0.7 | 17.1 ± 1.6 | 15.7 ± 0.7^**^ | 16.9 ± 0.8 | 17 3 ± 1 0 | 16 6 ± 1 0 | 16 6 ± 1 6 | 15 8 ± 0 7^**^ | 169 ± 09 | 17 2 ± 0 8 | 15 3 ± 0 5^*^ | 15 6 ± 1 0
Mean cell hemoglobm concentration (g/dL) | 34 2 ± 0 9 | 34 1 ± 1 3 | 33 8 ± 1 6 | 34 1 ± 2 2 | 34 4 ± 1 7 | 34.5 ± 1.3 | 35.3 ± 2.0 | 36.9 ± 0.9^**^ | 34.0 ± 1.1 | 34 3 ± 1 5 | 37 4 ± 2 2^**^ | 37 5 ± 3 2^**^ | 37 5 ± 1 1^**^ | 33 8 ± 1 1 | 34 1 ± 1 0 | 37 5 ± 1 7^**^ | 38 4 ± 2 1^**^
Platelets (10^3^/μL) | 1,149 ± 279 3 | 1,215 ± 202 2 | 1,325 ± 294 4 | 1,819 ± 647 1^**^ | 1,618 ± 495 1^*^ | 1,005 ± 224.3 | 2,010 ± 559.5^**^ | 1,354 ± 763.2 | 1,303 ± 328.4 | 1,213 ± 275 6 | 1,358 ± 482 8 | 927 ± 711 8 | 746 ± 655 4 | 1,407 ± 371 4 | 1,325 ± 189 6 | 1,382 ± 711 1 | 972 ± 285 0
Leukocytes (10^3^/μL) | 6 69 ± 2 54 | 6 59 ± 1 63 | 4 57 ± 1 69^**^ | 5 00 ± 1 40^*^ | 4 62 ± 1 35^**^ | 6.51 ± 1.82 | 4.09 ± 1.88^**^ | 3.26 ± 1.19^**^ | 6.70 ± 1.55 | 8 30 ± 2 72 | 2 62 ± 1 20^**^ | 2 49 ± 1 23^**^ | 1 56 ± 0 90^**^ | 6 37 ± 2 10 | 6 46 ± 1 77 | 2 18 ± 0 35^**^ | 0 94 ± 0 62^**^
Segmented neutrophils (10^3^/μL) | 1 56 ± 0 79 | 1 84 ± 1 02 | 0 72 ± 0 57^**^ | 0 50 ± 0 36^**^ | 0 51 ± 0 33^**^ | 1.50 ± 0.81 | 0.22 ± 0.18^**^ | 0.08 ± 0.08^**^ | 1.99 ± 0.90 | 2 25 ± 1 68 | 0 09 ± 0 09^**^ | 0 10 ± 0 12^**^ | 0 04 ± 0 03^**^ | 1 79 ± 0 95 | 2 01 ±0 81 | 0 18 ± 0 14^*^ | 0 02 ± 0 01
Lymphocytes (10^3^/μL) | 4 79 ± 2 18 | 4 37 ± 1 14 | 3 59 ± 1 31 | 4 24 ± 1 23 | 3 86 ± 1 23 | 4.60 ± 1.58 | 3.70 ± 1.71 | 3.13 ± 1.15^**^ | 4.29 ± 1.54 | 5 54 ± 2 45 | 2 48 ± 1 16^**^ | 2 33 ± 1 08^**^ | 1 50 ± 0 91^**^ | 4 21 ± 1 81 | 4 08 ± 1 58 | 1 94 ± 0 49^*^ | 0 91 ± 0 59^*^
Monocytes (10^3^/μL) | 0 17 ± 0 08 | 0 19 ± 0 09 | 0 09 ± 0 08^**^ | 0 08 ± 0 06^**^ | 0 08 ± 0 06^**^ | 0.18 ± 0.09 | 0.06 ± 0.05^**^ | 0.01 ± 0.02^**^ | 0.27 ± 0.11^**^ | 0 30 ± 0 15^**^ | 0 01 ± 0 02^**^ | 0 03 ± 0 05^**^ | 0 00 ± 0 01^**^ | 0 28 ± 0 12^**^ | 0 28 ± 0 12^**^ | 0 02 ± 0 03^*^ | 0 00 ± 0 00
Basophils (10^3^/μL) | 0 02 ± 0 016 | 0 02 ± 0 009 | 0 01 ± 0 008^**^ | 0 01 ± 0 007^**^ | 0 01 ± 0 008^**^ | 0.02 ± 0.013 | 0.01 ± 0.008^**^ | 0.01 ± 0.006^**^ | 0.02 ± 0.009 | 0 03 ± 0 016 | 0 00 ± 0 005^**^ | 0 01 ± 0 007 | 0 00 ± 0 007^**^ | 0 02 ± 0 010 | 0 02 ± 0 012 | 0 02 ± 0 022 | 0 00 ± 0 000
Eosinophils (10^3^/μL) | 0 14 ± 0 09 | 0 16 ± 0 11 | 0 14 ± 0 07 | 0 17 ± 0 15 | 0 14 ± 0 13 | 0.19 ± 0.13 | 0.09 ± 0.08 | 0.02 ± 0.04^**^ | 0.11 ± 0.10 | 0 16 ± 0 15 | 0 02 ± 0 02^**^ | 0 02 ± 0 03^**^ | 0 01 ± 0 01^**^ | 0 05 ± 0 05^*^ | 0 05 ± 0 07^*^ | 0 01 ± 0 01^*^ | 0 00 ± 0 00
Large unstained cell (10^3^/μL) | 0 02 ± 0 01^c^ | 0 01 ± 0 01 | 0 01 ± 0 01^d^ | 0 02 ± 0 01^e^ | 0 02 ± 0 01^f^ | 0.02 ± 0.01^g^ | 0.02 ± 0.01^c^ | 0.01 ± 0.01 | 0.01 ± 0.01^c^ | 0 03 ± 0 01^*^ | 0 01 ± 0 01^l^ | 0 01 ± 0 01 | 0 00 ± 0 01^*^,^m^ | 0 02 ± 0 01 | 0 02 ± 0 02 | 0 01 ± 0 01 | 0 00 ± 0 00
Clinical Chemistry
Urea nitrogen (mg/dL) | 15 9 ± 3 4 | 14 6 ± 6 0 | 18 1 ± 4 0^c^ | 18 3 ± 4 5 | 17 3 ± 4 1 | 14.6 ± 3.2^h^ | 17.4 ± 4.6 | 18.1 ± 3.6 | 16.2 ± 3.9 | 15 3 ± 1 7 | 24 1 ± 14 4^f^ | 25 4 ± 20 3^*^ | 24 0 ± 10 9 | 15 1 ± 4 6^b^ | 14 1 ± 1 9 | 18 5 ± 5 0 | 11 6 ± 3 5
Creatinine (mg/dL) | 0 37 ± 0 05 | 0 37 ± 0 06^c^ | 0 33 ± 0 11^c^ | 0 33 ± 0 08 | 0 32 ± 0 09 | 0.37 ± 0.07 | 0.32 ± 0.07 | 0.39 ± 0.09 | 0.53 ± 0.16^**^,^c^ | 0 44 ± 0 12 | 0 56 ± 0 24^**^,^f^ | 0 55 ± 0 19^*^ | 0 64 ± 0 12^**^ | 0 52 ± 0 14^*^,^b^ | 0 56 ± 0 21^**^ | 0 67 ± 0 25^**^ | 0 97 ± 0 00^**^
Alanine aminotransferase (IU/L) | 22 ± 12 | 24 ± 12^c^ | 17 ± 8^c^ | 13 ± 5^*^ | 17 ± 8 | 23 ± 9^h^ | 15 ± 6 | 19 ± 8 | 44 ± 18^**^ | 37 ± 17 | 36 ± 19^f^ | 47 ± 44 | 53 ± 55 | 66 ± 45^**^,^b^ | 43 ± 24 | 64 ± 48 | 59 ± 11
Alkaline phosphatase (IU/L) | 53 ± 14 | 53 ± 25 | 70 ± 24^c^ | 65 ± 22 | 71 ± 31^*^ | 51 ± 13^h^ | 39 ± 13 | 49 ± 17 | 52 ± 23 | 47 ± 12 | 34 ± 11^**^,^f^ | 35 ± 12^**^ | 33 ± 12^**^ | 45 ± 12^b^ | 43 ± 11 | 40 ± 17 | 24 ± 1^*^
Aspartate aminotransferase (IU/L) | 93 ± 24 | 77 ± 20 | 75 ± 17^*^,^c^ | 67 ± 19^**^ | 71 ± 20^**^ | 70 ± 22^**^,^h^ | 51 ± 9^**^ | 56 ± 15^**^ | 81 ± 21 | 87 ± 33 | 66 ± 26^f^ | 76 ± 40 | 90 ± 45 | 81 ± 41^b^ | 72 ± 38 | 65 ± 24 | 108 ± 8

* Significantly different (P≤0 05) from the vehicle control group by Dunnett’s test

** P≤0 01

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day) Data are given as mean ± standard error Statistical tests were performed on unrounded data

b n = 18

c n = 19

d n = 15

e n = 13

f n = 14

g n = 17

h n = 20

i n = 16

J n = 10

k n = 8

l n = 12

m n = 11

n n = 2

o n = 1

TABLE A3 Hematology and Clinical Chemistry Data for Female-B Swiss (CD-1^®^) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT, TMP/SMX, and Folinic Acid^a^

| Vehicle Control | 0 + 0 + 10 | 200 + 0 + 0 | 400 + 0 + 0 | 400 + 0 + 10 | 0 + 1,000 + 0 | 200 + 1,000 + 0 | 400 + 1,000 + 0 | 0 + 2,000 + 0 | 0 + 2,000 + 10 | 200 + 2,000 + 0 | 400 + 2,000 + 0 | 400 + 2,000 + 10 | 0 + 3,000 + 0 | 0 + 3,000 + 10 | 200 + 3,000 + 0 | 400 + 3,000 + 0
n | 14 | 14 | 14 | 16 | 16 | 15 | 16 | 15 | 14 | 15 | 16 | 16 | 15 | 13 | 12 | 12 | 13
Hematology
Hematocrit (%) | 41.9 ± 2.7 | 43.8 ± 4.3 | 43.6 ± 2.9 | 42.1 ± 2.0 | 43.1 ± 2.9 | 42 8 ± 4 0 | 42 1 ± 3 1 | 40 1 ± 6 6 | 44 3 ± 2 3 | 45 8 ± 3 7 | 40 2 ± 4 3 | 40 1 ± 4 8 | 37 5 ± 7 7 | 43 8 ± 2 1 | 44 4 ± 3 8 | 41 0 ± 6 9 | 36 4 ± 8 2
Hemoglobin (g/dL) | 13.8 ± 1.0 | 14.7 ± 1.7 | 14.3 ± 1.3 | 13.7 ± 0.8 | 14.3 ± 1.1 | 14 2 ± 1 9 | 13 9 ± 1 3 | 13 2 ± 2 3 | 14 8 ± 0 9 | 15 2 ± 1 4 | 13 2 ± 1 6 | 12 9 ± 1 7 | 12 2 ± 2 7 | 14 5 ± 0 6 | 15 2 ± 1 2 | 13 1 ± 2 4 | 11 4 ± 2 6
Erythrocytes (10^6^/μL) | 8.31 ± 0.51 | 8.81 ± 1.09 | 8.32 ± 0.73 | 7.77 ± 0.39 | 8.07 ± 0.78 | 8 82 ± 1 18 | 7 98 ± 0 80 | 7 62 ± 1 25 | 8 83 ± 0 63 | 9 02 ± 0 78 | 7 41 ± 0 80 | 7 37 ± 1 08 | 7 08 ± 1 60^*^ | 8 80 ± 0 64 | 8 68 ± 0 79 | 7 44 ± 1 44 | 6 48 ± 1 38^**^
Reticulocytes (10^5^/μL) | 4.7 ± 1.24 | 4.4 ± 1.44 | 5.0 ± 1.73 | 7.9 ± 3.36^*^ | 4.9 ± 2.11 | 5 8 ± 1 76 | 8 4 ± 4 84^**^ | 9 3 ± 5 28^**^ | 4 4 ± 1 66^g^ | 4 2 ± 1 44 | 8 8 ± 4 74 | 11 8 ± 5 12^**^ | 12 7 ± 5 79^**^ | 4 1 ± 1 13 | 6 4 ± 8 46^e^ | 10 0 ± 4 41^*^ | 14 2 ± 6 76^**^
Mean cell volume (fL) | 50.4 ± 2.0 | 49.9 ± 2.7 | 52.6 ± 2.8 | 54.2 ± 2.1^**^ | 53.6 ± 3.4^*^ | 48 8 ± 2 7 | 53 0 ± 3 6 | 52 5 ± 2 5 | 50 4 ± 3 3 | 50 8 ± 1 8 | 54 3 ± 2 8^**^ | 54 7 ± 3 2^**^ | 53 3 ± 3 6 | 49 9 ± 3 1 | 51 2 ± 2 5 | 55 5 ± 3 3^**^ | 56 1 ± 5 0^**^
Mean cell hemoglobin (pg) | 16.6 ± 0.8 | 16.7 ± 0.7 | 17.2 ± 0.7 | 17.7 ± 0.7^**^ | 17.8 ± 0.9^**^ | 16 2 ± 0 8 | 17 5 ± 0 8^**^ | 17 3 ± 0 6 | 16 8 ± 0 9 | 16 9 ± 0 7 | 17 8 ± 0 9^**^ | 17 5 ± 0 7^*^ | 17 2 ± 0 6 | 16 6 ± 0 8 | 17 2 ± 0 8 | 17 7 ± 0 9^**^ | 17 4 ± 1 2
Mean cell hemoglobin concentration (g/dL) | 33.0 ± 1.1 | 33.5 ± 1.2 | 32.7 ± 1.6 | 32.7 ± 1.2 | 33.3 ± 1.4 | 33 3 ± 2 3 | 33 1 ± 1 5 | 32 9 ± 1 0 | 33 3 ± 1 4 | 33 2 ± 1 0 | 32 7 ± 1 2 | 31 9 ± 1 1 | 32 3 ± 1 5 | 33 2 ± 1 7 | 33 7 ± 0 8 | 31 9 ± 1 5 | 31 2 ± 1 0^**^
Platelets (10^3^/μL) | 1,403 ± 359.6 | 1,237 ± 273.4 | 1,343 ± 228.1 | 1,421 ± 387.7 | 1,267 ± 365.0 | 1,213 ± 330 6 | 1,435 ± 409 7 | 1,487 ± 464 9 | 1,525 ± 325 0 | 1,289 ± 289 7 | 1,760 ± 447 5 | 1,468 ± 380 6 | 1,541 ± 385 4 | 1,591 ± 428 9 | 1,870 ± 492 7^*^ | 1,680 ± 575 2 | 1,517 ± 329 0
Leukocytes (10^3^/μL) | 4.47 ± 1.54 | 5.34 ± 2.22 | 5.04 ± 1.32 | 5.93 ± 3.68 | 6.16 ± 2.92 | 4 54 ± 1 17 | 7 05 ± 3 01^*^ | 8 14 ± 2 59^**^ | 6 06 ± 1 58 | 5 10 ± 1 47 | 8 20 ± 3 10^**^ | 8 42 ± 2 54^**^ | 8 74 ± 4 26^**^ | 6 62 ± 1 83 | 5 95 ± 2 29 | 9 32 ± 2 79^**^ | 8 31 ± 2 64^**^
Segmented neutrophils (10^3^/μL) | 1.00 ± 0.55 | 1.07 ± 0.67 | 0.93 ± 0.33 | 1.08 ± 0.63 | 1.10 ± 0.63 | 0 75 ± 0 18 | 1 18 ± 0 45 | 1 26 ± 0 66 | 1 01 ± 0 47 | 0 70 ± 0 19 | 1 10 ± 0 44 | 1 18 ± 0 35 | 1 15 ± 0 65 | 1 24 ± 0 65 | 1 10 ± 0 51 | 1 22 ± 0 33 | 1 39 ± 1 13
Lymphocytes (10^3^/μL) | 3.19 ± 1.03 | 4.00 ± 1.60 | 3.86 ± 1.05 | 4.37 ± 2.66 | 4.70 ± 2.29 | 3 52 ± 1 10 | 5 29 ± 2 36^*^ | 6 40 ± 2 01^**^ | 4 74 ± 1 43 | 4 14 ± 1 37 | 6 54 ± 2 46^**^ | 6 70 ± 2 15^**^ | 7 09 ± 3 67^**^ | 4 97 ± 1 58 | 4 48 ± 1 87 | 7 61 ± 2 67^**^ | 6 44 ± 1 89^**^
Monocytes (10^3^/μL) | 0.11 ± 0.05 | 0.14 ± 0.10 | 0.10 ± 0.05 | 0.17 ± 0.13 | 0.14 ± 0.10 | 0 10 ± 0 05 | 0 23 ± 0 14^**^ | 0 23 ± 0 13^**^ | 0 11 ± 0 05 | 0 10 ± 0 05 | 0 28 ± 0 23^*^ | 0 22 ± 0 13 | 0 26 ± 0 25^*^ | 0 17 ± 0 05 | 0 15 ± 0 07 | 0 26 ± 0 13 | 0 27 ± 0 21^*^
Basophils (10^3^/μL) | 0.01 ± 0.008 | 0.01 ± 0.011 | 0.01 ± 0.010 | 0.02 ± 0.031 | 0.02 ± 0.015 | 0 01 ± 0 011 | 0 03 ± 0 024 | 0 04 ± 0 036^**^ | 0 02 ± 0 013 | 0 02 ± 0 012 | 0 04 ± 0 038 | 0 06 ± 0 052^*^ | 0 05 ± 0 043 | 0 02 ± 0 013 | 0 02 ± 0 017 | 0 05 ± 0 050 | 0 07 ± 0 071^**^
Eosinophils (10^3^/μL) | 0.16 ± 0.14 | 0.11 ± 0.09 | 0.13 ± 0.08 | 0.28 ± 0.37 | 0.19 ± 0.14 | 0 15 ± 0 11 | 0 28 ± 0 20 | 0 17 ± 0 14 | 0 16 ± 0 10 | 0 13 ± 0 07 | 0 21 ± 0 15 | 0 22 ± 0 20 | 0 13 ± 0 13 | 0 20 ± 0 16 | 0 17 ± 0 19 | 0 15 ± 0 10 | 0 09 ± 0 06
Large unstained cell (10^3^/μL) | 0.01 ± 0.01^b^ | 0.01 ± 0.01^c^ | 0.01 ± 0.01^d^ | 0.03 ± 0.03^e^ | 0.02 ± 0.01^f^ | 0 02 ± 0 01^b^ | 0 04 ± 0 04^g^ | 0 04 ± 0 04^*^ | 0 03 ± 0 01^b^ | 0 01 ± 0 01^f^ | 0 04 ± 0 04^h^ | 0 05 ± 0 05^h^ | 0 06 ± 0 08^**^ | 0 03 ± 0 02^b^ | 0 03 ± 0 02^e^ | 0 04 ± 0 03^d^ | 0 05 ± 0 03^b^
Clinical Chemistry
Urea nitrogen (mg/dL) | 29.3 ± 4.2 | 30.6 ± 2.5 | 30.4 ± 7.5 | 27.3 ± 4.8 | 25.2 ± 5.3 | 29 3 ± 6 6 | 21 9 ± 3 1^**^ | 19 0 ± 5 2^**^ | 25 5 ± 4 5 | 26 0 ± 7 4 | 20 6 ± 3 5^**^ | 20 9 ± 3 5^**^ | 20 1 ± 2 7^**^ | 22 9 ± 4 1^**^ | 22 4 ± 2 9^**^ | 20 6 ± 3 8^**^,^g^ | 18 5 ± 3 7^**^
Creatinine (mg/dL) | 0.39 ± 0.05^g^ | 0.42 ± 0.05^g^ | 0.40 ± 0.10 | 0.35 ± 0.06^h^ | 0.37 ± 0.08^h^ | 0 38 ± 0 08^f^ | 0 29 ± 0 07^**^ | 0 28 ± 0 07^**^ | 0 36 ± 0 06^b^ | 0 34 ± 0 11^f^ | 0 30 ± 0 07^*^ | 0 29 ± 0 08^*^ | 0 29 ± 0 07^**^ | 0 35 ± 0 10 | 0 36 ± 0 06^c^ | 0 30 ± 0 07^*^,^g^ | 0 27 ± 0 07^**^
Alanine aminotransferase (IU/L) | 34 ± 14 | 33 ± 8 | 43 ± 25^g^ | 52 ± 42 | 32 ± 19 | 28 ± 7^f^ | 63 ± 50^*^ | 32 ± 27 | 28 ± 11 | 28 ± 9 | 40 ± 34^h^ | 35 ± 30^h^ | 48 ± 32 | 50 ± 39 | 51 ± 32^d^ | 38 ± 31^g^ | 24 ± 11
Alkaline phosphatase (IU/L) | 37 ± 16 | 37 ± 8 | 49 ± 23 | 37 ± 13 | 47 ± 20 | 46 ± 28 | 43 ± 13 | 42 ± 17 | 50 ± 13 | 46 ± 14 | 42 ± 14 | 47 ± 22 | 44 ± 12 | 49 ± 17 | 44 ± 9 | 48 ± 14^g^ | 39 ± 19
Aspartate aminotransferase (IU/L) | 72 ± 24 | 72 ± 19 | 86 ± 27^g^ | 93 ± 36 | 76 ± 26 | 76 ± 27^f^ | 86 ± 31 | 71 ± 31 | 70 ± 24 | 67 ± 17 | 79 ± 39^h^ | 78 ± 27^h^ | 91 ± 38 | 95 ± 28 | 97 ± 43^e^ | 76 ± 28^g^ | 59 ± 22

* Significantly different (P≤0.05) from the vehicle control group by Dunnett’s test

** P≤0 01

a Daily gavage doses of AZT + TMP/SMX + folinic acid (mg/kg per day). Data are given as mean ± standard error. Statistical tests were performed on unrounded data

b n = 12

c n = 8

d n = 10

e n = 11

f n = 14

g n = 13

h n = 15