# References

Barnes, P.F., Bloch, A.B., Davidson, and Snider, D.E. (1991). Tuberculosis in patients with human immunodeficiency virus infection. N. Engl. J. Med. 324, 1644–1650.2030721
Baron, D.N., and Bell, J.L. (1974). Serum enzyme changes in patients receiving antituberculosis therapy with rifampin or p-aminosalicylic acid, plus isoniazid and streptomycin. Tubercle 55, 115–120.4620296
Bederka, J.P., Jr., Davttiyananda, D., Moses, M.L., and Amad, N. (1975). Drug-biomolecule interactions: Drug toxicity and vitamin coenzyme depletion. J. Pharm. Sci. 64, 528–534.239196
Centers for Disease Control (CDC) (1987). Diagnosis and management of mycobacterial infection and disease in persons with human immunodeficiency virus infection. Ann. Intern. Med. 106, 254–256.3800186
Dunn, O.J. (1964). Multiple comparisons using rank sums. Technometrics 6, 241–252.
Dunnett, C.W. (1955). A multiple comparison procedure for comparing several treatments with a control. J. Am. Stat. Assoc. 50, 1096–1121.
East and Central African/British Medical Research Council (1986). Fifth Collaborative Study. Controlled clinical trial of 4 short-course regimens of chemotherapy (three 6-month and one 8-month) for pulmonary tuberculosis: Final report. Tubercle 67, 5–15.3521015
Goldschmidt, R.H., and Dong, B.J. (1992). Current Report - HIV. Treatment of AIDS and HIV-related conditions: 1992. J. Am. Board Fam. Pract. 5, 335–350.1580182
Grosset, J., Truffot-Pernot, C., Lacroix, C., and Ji, B. (1992). Antagonism between isoniazid and the combination pyrazinamide-rifampin against tuberculosis infection in mice. Antimicrob. Agents Chemother. 36, 545–551.1622163
Hardy, W.D. (1991). Prophylaxis of AIDS-related opportunistic infections (OIs). AIDS Clin. Rev., 145–180.
Harkins, T., and Herriot, K.B. (1992). Medical management of acquired immune deficiency syndrome patients: A review. J. Am. Optom. Assoc. 63, 35–42.1583259
Harris, M.W., Chapin, R.E., Lockhart, A.C., and Jokinen, M.P. (1992). Assessment of short-term reproductive and developmental toxicity screen. Fundam. Appl. Toxicol. 19, 186–196.1516774
Hollander, M., and Wolfe, D.A. (1973). Nonparametric Statistical Methods, pp. 120–123. John Wiley and Sons, New York.
Mandell, G.L., and Sande, M.A. (1990). Drugs used in the treatment of tuberculosis and leprosy. In Goodman and Gilman’s The Pharmacological Basis of Threapetics (A.G. Gilman, T.W. Rail, A.S. Nies, and P. Taylor, Eds.) 8th ed., pp. 1146–1164. Pergmon Press, Inc., New York.
Morrissey, R.E., Harris, M.W., and Schwetz, B.A. (1989). Developmental toxicity screen. Results of rat studies with diethylhexyl phthalate and ethylene glycol monomethyl ether. Teratog. Carcinog. Mutagen. 9, 119–129.2568021
Nolan, CM. (1992). Human immunodeficiency syndrome-associated tuberculosis: A review with an emphasis on infection control issues. Am. J. Infect. Control. 20, 30–34.1554145
Physicians’ Desk Reference (PDR) (1994). 48th ed., pp. 463–465. Medical Economics Company Inc., Montvale, NJ.
Ramakrishnan, C.V., Janardhanam, B., Krishnamurthy, D.V., Stott, H., Subbammal, S., and Tripathy, S.P. (1968). Toxicity of pyrazinamide administered once weekly in high dosage in tuberculosis patients. Bull. World Health Organ. 39, 775–779.5306313
Roman, I.C., and Georgian, L. (1977). Cytogenetic effects of some anti-tuberculosis drugs in vitro. Mutat. Res. 48, 215–224.876269
Registry of Toxic Effects of Chemical Substances (RTECS) (1983). 1981–1982 Edition, Vol. 3 (P-Z), p. 393. National Institute for Occupational Safety and Health, Cincinnati, OH.
Siegel, S. (1956). Nonparametric Statistics for the Behavioral Sciences, pp. 96–104. McGraw-Hill, New York.
Snedecor, G.W., and Cochran, W.G. (1967). Test for a linear trend in proportions. In Statistical Methods, 6th ed., pp. 246–248. Iowa State University Press, Ames.
Weiner, I.M., and Tinker, J.P. (1972). Pharmacology of pyrazinamide: Metabolic and renal function studies related to die mechanism of drug-induced urate retention. J. Pharmacol. Exp. Ther. 180,411–434.4622054
Zitkova, L., Stastna, J., Tousek, J., and Viklicky, J. (1983). Toxicity of morphazinamide compared with pyrazinamide. Czech. Med. 6, 140–151.6416791