# Results and Discussion

## Mortality

All male and female mice survived to the end of the study with the exception of one female-A control which died on day 29 after retroorbital bleeding. No clinical signs of toxicity were observed in any of the groups.

## Body and Organ Weights

A significant reduction in body weight occurred in the male 1,200 mg/kg group during the first 4 days of treatment (study days 5 to 9). Otherwise, mean body weights of dosed males and females-A were comparable to those of the control group during the course of the study and at termination (Figures 1 and 2). Gravid uterine weights of dosed females-A were also similar to those of the control group.

Weight gain was reduced in the 800 and 1,200 mg/kg groups of females-B during days 8 to 15 of gestation and the mean body weights of these groups were significantly lower (P≤0.05) than that of the control group on gestation day 15 (Figure 3, Table 1). However, this does not appear to be a true reduction in weight gain but rather the result of the lower number of pups in utero in the 800 and 1,200 mg/kg groups: 127 and 100 pups respectively, versus 139 in the control group (Table 8). The postpartum mean body weights of all female-B dose groups were nearly identical to that of the control group as were the mean pup weights (Figure 4).

Figure 1 Mean Body Weights of Males in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-1^®^) Mice

Figure 2 Mean Body Weights of Females-A in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-1^®^) Mice [TBW = Terminal Body Weight prior to Caesarean-Section; CBW = Corrected Body Weight (TBW - gravid uterine weight); TSAC = Terminal Sacrifice]

Figure 3 Mean Body Weights of Females-B in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-I^8^) Mice [GD = Gestation Day; LD = Lactation Day]

Figure 4 Mean Body Weights of Female-B Pups in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-1^®^) Mice [LD = Lactation Day]

Table 1 Body Weights of Females-B in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-I^®^) Mice^a^

| Vehicle Control | 400 mg/kg | 800 mg/kg | 1,200 mg/kg
Mice Assigned to
Natural Delivery (n) | 17 | 15 | 15 | 14
Pregnant (n) | 11 | 12 | 14 | 11
GD 0 | 30.3 ± 0.9 | 30.2 ± 1.4 | 30.1 ± 1.0 | 30.0 ± 1.5
GD 8 | 34.4 ± 1.5 | 33.8 ± 2.4 | 34.3 ± 1.2 | 33.4 ± 1.4
GD 12 | 40.4 ± 2.4[7]^b^ | 40.0 ± 3.4[9]^b^ | 38.5 ± 2.1[11]^b^ | 37.4 ± 2.0[8]^b^
GD15 | 47.9 ± 2.5 | 47.2 ± 4.5 | 44.1 ± 4.8^*^ | 43.8 ± 3.9 *
LD 0 | 35.4 ± 1.1 | 35.1 ± 2.5 | 35.0 ± 2.1[10]^b^ | 34.5 ± 1.5
LD 1 | 36.4 ± 1.6 | 36.0 ± 2.8 | 34.9 ± 2.3 | 35.0 ± 2.0[9]^c^
LD 4 | 40.8 ± 2.1 | 40.8 ± 3.4 | 39.7 ± 3.8 | 40.4 ± 3.0[9]^c^

* Significantly different from the vehicle control group value (Ps0.05) by Dunnett’s or Dunn’s test

GD=Gestation day

LD = Lactation day

a Data are presented as mean ± standard deviation

b Number of values averaged (due to error some values were not recorded at this time point)

c Excludes values for a dam with no surviving pups

During lactation, mean pup weights of dosed groups continued to be similar to the control group (Table 8). Although the reduction in the number of pups delivered occurred in the 800 and 1,200 mg/kg groups, it appears to be the result of biological variation rather than the result of the administration of pyrazinamide, since: a) the females-B were mated with untreated males, and b) the females-B were not treated until after implantation (day 6 of gestation). Also, the rate of resorption in the two highest dose groups was similar to the rate in the control group (Table 9).

Mean right epididymis weights were slightly decreased in all treated groups relative to the control group. Respective mean epididymis weights for the 400, 800, and 1,200 mg/kg groups were approximately 1.8% (47.75 mg), 10.0% (43.77 mg), and 2.6% (47.37 mg) lower than the mean body weight (48.61 mg) for the control group. The statistically significant (P < 0.05) decline in the 800 mg/kg group was not believed to be biologically significant, as a dose-related effect was not evident. Although Morrissey et al. (1989) found that reduced epididymal weights correlated well with reduced fertility in mouse continuous breeding studies, fertility was apparently unimpaired in the present study.

## Clinical Pathology

Administration of pyrazinamide to male mice at 400, 800, and 1,200 mg/kg did not produce any biologically significant hematologic alterations. However, there were slight but statistically significant increases in MCH in 1,200 mg/kg males, and there were statistically significant increases in MCHC in 800 and 1,200 mg/kg males (Table 2).

Hematology values for dosed females-A and -B were generally similar to those of the control groups (Table 3). Reticulocyte counts in females-B were slightly reduced in the 800 and 1,200 mg/kg groups, and these reductions were statistically significant but not considered to be biologically significant. No significant effects occurred in any of the clinical chemistry parameters evaluated in this study (Table 4).

## Plasma Pyrazinamide Concentrations

The internal exposure of pyrazinamide appeared to be dose proportional based on C_max_ values measured at the end of the study (Table 5). No sex differences were apparent. The estimates for T_max_ and t_1/2_ were consistent for all doses for males and females. The 90-minute T_max_ value for the 1,200 mg/kg dose in female mice resulted from the limited number of time points taken; the actual value is between 30 and 90 minutes. The estimates for t_%_ tend to support the conclusion that the doses given fall within the linear range. The variations seen in the estimates for t_1/2_ showed no apparent dose dependency and may be accounted for by interanimal variability and the uncertainty in the estimates, which were based on a small number of time points.

Table 2 Selected Hematology Parameters in Males in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-1^®^) Mice^a^

| Vehicle Control | 400 mg/kg | 800 mg/kg | 1,200 mg/kg
n | 10 | 10 | 10 | 10
Hematocrit (%) | 49.1 ± 3.2 | 47.9 ± 2.3 | 48.3 ± 4.0 | 48.3 ± 3.4
Hemoglobin (g/dL) | 16.0 ± 1.1 | 15.6 ± 0.7 | 16.1 ± 1.5 | 16.0 ± 1.2
Erythrocytes (10^6^/MM^3^) | 10.17 ± 0.72 | 9.87 ± 0.60 | 10.01 ± 0.90 | 9.89 ± 0.71
Reticulocytes (K^/MM^3^) | 3.9 ± 0.65 | 3.7 ± 0.42 | 3.6 ± 0.64 | 3.7 ± 0.74
Mean cell volume (fL) | 48.4 ± 1.3 | 48.6 ± 1.9 | 48.3 ± 1.2 | 48.8 ± 1.2
Mean cell hemoglobin (pg) | 15.7 ± 0.3 | 15.8 ± 0.5 | 16.0 ± 0.3 | 16.2 ± 0.4^*^
Mean cell hemoglobin concentration (g/dL) | 32.6 ± 0.51 | 32.6 ± 0.54 | 33.2 ± 0.69^*^ | 33.2 ± 0.63^*^
Platelets (10^3^/MM^3^) | 1,188 ± 211.0 | 1,257 ± 225.3 | 1,250 ± 351.7 | 1,236 ± 265.5
Leukocytes (10^3^/MM^3^) | 7.95 ± 1.99 | 7.30 ± 3.24 | 7.09 ± 2.23 | 8.61 ± 2.69

* Significantly different from control group (P≤0.05) by Dunnett’s test

a Data are presented as mean ± standard deviation

Table 3 Selected Hematology Parameters in Females in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-1^®^) Mice^a^

| Vehicle Control | 400 mg/kg | 800 mg/kg | 1,200 mg/kg
Females-A
n | 20 | 19 | 20 | 20
Hematocrit (%) | 42.0 ± 2.6 | 42.1 ± 3.3 | 43.4 ± 4.1 | 42.6 ± 2.8
Hemoglobin (g/dL) | 14.0 ± 1.1 | 13.8 ± 0.9 | 14.1 ± 1.5 | 13.9 ± 0.9
Erythrocytes (10^6^/MM^3^) | 8.78 ± 0.71 | 8.75 ± 0.59 | 8.90 ± 0.93 | 8.59 ± 0.60
Reticulocytes (10^5^/MM^3^) | 3.4 ± 1.19^b^ | 3.6 ± 1.54 | 3.5 ± 0.68 | 4.0 ± 1.96^c^
Mean cell volume (fL) | 48.0 ± 2.5 | 48.1 ± 1.6 | 48.9 ± 1.7 | 49.6 ± 2.5
Mean cell hemoglobin (pg) | 16.0 ± 0.8 | 15.8 ± 0.7 | 15.9 ± 0.4 | 16.2 ± 0.8
Mean cell hemoglobin concentration (g/dL) | 33.3 ± 1.4 | 32.9 ± 1.4 | 32.5 ± 0.8 | 32.6 ± 1.2
Platelets (10^3^/MM^3^) | 1,268 ± 322.2 | 1,305 ± 360.8 | 1,434 ± 241.0 | 1,453 ± 197.5
Leukocytes (10^3^/MM^3^) | 7.86 ± 1.87 | 7.73 ± 2.09 | 7.11 ± 1.63 | 7.68 ± 1.45
n | 16 | 15 | 14 | 14
Hematocrit (%) | 43.3 ± 4.6 | 41.8 ± 2.5 | 42.2 ± 2.2 | 43.0 ± 4.4
Hemoglobin (g/dL) | 14.1 ± 1.7 | 13.8 ± 0.9 | 14.0 ± 0.9 | 14.1 ± 1.6
Erythrocytes (10^6^/MM^3^) | 8.89 ± 1.13 | 8.52 ± 0.69 | 8.59 ± 0.65 | 8.84 ± 1.12
Reticulocytes (10^5^/MM^3^) | 4.6 ± 1.23 | 4.3 ± 0.81 | 3.3 ± 1.04^**^ | 3.4 ± 1.64^*^
Mean cell volume (fL) | 48.9 ± 2.7 | 49.1 ± 2.4 | 49.2 ± 1.8 | 48.9 ± 3.1
Mean cell hemoglobin (pg) | 15.9 ± 0.9 | 16.2 ± 0.7 | 16.3 ± 0.6 | 16.0 ± 0.8
(g/dL) | 32.6 ± 1.2 | 32.9 ± 1.3 | 33.1 ± 0.9 | 32.8 ± 0.9
Platelets (10^3^/MM^3^) | 1,264 ± 267.0 | 1,313 ± 329.0 | 1,268 ± 264.7 | 1,300 ± 338.5
Leukocytes (10^3^/MM^3^) | 7.6 ± 3.40 | 6.36 ± 1.20 | 7.19 ± 3.13 | 7.78 ± 1.66

* Significantly different from control group (P≤0.05) by Dunnett’s test

** (P≤0.01)

a Data are presented as mean ± standard deviation

b n=19

c n=17

Table 4 Selected Clinical Chemistry Parameters in Females in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-1^®^) Mice^a^

| Vehicle Control | 400 mg/kg | 800 mg/kg | 1,200 mg/kg
Females-A
n | 11 | 11 | 11 | 11
Alanine aminotransferase (IU/L) | 44 ± 22 | 38 ± 10 | 44 ± 11 | 40 ± 14
Alkaline phosphatase (IU/L) | 56 ± 8 | 55 ± 15 | 56 ± 16 | 45 ± 12
Aspartate aminotransferase (IU/L) | 88 ± 24 | 71 ± 21 | 89 ± 16 | 79 ± 19
Sorbitol dehydrogenase (IU/L) | 27 ± 13^b^ | 21 ± 4^c^ | 29 ± 3^d^ | 25 ± 5^e^
Bile acids (μmol/L) | 20 ± U.5^e^ | 12 ± 7.2^f^ | 11 ± 9.7^f^ | 14 ± 7.9^f^
n | 17 | 15 | 15 | 14
Alanine aminotransferase (IU/L) | 45 ± 17 | 40 ± 11 | 47 ± 15 | 43 ± 11
Alkaline phosphatase (IU/L) | 55 ± 18 | 44 ± 18 | 49 ± 20 | 47 ± 25
Aspartate aminotransferase (IU/L) | 85 ± 23 | 77 ± 15 | 85 ± 28^g^ | 83 ± 31
Sorbitol dehydrogenase (IU/L) | 20 ± 8^h^ | 17 ± 5^h^ | 15 ± 10^i^ | 17 ± 8^i^
Bile acids (μmol/L) | 16 ± 5.3^j^ | 18 ± 10.4^j^ | 14 ± 7.7^b^ | 15 ± 6.1^e^

a Data are presented as mean ± standard deviation

b n=7

c n=3

d n=4

e n=8

f n=6

s n=14

h n=U

l n=9

j n=10

Table 5 Toxicokinetic Parameters of Pyrazinamide in Swiss (CD-1^®^) Mice^a^

Parameter | Males (mg/kg) | | | Females (mg/kg)
Parameter | 400 | 800 | 1,200 | 400 | 800 | 1,200
C_max_ (_μ_g/mL) | 143 | 315 | 539 | 113 | 222 | 408
T_max_ (min) | 30 | 30 | 30 | 30 | 30 | 90
T_1/2_ (min) | 58.3 | 99.2 | 102 | 74.8 | 61.5 | 47.7^b^

a Except as noted, parameters were estimated from 30-, 90-, and 120-minute time points

b Based on 90- and 120-minute time points

## Gross Necropsy Findings and Histopathology

Microscopic evaluation of a gross lesion observed in the lung of one female-B in the 1,200 mg/kg group revealed the presence of a nodule composed of slightly anaplastic alveolar/bronchiolar epithelial cells. The lesion was well delineated and mitotic figures were not abundant. Slight compression of the adjacent pulmonary parenchyma was evident. These morphologic findings were compatible with a diagnosis of an alveolar/bronchiolar adenoma. This lesion was considered incidental and unrelated to chemical treatment. No other gross lesions of any consequence were observed.

## Sperm Evaluation

Male reproductive parameters were not significantly affected by the administration of pyrazinamide (Table 6).

Table 6 Reproductive Parameters in Males in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-I^®^) Mice^a^

| Vehicle Control | 400 mg/kg | 800 mg/kg | 1,200 mg/kg
n | 10 | 10 | 10 | 10
Body weight (g) | 37.94 ± 0.80 | 39.54 ± 0.80 | 39.18 ± 0.54 | 38.94 ± 0.61
Left caudal weight (mg) | 18.1 ± 1.1 | 21.3 ± 1.0 | 18.8 ± 0.9 | 19.6 ± 0.8
Left epididymal weight (mg) | 47.2 ± 1.9 | 50.8 ± 1.8 | 48.2 ± 1.0 | 47.2 ± 1.2
Left testicular weight (mg) | 120.8 ± 6.2 | 125.9 ± 3.3 | 116.7 ± 5.9 | 123.4 ± 4.0
Epididymal sperm motility (%) | 83.40 ± 0.42^d^ | 76.36 ± 3.37 | 76.76 ± 5.72 | 75.54 ± 3.23
Epididymal sperm density^13^ (× 10^6^) | 1,383 ± 90^d^ | 1,085 ± 39 | 1,229 ± 87 | 1,160 ± 65
Spermatid heads/testis (× 10^7^) | 2.16 ± 0.71 | 2.32 ± 0.07 | 2.26 ± 0.06 | 2.25 ± 0.05
Spermatid heads/g testis^c^ (× 10^7^) | 17.73 ± 1.22 | 18.48 ± 0.45 | 19.70 ± 0.84 | 18.32 ± 0.42

a Data are presented as mean ± standard error

b Per gram of caudal tissue

c Total spermatid heads per testis/testicular weight in grams

d n=9

## Pregnancy and Fetal Parameters

In the female-B group, pregnancy occurred in 11/17 (64.7%), 12/15 (80.0%), 14/15 (93.3%), and 11/14 (78.6%) sperm-positive mice assigned to natural delivery in the groups administered pyrazinamide at 0, 400, 800, and 1,200 mg/kg, respectively. No significant differences were found between the dosed females-B group dams or their pups in comparison to the control group (Tables 7 and 8). The total number of pups delivered in the 800 and 1,200 mg/kg groups was lower than that in the control group, but as indicated earlier, this appears to be the result of biological variation as does the lower number of implantation sites in the 1,200 mg/kg group. One control dam and one dam in the 400 mg/kg group each had one stillborn pup; all others had only liveborn pups, and nearly all liveborn pups from all groups survived through postpartum day 4.

In the female-A group, pregnancy occurred in 16 (80.0%), 12 (60.0%), 13 (65.0%), and 17 (85.0%) of the 20 mice per group administered 0, 400, 800, and 1,200 mg/kg, respectively (Table 9). In the 800 mg/kg group, one mouse delivered a litter before sacrifice and one, two, three, and two mice from the 0, 400, 800, and 1,200 mg/kg groups, respectively, were sacrificed on the estimated day 14 of gestation due to technical error. Data from the dam that delivered early were excluded from averages, and fetal weight data were excluded from averages for the eight litters caesarean-sectioned on the estimated day 14 of gestation (two dams, one from the 400 mg/kg group and one from the 1,200 mg/kg group, had fetuses at such an early gestational age that viability and sexes could not be determined; all data were excluded for these two dams and litters).

Table 7 Natural Delivery Observations for Females-B in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-I^®^) Mice

| Vehicle Control | 400 mg/kg | 800 mg/kg | 1,200 mg/kg
Females Mated
n | 17 | 15 | 15 | 14
n | 11 | 12 | 14 | 11
% | 64.7 | 80.0 | 93.3 | 78.6
n | 11 | 12 | 13 | 10
% | 64.7 | 80.0 | 86.7 | 71.4
mean ± standard deviation | 20.0 ± 0.0 | 19.8 ± 0.4 | 20.1 ± 0.3 | 20.4 ± 0.7
n | 145 | 168 | 142 | 109
mean ± standard deviation | 13.2 ± 2.1 | 14.0 ± 1.6 | 10.9 ± 3.0 | 10.9 ± 4.2
n | 1 | 1 | 0 | 0
% | 9.1 | 8.3 | 0.0 | 0.0
n | 0 | 0 | 0 | 0

Table 8 Litter Observations and Mean Pup Weights for Females-B in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-1^®^) Mice

| Vehicle Control | 400 mg/kg | 800 mg/kg | 1,200 mg/kg
n | 11 | 12 | 13 | 9^a^
n | 139 | 150 | 127 | 100
| 12.6 ± 2.0^b^ | 12.5 ± 1.9 | 9.8 ± 3.1 | 11.1 ± 3.0
n | 138 | 149 | 127 | 100
n | | 1 | 0 | 0
% | 0.7 | 0.7 | 0.0 | 0.0
| 0.1 ± 0.3^b^ | 0.1 ± 0.3 | 0.0 ± 0.0 | 0.0 ± 0.0
Day 0
n | 0 | 0 | 0 | 1
% | 0.0 | 0.0 | 0.0 | 1.0
n | 1 | 3 | 3 | 0
% | 0.7 | 2.0 | 2.4 | 0.0
Live Pups/Litter at Weighing
Day 0 | 12.5 ± 2.1° | 12.4 ± 1.9 | 9.8 ± 3.1 | 11.0 ± 3.1
Day 1 | 12.5 ± 2.1 | 12.3 ± 1.9 | 9.6 ± 3.4 | 11.0 ± 3.1
Day 4 | 12.4 ± 2.0 | 12.3 ± 1.9 | 9.5 ± 3.5 | 11.0 ± 3.1
Day 0 | 1.7 ± 0.1 | 1.6 ± 0.1 | 1.7 ± 0.1 | 1.7 ± 0.2
Day 4 | 2.9 ± 0.3 | 2.9 ± 0.2 | 3.1 ± 0.4 | 3.0 ± 0.4

a Excludes one litter that consisted of two pups of undetermined viability

b Data are presented as mean number of pups/litter ± standard deviation

c Data are presented as mean ± standard deviation

Table 9 Caesarean-Section Observations and Fetal Data for Females-A in the Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide in Swiss (CD-1^®^) Mice

| Vehicle Control | 400 mg/kg | 800 mg/kg | 1,200 mg/kg
Mice Tested
n | 20 | 20 | 20 | 20
n | 16 | 12 | 13 | 17
% | 800 | 600 | 650 | 850
n | 0 | 0 | 1 | 0
n | 16 | 11^a^ | 12 | 16^a^
Corpora Lutea | 137 ± 16^b^ | HA-± 26 | 141 ± 38 | 141 ± 29
Implantations | 128 ± 15 | 134 ± 22 | 128 ± 40 | 131 ± 22
Litter Sizes | 114 ± 16 | 124 ± 26 | 113 ± 44 | 124 ± 22
n | 181 | 134 | 134 | 199
| 113 ± 15 | 122 ± 25 | 112 ± 43 | 124 ± 22
n | 1 | 2 | 2 | 0
| 01 ± 02 | 02 ± 04 | 02 ± 04 | 00 ± 00
Resorptions | 14 ± 12 | 11 ± 18 | 15 ± 15 | 07 ± 09
n | 17 | 10 | 18 | 9
| 11 ± 09 | 09 ± 18 | 15 ± 15 | 06 ± 09
n | 6 | 2 | 0 | 2
| 04 ± 06 | 02 ± 04 | 00 ± 00 | 01 ± 03
n | 12 | 6 | 9 | 8
% | 750 | 545 | 750 | 500
n | 0 | 0 | 0 | 0
n | 16 | 11 | 12 | 16
% | 1000 | 1000 | 1000 | 1000

a Excludes two dams (400 and 1,200 mg/kg group) that were sacrificed by error on the estimated day 14 of gestation Due to gestational age of fetuses, sexes and viability could not be determined

b Data are presented as mean ± standard deviation

Necropsy observations were based on 16, 11, 12, and 16 litters in the 0, 400, 800 and 1,200 mg/kg groups, respectively. There were no effects on any of the parameters evaluated in females-A that could clearly be attributed to the administration of pyrazinamide (Table 9). All values were comparable to the control group values with the exception of lower female fetal body weights in the 800 and 1,200 mg/kg groups which were significant (P≤0.05) in the 1,200 mg/kg group (1.26 g and 1.25 g, respectively, vs. 1.36 g for the control group). It is uncertain whether these differences are related to the test article because: 1) there was no clear dose-response relationship, 2) the 1,200 mg/kg group had the largest live litter size (12.4 vs. 11.4 for the control group) and the lowest incidence of resorptions (0.7 vs. 1.4 for the control group) of any group, 3) there was no effect on body weight of dams or gravid uterine weight, and 4) no difference in pup weight was observed in the female-B litters (this group received pyrazinamide during days 6 through 15 of presumed gestation and was mated with undosed males). Future studies in this series using higher doses of pyrazinamide may help to resolve this question.

No gross external fetal malformations or alterations were observed as a consequence of administering pyrazinamide to pregnant mice.

In summary, with the exception of the equivocal findings in regard to the lower female fetal body weights in females-A, no apparent reproductive or developmental toxic effects of pyrazinamide were detected in male or female Swiss (CD-1^®^) mice. However, results of this study indicated that higher doses could have been tolerated, and future studies for toxicity of combination therapies may include higher doses of pyrazinamide. The dose of 1,200 mg/kg body weight employed in this study is equivalent to approximately eight times the therapeutic dose in female Swiss (CD-1^®^) mice (Grossett et al., 1992) and resulted in a C_max_ 9 to 12 times the C_max_ caused by the therapeutic dose.