# Materials and Methods

## Procurement and Characterization of Pyrazinamide

Pyrazinamide (Lot 00909PJ) was manufactured by Aldrich Chemical Company (Milwaukee, WI). The material, a fine white powder, was identified as pyrazinamide by nuclear magnetic resonance and infrared spectroscopy. The purity of the compound was determined to be greater than 99% by high-performance liquid chromatography (HPLC).

## Dose Formulations

Suspensions of pyrazinamide were prepared by weighing the required amount of the drug into a volumetric flask and adding the appropriate amount of 0.5% methyl cellulose in deionized water. Each formulation was then stirred and sonicated until a homogeneous suspension was obtained. Homogeneity analyses were conducted on triplicate samples from the top, middle, and bottom of the suspension using HPLC. Results indicated that the suspension was slightly lower in concentration at the top and slightly higher in concentration at the bottom, but the differences were not significant. The range of dose concentrations among the three sampling locations was ± 2.5% of the target concentrations. Stability studies conducted on a formulation containing pyrazinamide at 3.75 mg/mL (equivalent in mice to 75 mg/kg body weight) in 0.5% aqueous methyl cellulose indicated that formulations were stable for 30 days in sealed glass bottles at refrigerated and room temperatures, and for 3 hours under simulated dosing conditions. After 3 hours, formulations showed slightly elevated concentrations (11%) of pyrazinamide. Dosing formulations of pyrazinamide used in this study were stored under refrigeration in the dark for a maximum of 29 days after mixing.

Samples of formulations from each dose level from the first mix showed that all formulations analyzed prior to dosing were within the acceptable range (± 10% of theoretical values). Animal room samples contained 105% to 111% of the target pyrazinamide concentrations; these values were consistent with the slight elevation of concentration seen in the dosage stability study. Since only the 400 mg/kg dose formulation exceeded the acceptable limit of ± 10% of theoretical values (111%), the elevated concentrations of the animal room samples were considered acceptable.

## Study Design

Male and female Swiss (CD-1^®^) mice were obtained from Charles River Laboratories (Raleigh, NC) and were placed on study at about 12 weeks of age. During the acclimation period of 17 days, five males and five females were examined for parasites at four time points; all parasite examinations were negative. At terminal sacrifice, blood samples were collected from five male and five female sentinel animals for testing as part of the animal disease screening program. Results indicated that all animals were free of viral antibodies. The mice were housed five per sex per cage during quarantine before randomization and were individually housed after randomization, except during cohabitation. Polycarbonate cages were used. Animal rooms were maintained at an average temperature of 70.4° F and an average relative humidity of 57.8% with 12 hours of fluorescent light per day and a minimum of 10 room air changes per hour.

The design of this study is a modification of a design published elsewhere (Harris et al., 1992). The oral route of administration was selected because it is the route used in humans. The study was conducted on Swiss (CD-1^®^) mice because this strain is routinely used for reproductive and developmental toxicity evaluations. Pyrazinamide was administered in a 0.5% (w/v) methyl cellulose suspension at concentrations of 0, 400, 800, and 1,200 mg/kg by gavage. Total daily doses of 20 mL/kg were divided into two equal doses of 10 mL/kg given approximately 6 hours apart. There were 10 males and 40 females per dose group. Each female dose group was further divided into groups of 20 females-A and 20 females-B. Males were dosed during study days 5 through 25, females-A were dosed during study days 0 through the day prior to sacrifice. Males were cohabited with females-A on study days 9 to 13 to identify any effects of treatment on mating behavior, fertilization, implantation, or the initial stages of development. The group females-B cohabited with males on study days 0 through 4, before the males began receiving pyrazinamide, and were dosed on gestation days 6 through 15 during organogenesis to identify effects on fetal development. Residual effects on parturition and the beginning of lactation were also evaluated. All animals were observed daily for clinical signs of toxicity.

During cohabitation periods, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually and that day was designated as day 0 of gestation. At the end of each cohabitation period, all animals were housed individually.

On study day 25, all male mice were weighed, dosed, and retroorbital blood samples were obtained for hematology evaluation. Samples were also obtained from nine males per group, divided over three time points after dosing, for evaluation of plasma pyrazinamide concentrations. Sperm count, function, and motility were assessed, the males were euthanized with CO_2_, and a gross necropsy was conducted.

On study days 28 to 32 (day 18 of presumed gestation) all female-A mice were weighed, and blood samples were collected for hematology and clinical chemistry evaluations. Samples were also obtained from nine animals per group, divided over three time points after dosing, for plasma pyrazinamide concentration evaluations. The females-A were then euthanized with CO_2_ and gross necropsy and caesarean-section evaluations were conducted. Live fetuses were removed, weighed, anesthetized on ice, and preserved in Bouin’s fixative. The uteri of all sperm-negative females-A were examined for evidence of unsuccessful pregnancy, then “press-plated” between two heavy plates of glass to visualize early implantation sites. Additional endpoints for all females-A included gravid uterine weight, number of implantation sites, resorptions, corpora lutea, and dead and live fetuses.

Sperm-negative females-B were euthanized with CO_2_ and discarded without necropsy. The sperm-positive females-B were assigned evenly across dose groups prior to gestation day 6. Beginning on gestation day 16 for females-B, the bedding material and feeders in the cages were no longer changed. From gestation day 17 until the litters were delivered, females-B were observed twice daily for evidence of labor or delivery. The day of delivery was determined to the nearest day and was designated as postnatal day 0. On postnatal days 0 and 1, dam weights were recorded, along with the number of live and dead pups, the number of male and female pups, any gross malformations, and live pup weights. Dead pups were discarded. On postnatal day 4, females-B, including any which did not deliver, were weighed and blood samples were collected for hematology and clinical chemistry determinations. These mice were then euthanized with CO_2_ and a complete gross necropsy was performed. The uterus was removed and “press-plated.” All pups were weighed, given a thorough external examination for lesions or malformations, and the sex was recorded. The pups were then euthanized with CO_2_ and saved in Bouin’s fixative.

A gross necropsy was performed on all animals except sperm-negative females-B, which were euthanized after cohabitation. If gross lesions were present, the tissue was fixed in formalin, trimmed to a maximum thickness of 0.3 cm for processing, embedded in paraffin, sectioned at 4 to 6 /am thickness, stained with hematoxylin and eosin, and examined by light microscopy. The right testis from all males was saved in Bouin’s fixative.

### Clinical Pathology

All blood samples for hematology and clinical chemistry were taken from the retroorbital sinus under CO_2_/O_2_ (70/30) anesthesia. Animals were selected in random order for blood collection and samples were analyzed in the order collected.

Erythrocyte, platelet, and leukocyte counts; hematocrit; hemoglobin; mean cell hemoglobin (MCH); mean cell volume (MCV); mean cell hemoglobin concentration (MCHC); leukocyte differentials; and erythrocyte and platelet morphologies were determined on whole blood using a Technicon H-1 automated hematology analyzer. Reticulocyte counts were conducted using a Coulter Model Elite Flow Cytometer. Blood smears were prepared to manually verify reticulocyte counts, leukocyte differentials, and morphologies, if necessary.

Values for alanine aminotransferase, alkaline phosphatase, aspartate aminotransferase, sorbitol dehydrogenase, and bile acids were determined using a Roche Cobas Fara automated analyzer. Priority for clinical chemistry tests was assigned in the order listed above. Determination of plasma concentrations of pyrazinamide was considered the highest priority. Due to the limited number (10) of male mice per group, all the plasma samples available from male mice were used for pyrazinamide determination, and serum chemistry determinations were not performed.

### Plasma Pyrazinamide Concentrations

All blood samples were taken from the retroorbital sinus of control and dosed mice under CO_2_/O_2_ anesthesia at 30, 90, and 120 minutes after gavage administration. Samples from three males and three females-A per group were collected into a tube containing EDTA. Plasma was obtained and stored at approximately −70° C until the analyses were performed. Plasma samples were diluted with distilled water and an internal standard solution was added (1 mg benzamide/mL water). Samples were mixed and analyzed on an HPLC equipped with a Zorbax C8 column and UV detector (267 nm). Chromatography was achieved by gradient elution with a mobile phase of acetonitrile:0.01 heptanesulfonic acid in water (pH 3.5) in the following proportions: 4:96 for 11 minutes, 4:96 to 15:85 in 3 minutes, 15:85 for five minutes, 15:85 to 4:96 in 3 minutes, and 4:96 for 18 minutes with a flow rate of 1 mL/minute. Retention times were approximately 10 minutes for pyrazinamide and 25 minutes for the internal standard. The minimum detection limit was 1 fig/mL. To characterize the internal dose, the toxicokinetic parameters C_max_, T_max_, and t_1/2_ were estimated from the data.

### Sperm Function Evaluation

Sperm motility was evaluated at necropsy. The left epididymis was isolated and weighed. The tail of the epididymis (cauda epididymis) was then removed from the epididymal body (corpus epididymis) and weighed. Modified Tyrode’s buffer was applied to slides and a small incision was made at the distal border of the cauda epididymis. The sperm effluxing from the incision were dispersed in the buffer on the slides, and the numbers of motile and nonmotile spermatozoa were counted for five fields per slide by two observers.

Following completion of sperm motility estimates, each left cauda epididymis was placed in buffered neutral saline solution. Caudae were finely minced and the tissue was incubated in the saline solution and then heat fixed at 65° C. Sperm density was then determined microscopically with the aid of a hemocytometer. To quantify spermatogenesis, testicular spermatid head count was determined by removing the tunica albuginea and homogenizing the left testis in phosphate-buffered saline containing 10% dimethyl sulfoxide. Homogenization-resistant spermatid nuclei were counted with a hemocytometer.

## Statistical Methods

Paternal and maternal body weight data were analyzed using Bartlett’s test of homogeneity of variances and the analysis of variance (Snedecor and Cochran, 1967). If Bartlett’s test was not significant (P>0.05) and the analysis of variance was significant (P<0.05), then Dunnett’s test (Dunnett, 1955) was used to identify the statistical significance of individual groups. If Bartlett’s test was significant (P < 0.05), the Kruskal-Wallis test (Hollander and Wolfe, 1973) was used; in cases where the Kruskal-Wallis test was significant (P≤0.05), Dunn’s (Dunn, 1964) method of multiple comparisons was used to identify the statistical significance of individual groups. These methods were also used to analyze fetal body weight and pup body weight (per litter), as well as all other evaluations involving continuous data. For F_0_ generation sires and dams, analysis of covariance (Snedecor and Cochran, 1967) was used to evaluate average body weight changes and average maternal body weight changes. Observations for delivered and dead conceptuses of the female-A dams, and fetuses from female-A dams caesarean-sectioned on an estimated day 14 of gestation, were excluded from fetal body weight summaries and statistical analyses.

Group means and standard deviations were calculated for hematology and clinical chemistry parameters and for terminal body and epididymis weights. Epididymis/body weight ratios were also calculated. Mean terminal body weights of males and females and mean epididymis weights and epididymis/body weight ratios of males in each dose group were compared to those of the control group by a two-tailed Student’s Mest. The standard deviations used in the f-tests were obtained by pooling the individual values for the control and dose groups. Hematology and clinical chemistry data were evaluated using Dunnett’s test.

Proportion data (e.g., clinical observation data and the incidences of pregnancy, resorption, death, and total resorption) for presumed pregnant mice were analyzed using the Cochran-Armitage test for a linear trend in proportions (Snedecor and Cochran, 1967) and Fisher’s exact test (Siegel, 1956).