# Introduction

Because acquired immunodeficiency syndrome (AIDS) is a disease of immune suppression, the majority of AIDS patients actually die from characteristic opportunistic infections (Hardy, 1991; Harkins and Herriot, 1992). As a result, the treatment of AIDS is increasingly one of combination therapy of antiretroviral drugs and antimicrobial drugs (Goldschmidt and Dong, 1992). Tuberculosis (TB) is one of the opportunistic diseases leading to mortality in AIDS patients (Nolan, 1992). AIDS patients with TB receive combination therapy with 3'-azido-3'-deoxythymidine (AZT) and antituberculosis drugs. Treatment for TB involves combination therapy with multiple antibacterial agents in order to eliminate the strains of organisms inducing TB including those resistant to isoniazid, the primary drug used in treating TB. The standard treatment regimen is isoniazid (300 mg/day), rifampin (600 mg/day or 450 mg/day for persons weighing less than 50 kg), and pyrazinamide (20 to 30 mg/kg per day) for the first 2 months of treatment. Isoniazid and rifampin are continued for another 7 months, for a total therapy duration of 9 months (CDC, 1987; Barnes et al., 1991). The inclusion of pyrazinamide in treatment regimens has made possible the shortening of therapy to 6 months (East and Central African/British Medical Research Council, 1986). Pyrazinamide is the synthetic pyrazine analogue of nicotinamide. Its molecular formula is C_5_H_5_N_3_O, and it has a molecular weight of 123.12. The daily dose for adults is 20 to 35 mg/kg orally, given in three or four equally spaced doses. The maximum quantity to be administered is 3 g per day, regardless of body weight.

## Absorption, Distribution, Metabolism, and Excretion

Pyrazinamide is well absorbed from the gastrointestinal tract, and it is distributed throughout the body. The oral administration of 1 g produces plasma concentrations of about 45 µg/mL at 2 hours and 10 /µg/mL at 15 hours. The drug is excreted primarily by renal glomerular filtration; urinary concentrations are 50 to 100 µg/mL for several hours after a single dose. Pyrazinamide is hydrolyzed to pyrazinoic acid and subsequently hydroxylated to 5-hydroxypyrazinoic acid, the major excretory product (Weiner and Tinker, 1972). Grossett et al. (1992) reported that 150 mg/kg pyrazinamide (considered to be a therapeutic dose) administered by gavage to female Swiss (CD-1^®^) mice resulted in serum concentrations similar to those of humans receiving pyrazinamide therapy.

## Toxicity

Injury to the liver is the most common and serious side effect of pyrazinamide. When a dose of 3 g per day (40 to 50 mg/kg body weight) is orally administered, signs and symptoms of hepatic disease appear in about 15% of patients, with jaundice appearing in 2% to 3% of patients, and death due to hepatic necrosis occurring in rare instances (Mandell and Sande, 1990). Mild and transient elevations of the plasma alanine and aspartate aminotransferases are the earliest abnormalities produced by the drug and occur approximately 2 weeks after initiation of therapy (Ramakrishnan et al., 1968). Baron and Bell (1974) have pointed out that such transient asymptomatic increases in the serum hepatic enzyme concentrations are also common during the early weeks of antituberculosis chemotherapy with other drugs, and these usually return to normal without interrupting or altering the regimen and are not clinically important.

Hepatotoxicity and nephrotoxicity occurred in male Wistar rats following the administration of 2.5 g/kg of pyrazinamide by gavage in 10% gum arabic (Zitkova et al., 1983). Bederka et al. (1975) have reported a LD_25_ for pyrazinamide in young adult female Swiss albino and Charles River mice (20 to 32 g) of 705 mg/kg of body weight following intraperitoneal administration in dimethyl sulfoxide. The LD_50_ data for pyrazinamide reported in the Registry of Toxic Effects of Chemical Substances are as follows: mouse, intraperitoneal, 1,680 mg/kg; mouse, subcutaneous, 2,793 mg/kg (RTECS, 1983).

## Genetic Toxicology

Roman and Georgian (1977) studied the comparative cytogenetic effects of para-aminosalicylic acid sodium salt, pyrazinamide, and rifampin in human peripheral blood cultures. The structural chromosomal lesions were randomly distributed between the different chromosome groups of the human karyotype; nearly 20% to 30% of affected cells had more than one lesion per metaphase. In the treatments with sodium para-aminosalicylate and pyrazinamide, the analysis of the frequencies of the cells carrying chromosomal aberrations and of the chromosomal lesion types indicated a dose-response correlation. The in vitro studies indicate a potential genetic hazard in the use of these drugs.

## Study Rationale

This study of pyrazinamide was conducted by the NIEHS as part of its program to evaluate the safety, in pregnant women and in the developing conceptus, of drugs used in the treatment of AIDS or the opportunistic infections accompanying AIDS. In the present study, effects on the motility and density of sperm were also evaluated. Tuberculosis is a frequent complication in AIDS and is commonly treated with pyrazinamide. Animal reproduction studies have not been conducted with pyrazinamide. Also, it is not known whether pyrazinamide can cause harm to the conceptus when administered to pregnant women or can affect reproductive capacity (PDR, 1994). To facilitate the screening of chemicals for reproductive and developmental toxicity, the National Toxicology Program has developed a protocol that combines aspects of other studies designed for this purpose (Morrissey et al., 1989; Harris et al., 1992). This protocol is intended to provide results that may be used to set dose levels for a definitive developmental toxicity study, if necessary. Since the liver has been shown to be a target organ of pyrazinamide in humans, liver enzyme determinations were included depending on sample availability.

Based on mouse and human therapeutic doses and mouse toxic doses reported in the literature (Bederka et al., 1975), the high dose selected for this study was approximately 8 times the mouse therapeutic dose and 50 times the human therapeutic dose. However, blood levels indicated the high dose was close to 10 times the mouse therapeutic dose (Grossett et al., 1992). The mid and low doses were spaced at 400 mg/kg intervals from the high dose.