# 2 SYNOPSIS

NAME OF SPONSOR: Eunice Kennedy Shriver National Institute of Child Health and Human Development

NAME OF STUDY DRUGS: Lorazepam, Diazepam

Title of Study: Use of Lorazepam for the Treatment of Pediatric Status Epilepticus: A Randomized, Double-Blinded Trial of Lorazepam and Diazepam

Principal Investigators: James Chamberlain, MD, PODS Site Principal Investigator, Children’s National Medical Center

Publication (ref.):

Chamberlain JM, Lorazepam vs diazepam for pediatric status epilepticus: a randomized clinical trial. JAMA. 2014 Apr 23–30;311(16):1652–60. doi: 10.1001/jama.2014.2625.24756515

Study Period:; (date of first enrollment): March 6, 2008; (date of last completed): March 13, 2012 | Phase of Development: III

Primary Objective:

To determine the efficacy and safety of lorazepam compared to diazepam for pediatric status epilepticus (SE).

Primary Hypotheses:

Efficacy:

Is there a significant difference between the proportions of participants randomized and treated with either lorazepam or diazepam who have cessation of convulsions within 10 minutes of the initial administration of the study drug and a sustained absence of convulsions for 30 minutes from the initial administration of the study drug?

Safety:

Is there a difference between the proportions of participants randomized and treated with either lorazepam or diazepam who experience severe or life-threatening respiratory depression within 4 hours of the initial administration of the study drug?

Secondary Objectives:

- To determine population pharmacokinetics (PK) of lorazepam using sparse sampling.
- To determine the feasibility of identifying participants for informed consent prior to arrival in SE for a randomized control trial (RCT) of lorazepam vs. diazepam for pediatric SE.
- To describe the experience of community consultation and public disclosure as per 21 CFR 50.24.
- To determine the feasibility of enrolling pediatric participants under an exception from informed consent.
- To determine participants’ and parents’ attitudes and reactions to an exception from informed consent approach.

Methodology: This study was a double-blinded, randomized, controlled trial comparing the efficacy and short-term safety of lorazepam versus diazepam in pediatric status epilepticus. For participants in whom SE was not terminated by benzodiazepines, data was collected prospectively regarding subsequent medications, dosing, and effectiveness.

Participants were grouped according to the following age groups:

- 3 months to less than 3 years;
- 3 years to less than 13 years; or
- 13 years to less than 18 years.

Fourteen hospitals from the United States and Canada participated in this study. For this study there were 2 cohorts of participants based on the process of informed consent:

Cohort 1 (preconsented) included potential participants whose parents or legally authorized representative (LAR) provided informed consent prior to a potential study participant presented to the Emergency department (ED) in SE.

Cohort 2 (Exception From Informed Consent, EFIC) included participants who appeared in the ED with SE and qualified for the study, but had not given prior consent. These participants were enrolled under the EFIC regulations. The participant was enrolled (dosed) with study medication under an EFIC. Once the participant was stabilized, a research staff member approached the parent or LAR to obtain informed consent to continue the participant’s participation in the study. If a parent or LAR refused continued participation, no further study procedures were performed. Safety data were collected in accordance with federal regulations

Number of Participants (planned and analyzed):

Planned: 262

Analyzed: 258

Diagnosis and Main Criteria for Inclusion:

Inclusion Criteria:

1. Age 3 months to less than 18 years; and
2. Generalized tonic-clonic status epilepticus, defined as:
  a. Three or more generalized tonic-clonic seizures within the last hour and currently experiencing a convulsion (i.e., the current convulsion may be the third convulsion within one hour); or
  b. Two or more generalized tonic-clonic seizures in succession with no recovery of consciousness between seizures and currently experiencing a convulsion (i.e., the current convulsion may be the second convulsion without recovery of consciousness after the first convulsion); or
  c. A seizure that lasts at least 5 minutes that is either generalized tonic clonic in its entirety or starts focal and then generalizes. The seizure must be associated with loss of consciousness.

Exclusion Criteria:

Prior to drug administration:

1. Known pregnancy;
2. Shock prior to study drug (sustained hypotension requiring inotropic therapy);
3. Significant dysrhythmia prior to study drug (other than sinus tachycardia);
4. Need for emergent surgical intervention and general anesthesia for a condition present prior to study drug;
5. Known sensitivity to benzodiazepines or known contraindication to benzodiazepine use; or
6. Use of a benzodiazepine within 1 week of presentation;
7. Prior participation in this study.

Exclusion Criteria if known after study drug administration::

1. Confirmed pregnancy;
2. Use of a benzodiazepine within 1 week of presentation.
3. Parent/guardian refusal to give informed consent by the methods described;
4. Participant’s refusal to assent (for participants ≥ 7 yrs old and mentally competent to understand study procedures) by the methods described, or as required by the local IRB.

Test Product, Dose and Mode of Administration, Batch Number: lorazepam/diazepam;

Lorazepam 0.1 mg/kg IVP, maximum of 4 mg, Manufactured by Baxter Health Corporation.

Lorazepam batch numbers: 037125, 038062, 041370, 069067, 088013, 089028, 127008, 088013, 127008EV

Duration of Treatment: Up to 2 doses five minutes apart

Reference Therapy, Dose and Mode of Administration, Batch Number:

Diazepam 0.2 mg/kg IVP, maximum of 8 mg.

Batch numbers for drug manufacturer by Baxter Health Corporation. – 08908, 106092,

Batch numbers for drug manufactured by Hospira Inc. - 61-174-EV, 67-201-EV, 73-208-EV, 75-495-EV, 80-516-EV, 96-024-EV, 96-172-EV

Duration of Treatment: Up to 2 doses five minutes apart

Criteria for Evaluation:

Efficacy: The primary efficacy endpoint was a composite endpoint, defined as the proportion of participants who have both (1) a cessation of convulsions within 10 minutes of the initial administration of the study medication and (2) a sustained absence of convulsions for 30 minutes from the initial administration of the study medication.

The secondary efficacy endpoints included:

1. Number and proportion of participants with a sustained absence of convulsions for 30 minutes.
2. Number and proportion of participants with a sustained absence of convulsions for 60 minutes.
3. Number and proportion of participants requiring a second dose of study medication.
4. Number and proportion of participants who require only a single dose of study medication and have no recurring seizures within 30 minutes.
5. Number of minutes from the end of the first administration of the study medication (lorazepam or diazepam) to the cessation of the initial convulsion.
6. Number of minutes from study medication administration until new seizure activity is observed (within 24 hours).
7. Number of minutes from study medication administration until there is a return to baseline functioning/mental status (duration of sedation).

Safety: The primary safety endpoint was the proportion of participants who experienced severe or life-threatening respiratory depression within four hours of the initial administration of the study medication.

The secondary safety endpoint was the proportion of participants who experienced any serious adverse events considered to be possibly, probably, or definitely related to the study medication (lorazepam or diazepam).

STUDY POPULATION

The Safety population was based on all randomizations who received study drug. We chose this population because some participants presented in status more than once and received study medication on more than one occasion. There were 310 randomizations: 162 (52%) were randomized to diazepam and 148 (48%) were randomized to lorazepam. All randomizations where the participant received at least one dose of study medication were included. All safety analyses were performed on the safety population.

The Modified Intention-to-Treat (MITT) population included all randomized participants who received at least one dose of study medication and met the protocol definition of status epilepticus. The population excluded 15 participants with randomization errors from ▬ If a participant had more than one randomization, the MITT population only included data from the first enrollment in which the participant met the MITT definition. There were 258 MITT participants: 131 in diazepam and 127 in lorazepam.

Per protocol (PP) population included all participants in the MITT population without a major protocol deviation. Major protocol deviations were defined prior to the unblinding of the data. There were 209 per protocol participants: 102 in diazepam and 107 in lorazepam.

Sensitivity population (ITT) included all MITT population (258 participants) and qualified ▬ randomization errors (15 participants meeting the MITT criteria).

Efficacy analyses performed on the MITT population were regarded as the primary analyses to make statistical inferences regarding efficacy of the trial. The primary efficacy analyses performed based on the sensitivity population and the per protocol population were considered sensitivity analyses.

STATISTICAL METHODS:

The statistical analyses were conducted using both summary statistics and hypothesis testing and were performed using SAS version 9.2 or higher. R version 2.12.2 or higher were used for Cox regression analysis with random effect for the safety analysis that included the duplicate enrollments. Demographic characteristics and efficacy and safety variables were summarized using descriptive summaries.

The analysis of the primary efficacy endpoint was based on a logistic regression model. Independent factors in the model were treatment assignment and age stratum. A Cochran-Mantel-Haenszel (CMH) test, stratified by site, was performed to determine if there is a significant difference in proportions between the treatment groups for each of these endpoints.

All safety analyses were performed on the safety population except where noted. Each analysis consisted of a summary of data within each age strata, treatment group and overall. A Cochran-Mantel-Haenszel (CMH) test, stratified by age group, was performed to determine if there is a significant difference in proportions between the treatment groups by both the primary safety outcome and the secondary safety outcome.

RESULTS:

Efficacy:

Primary Efficacy Endpoint - There were 258 MITT participants in the analysis for the primary efficacy endpoint; 131 in the diazepam group, and 127 in the lorazepam group. Efficacy rates were 71% among the diazepam participants and 74% among the lorazepam participants, respectively, (p=0.69; reference to lorazepam adjusted odds ratio=0.89; 95% CI: 0.51–1.56) after adjusting for age stratum. There was an association of efficacy with age: the overall age effect was significant with p-value of 0.01. The comparison of the 3 yrs - <13 yrs to the 3 mo - <3 yrs age group was significant, odds ratio: 2.45 [95% CI: 1.3–4.5]; the comparison of the >13 yrs to the 3 mo - <3 yrs comparison was not significant, odds ratio: 1.9 [95% CI: 0.7–5.5]). A sensitivity analysis for the primary endpoint was completed on the sensitivity population; this population included all MITT population (258 participants) and qualified ▬ randomization errors (15 participants meeting the MITT criteria). There were 273 participants (140 diazepam, 133 lorazepam) after adding back the 15 ▬ randomization errors to the MITT population. Efficacy rates were 72% for diazepam population and 73% for lorazepam population. The overall p-value for the assessment of treatment difference was 0.99.

Secondary Efficacy Endpoints - The results for the first four secondary endpoints are presented in the table below; no differences between treatment groups were detected:

| Diazepam (N=131) | Lorazepam (N=127) | Total (N=258) | P value
Sustained absence of convulsions for 30 minutes | 86 (65.6%) | 86 (67.7%) | 172 (66.7%) | 0.70
Sustained absence of convulsions for 60 minutes | 83 (63.4%) | 86 (67.7%) | 169 (65.5%) | 0.21
Participants requiring a second dose of study medication | 41 (31.3%) | 41 (32.3%) | 82 (31.8%) | 0.81
Participants who require only a single dose of study medication and have no recurring seizures within 30 minutes | 81 (61.8%) | 79 (62.2%) | 160 (62.0%) | 0.74

The analysis of the time to initial cessation of convulsions was based on a time-to-event analysis using a Cox proportional hazards regression model. One hundred and fifteen participants (87.8%) in the diazepam group and 110 participants (86.6%) treated with lorazepam reported cessation of the initial convulsions. The median time to cessation in the diazepam group was 1.0 minute (95% CI, 1.0–2.0) and 2.0 minutes (95% CI, 1.0–2.0) for the participants receiving lorazepam. Cox proportional hazards model stratified by age group shows there was no evidence to suggest that the time to initial cessation of convulsions differed between the treatment arms (p-value=0.39, hazard ratio: 1.1 [95% CI: 0.86–1.47]).

The analysis of the time to new seizure activity was based on a time-to-event analysis using a Cox proportional hazards regression model. Thirty-six participants (27.5%) in the diazepam group and 25 participants (19.7%) treated with lorazepam reported new seizure activities within 24 hours. The median time to event for the diazepam was 25.5 minutes and 22.0 minutes for lorazepam. Cox regression model shows no significant difference between treatment arms with respect to time to new seizure activity (p-value=0.12 adjusting for site, hazard ratio: 1.51 [95% CI: 0.9–2.53]).

In the analysis of number of minutes from study medication administration until there was a return to baseline mental status (duration of sedation within 4 hours), the diazepam group reported a higher rate of return to baseline mental status than the lorazepam group (55.0% vs. 35.4%). The median time to event for the diazepam group was 120 minutes (95% CI, 119–125) and 239 minutes for the lorazepam group. Using the Cox regression model stratified by age group, there is a significant difference between treatment arms (p-value<0.0001 after adjusting for site, hazard ratio: 2.18 [95% CI: 1.48–3.20]).

Safety:

The primary safety endpoint was the proportion of randomizations who experienced severe or life-threatening respiratory depression within four hours of the initial administration of the study medication. The analysis was based on a time-to-event analysis using the Cox proportional hazards regression model. The youngest age group of 3 months to <3 years had rates of 14.3% and 22.5% in the diazepam and lorazepam groups, respectively. For children aged 3 years to <13 years, the rate of the primary safety endpoint was 17.6% in diazepam group vs. 15.9% in lorazepam group and in the oldest age group (≥13 years) the event rate was 17.6% for diazepam randomizations and 0% for lorazepam randomizations. Please note there were only 31 randomizations in the age group of ≥13 years. The overall rate of primary safety endpoint was 16.0% in diazepam and 17.6% in lorazepam. The Cochran-Mantel-Haenszel (CMH) test, stratified by age group was performed to determine differences in proportions between the two treatment groups. A p-value of 0.74 indicates no difference between arms for the primary safety endpoint after adjusting for age group. Cox proportional hazards model shows no difference in time to severe or life threatening respiratory depression within four hours between treatment arms, p=0.74.

Secondary safety endpoints included occurrence of least one SAE, adverse clinical events and critical and near critical adverse events, treatment-emergent adverse event (TEAE) of respiratory depression (all severities at any time post-dosing) and TEAE of sedation. These endpoints were evaluated in both the safety population and PP population (included all participants in the MITT population without a major protocol deviation) using the Cochran-Mantel-Haenszel (CMH) test stratified by age group.

The proportion of randomizations that reported at least one SAE was 26.5% for diazepam and 30.4% for lorazepam. The SAE rates were higher in the 3 month to <3 year age group (28.6% in diazepam and 38.0% in lorazepam) than in the 3 year to <13 year age group (25.0% in diazepam and 27.0% in lorazepam). No statistically significant differences were seen between the treatment arms (p-value=0.47). Results on PP population were similar, with 21.6% of diazepam and 27.1% of lorazepam randomizations experiencing an SAE, p-value of 0.37. Percentage of randomizations with adverse clinical events was 75.3% in the diazepam group and 79.7% in the lorazepam group.

The rate of adverse clinical events in the lorazepam group was higher among randomizations in the 3 month to <3 year age group (81.7% lorazepam vs. 74% diazepam) and similar between treatment arms in the 3 year to <13 year age group (81.0% in lorazepam and 79.4% in diazepam) and in the ≥13 year old age group (64.3% in lorazepam and 64.7% in diazepam). CMH test shows no significant difference between treatment groups (p-value =0.37). Similar results were found in analyses based on the PP population with 73.5% in the diazepam group and 82.2% in the lorazepam group; the p-value was 0.15.

Critical and near critical adverse events were reported in 18% of the randomizations in the diazepam group and 20% of randomizations in the lorazepam group. Similar results were reported across treatment arms in the 3 month to <3 year age group (16% diazepam and 25% lorazepam) and in the 3 year to <13 year age group (19% lorazepam and 21% diazepam). No critical or near critical adverse events were reported in the lorazepam arm of the ≥13 year old age group and 18 % of randomizations in the diazepam arm of this age group reported these events. There was no significant difference detected between the treatment arms, p-value is 0.61. Similar results were obtained for PP population with a p-value of 0.59.

The rate of any respiratory depression was 45.7% in the diazepam arm and 36.5% in lorazepam arm. The rates of respiratory depression within each age group were: 49.4% diazepam vs. 45.1% lorazepam in the 3 month to <3 year age group, 48.5% diazepam vs. 33.3% lorazepam in the 3 year to <13 year age group and 17.6% diazepam vs. 7.1% lorazepam in the ≥13 year old age group. CMH test results found no significant treatment differences, p-value=0.08. Results are similar in the sub-group analysis on PP population with 45.1% with respiratory depression in the diazepam arm and 35.5% in the lorazepam arm with p-value=0.12 for respiratory depression rate treatment comparisons.

While randomizations in the diazepam arm had higher rates of respiratory depression, higher rates of sedation were reported in the lorazepam arm. Overall reported sedation rates were 50.0% in the diazepam arm and 66.9% in the lorazepam arm. The largest difference in the reported sedation rates were in the 3 year to <13 year age group with 55.9% of the diazepam arm and 74.6% of the lorazepam arm reporting a TEAE of sedation; p-value=0.003. Treatments arms have significantly different rates of TEAE sedation. Similar results are obtained in the sub-group analysis based on PP population with overall sedation rates of 49.0% in the diazepam arm and 70.1% in lorazepam arm, CMH p-value=0.002.

Conclusions:

The results of this study do not support the hypothesis that lorazepam is superior to diazepam for pediatric status epilepticus for either efficacy or safety. The only significant differences between the two medications is that lorazepam caused higher rates of sedation and time to return to baseline mental status was longer in the lorazepam group.

Date of the Report: September 15, 2015