# 13 DISCUSSION AND OVERALL CONCLUSIONS

## 13.1 Discussion Overall Conclusions

The results of this study do not support the hypothesis that lorazepam is superior to diazepam for pediatric status epilepticus for either efficacy or safety. The only significant differences between the two medications is that lorazepam caused higher rates of sedation and time to return to baseline mental status was longer in the lorazepam group.