# 12 SAFETY EVALUATION

All safety analyses were performed on the safety population except where noted. Each analysis consisted of a summary of data within each age strata, treatment group and overall. Because the safety population includes data from duplicate randomizations of some participants, the term ‘randomization’ will be used instead of ‘participants’ in some portions of this section.

## 12.1 Primary Safety Endpoint and Analyses

The primary safety endpoint was the proportion of randomizations who experienced severe or life-threatening respiratory depression within four hours of the initial administration of the study medication. Severe or life-threatening respiratory depression is defined as respiratory depression (apnea longer than 20 seconds or RR age-specific criteria: < 2 yr: < 24 bpm; 2 yr to <7 yr: <20 bpm; 7 yr to <13 yr: <16 bpm; 13 yr & above: <12 bpm) requiring any of the following:

- Assisted BVM ventilation;
- Endotracheal intubation;
- Tracheostomy; or
- Ventilatory support above baseline for ventilator-dependent participants. (Note: There were two ventilator dependent participants in this study and only one met the primary safety endpoint of needing oxygen above his/her baseline needs).

The use of supplemental oxygen was recorded on the vital signs eCRF (primary source) and the aspiration eCRF. Any participant who had supplemental oxygen and bag valve or intubation marked on the vital signs eCRF who did not meet the primary safety endpoint was included in a secondary analysis of the safety endpoint. Some participants received supplemental oxygen (BVM) solely during the pre-dose period. Pre-dose only cases did not count towards primary safety endpoint.

Cochran-Mantel-Haenszel (CMH) test, stratified by age group, was performed to determine if there was a significant difference in proportions between the treatment groups for both the primary safety and secondary safety outcomes. The number and proportion of randomizations with severe or life-threatening respiratory depression is presented.

The analysis of the time to severe or life-threatening respiratory depression within four hours of the initial administration of study medication was based on a time-to-event analysis using the Cox proportional hazards regression model. An independent factor in the Cox proportional hazards regression model was treatment assignment; the model was also stratified by age group. Time to severe or life-threatening respiratory depression was reported using quartiles (25th, 50th, 75th) with 95% confidence intervals for each treatment group from Kaplan-Meier analysis. Kaplan-Meier survival curves were constructed for each treatment group. The primary safety analysis was performed on the safety population (all dosed randomizations) and on the PP population.

A summary of results is presented in Table 12-1 and Table 12-2 below and in Table 14.3.1.1 and Figure 14.4.2.

Severe or life threatening respiratory depression within four hours by age group is shown in Table 12-1. The youngest age group of 3 months to <3 years had rates of 14.3% and 22.5% in the diazepam and lorazepam groups, respectively. For children aged 3 years to <13 years, the rate of the primary safety endpoint was 17.6% in diazepam group vs. 15.9% in lorazepam group and in the oldest age group (≥13 years) the event rate was 17.6% for diazepam randomizations and 0% for lorazepam randomizations. Please note there were only 31 randomizations in the age group of ≥13 years. The overall rate of primary safety endpoint was 16.0% in diazepam and 17.6% in lorazepam. The Cochran-Mantel-Haenszel (CMH) test, stratified by age group was performed to determine differences in proportions between the two treatment groups. A p-value of 0.74 indicates no difference between arms for the primary safety endpoint after adjusting for age group. Cox proportional hazards model shows no difference in time to severe or life threatening respiratory depression within four hours between treatment arms, p=0.74. Kaplan-Meier estimates of time to severe or life threatening respiratory depression by treatment is presented in Table 12-2 and Figure 12-1. The missing values of quantiles were due to the large portion of censored participants for this endpoint. Figure 12-1 shows a marginally lower probability of developing severe or life threatening respiratory depression in the diazepam arm, however, comparison for overall survival between the diazepam and lorazepam arms is not statistically significant. The sensitivity analysis performed on the PP population yielded a p-value of 0.51, which is not significant.

Table 12-1 Primary Safety Endpoint

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148) | P-value
Number of Randomizations | 77 | 71 | 68 | 63 | 17 | 14 | 162 | 148
Randomizations That Met Primary Safety Endpoint | 11 (14.3%) | 16 (22.5%) | 12 (17.6%) | 10 (15.9%) | 3 (17.6%) | 0 | 26 (16.0%) | 26 (17.6%) | 0.74

Table 12-2 Time to Severe or Life-threatening Respiratory Depression

| Diazepam (N=162) | Lorazepam (N=148) | Total (N=310)
Number of Randomizations
Num of Censored Randomizations | 136 (84.0%) | 122 (82.4%) | 258 (83.2%)
Num of Randomizations with Severe or Life-threatening Respiratory Depression | 26 (16.0%) | 26 (17.6%) | 52 (16.8%)
Stratified Analysis by age group
Hazard Ratio (Relative to lorazepam) | 0.91
(95% CI) | (0.53, 1.57)
p value (Log Rank) | 0.74

Figure 12-1 Time to Severe or Life-threatening Respiratory Depression by Treatment Group

## 12.2 Secondary Safety Endpoints and Analyses

Secondary endpoints included occurrence of least one SAE, adverse clinical events and critical and near critical adverse events, treatment-emergent adverse event (TEAE) of respiratory depression (all severities at any time post-dosing) and TEAE of sedation. These endpoints were evaluated in both the safety population and PP population using the Cochran-Mantel-Haenszel (CMH) test stratified by age group.

Results are presented in Table 12-3 below and Tables 14.3.1.1 and 14.3.1.3.

The proportion of randomizations that reported at least one SAE was 26.5% for diazepam and 30.4% for lorazepam. The SAE rates were higher in the 3 month to <3 year age group (28.6% in diazepam and 38.0% in lorazepam) than in the 3 year to <13 year age group (25.0% in diazepam and 27.0% in lorazepam). No statistically significant differences were seen between the treatment arms (p-value=0.47). Results on PP population were similar, with 21.6% of diazepam and 27.1% of lorazepam randomizations experiencing an SAE, p-value of 0.37. Percentage of randomizations with adverse clinical events was 75.3% in the diazepam group and 79.7% in the lorazepam group. The rate of adverse clinical events (see Section 12.5.1.4 for description) in the lorazepam group was higher among randomizations in the 3 month to <3 year age group (81.7% lorazepam vs. 74% diazepam) and similar between treatments in the 3 year to <13 year age group (81.0% in lorazepam and 79.4% in diazepam) and in the ≥13 year old age group (64.3% in lorazepam and 64.7% in diazepam). CMH test shows no significant difference between treatment groups (p-value =0.37). Similar results were found in analyses based on the PP population with 73.5% in the diazepam group and 82.2% in the lorazepam group; the p-value was 0.15.

Critical and near critical adverse events were reported in 17.9% of randomizations in the diazepam group and 20.3% of randomizations in the lorazepam group. Similar results were reported across treatment arms in the 3 month to <3 year age group (15.6% diazepam and 25.4% lorazepam) and in the 3 year to <13 year age group (19.0% lorazepam and 20.6% diazepam). No critical or near critical adverse events were reported in the lorazepam group in the ≥13 year old age group and 17.6 % of randomizations in the diazepam arm of this age group reported these events. There was no significant difference detected between the treatment arms, p-value is 0.61. Similar results were obtained for PP population with a p-value of 0.59.

The rate of any respiratory depression was 45.7% in the diazepam arm and 36.5% in lorazepam arm. The rates of respiratory depression within each age group were: 49.4% diazepam vs. 45.1% lorazepam in the 3 month to <3 year age group, 48.5% diazepam vs. 33.3% lorazepam in the 3 year to <13 year age group and 17.6% diazepam vs. 7.1% lorazepam in the ≥13 year old age group. CMH test results found no significant treatment differences, p-value=0.08. Results are similar in the sub-group analysis on PP population with 45.1% with respiratory depression in the diazepam arm and 35.5% in the lorazepam arm with p-value=0.12 for respiratory depression rate treatment comparisons.

While randomizations in the diazepam arm had higher rates of respiratory depression, higher rates of sedation were reported in the lorazepam arm. Overall reported sedation rates were 50.0% in the diazepam arm and 66.9% in the lorazepam arm. The largest difference in the reported sedation rates were in the 3 year to <13 year age group with 55.9% of the diazepam arm and 74.6% of the lorazepam arm reporting a TEAE of sedation; p-value=0.003. Treatments arms have significantly different rates of TEAE sedation. Similar results are obtained in the sub-group analysis based on PP population with overall sedation rates of 49.0% in the diazepam arm and 70.1% in lorazepam arm, CMH p-value=0.002.

Table 12-3 Secondary Safety Endpoints

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148) | P-value
Number of Randomizations | 77 | 71 | 68 | 63 | 17 | 14 | 162 | 148
Randomizations That Met Secondary Safety Endpoints
Randomizations with at least one SAE | 22 (28.6%) | 27 (38.0%) | 17 (25.0%) | 17 (27.0%) | 4 (23.5%) | 1 (7.1%) | 43 (26.5%) | 45 (30.4%) | 0.466
Randomizations with Adverse Clinical Events | 57 (74.0%) | 58 (81.7%) | 54 (79.4%) | 51 (81.0%) | 11 (64.7%) | 9 (64.3%) | 122 (75.3%) | 118 (79.7%) | 0.369
Randomizations with Critical and Near Critical Adverse Events | 12 (15.6%) | 18 (25.4%) | 14 (20.6%) | 12 (19.0%) | 3 (17.6%) | 0 | 29 (17.9%) | 30 (20.3%) | 0.613
Randomizations with Respiratory Depression | 38 (49.4%) | 32 (45.1%) | 33 (48.5%) | 21 (33.3%) | 3 (17.6%) | 1 (7.1%) | 74 (45.7%) | 54 (36.5%) | 0.084
Randomizations with Sedation | 35 (45.5%) | 44 (62.0%) | 38 (55.9%) | 47 (74.6%) | 8 (47.1%) | 8 (57.1%) | 81 (50.0%) | 99 (66.9%) | 0.003

## 12.3 Extent of Exposure

A summary of study medication administration is presented overall, by dose and dosing order, by age strata and treatment in Table 14.1.8.

## 12.4 Adverse Events

An adverse event (AE) is defined as any untoward medical occurrence in a participant in a clinical investigation. Treatment emergent adverse events are those AEs that occur after administration of the study product and are therefore temporally associated with the use of the study product. Pre-existing conditions are not considered AEs unless they worsen in intensity or frequency during the course of the clinical investigation.

AEs were coded using the Medical Dictionary for Regulatory Affairs (MedDRA v16.0) coding dictionary. Treatment-emergent AE was defined as any event with a start date and time occurring on or after initial administration of study medication or, if pre-existing, worsening after treatment with study medication is initiated. Two AEs that met the criteria for primary endpoint and but not TEAE were included based on the study PI decision.

### 12.4.1 Brief Summary of Adverse Events

An overall summary of TEAEs by age at enrollment and Treatment arm is presented in Table 12-4. Overall, 682 adverse events in 265 of the 310 safety randomizations (85%) were reported in this study. TEAEs rates were similar in diazepam [137 (85%)] and lorazepam [128 (86%)] arms.

The maximum severity of any TEAE was mild for 69 (43%), moderate for 27 (17%), severe for 12 (7%), life threatening for 28 (17%) and 1 death for the 162 diazepam randomizations. Among the 148 lorazepam randomizations, the maximum severity of any TEAE was mild in 60 (41%) randomizations, moderate in 27 (18%) and severe in 14 (10%) randomizations, life threatening in 26 (18%) randomizations and 1 death. Out of the 162 diazepam randomizations 19 (12%) randomizations were reported with TEAEs that were probably or definitely related to study medication, compared to 19/148 (13%) for lorazepam treated randomizations.

Table 12-4 Summary of TEAE by Age and treatment

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Number of Events/Randomizations
Number of TEAE | 154 | 175 | 155 | 137 | 38 | 23 | 347 | 335
Randomizations with at least one TEAE | 67 (87.0%) | 64 (90.1%) | 56 (82.4%) | 55 (87.3%) | 14 (82.4%) | 9 (64.3%) | 137 (84.6%) | 128 (86.5%)
Highest Severity Per Randomization
Mild | 35 (45.5%) | 25 (35.2%) | 25 (36.8%) | 28 (44.4%) | 9 (52.9%) | 7 (50.0%) | 69 (42.6%) | 60 (40.5%)
Moderate | 12 (15.6%) | 14 (19.7%) | 13 (19.1%) | 11 (17.5%) | 2 (11.8%) | 2 (14.3%) | 27 (16.7%) | 27 (18.2%)
Severe | 7 (9.1%) | 9 (12.7%) | 5 (7.4%) | 5 (7.9%) | 0 | 0 | 12 (7.4%) | 14 (9.5%)
Life threatening | 13 (16.9%) | 16 (22.5%) | 13 (19.1%) | 10 (15.9%) | 2 (11.8%) | 0 | 28 (17.3%) | 26 (17.6%)
Death | 0 | 0 | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 1 (0.6%) | 1 (0.7%)
Strongest Relationship Per Randomization
Unrelated | 8 (10.4%) | 5 (7.0%) | 3 (4.4%) | 3 (4.8%) | 3 (17.6%) | 1 (7.1%) | 14 (8.6%) | 9 (6.1%)
Possibly related | 51 (66.2%) | 51 (71.8%) | 46 (67.6%) | 46 (73.0%) | 7 (41.2%) | 3 (21.4%) | 104 (64.2%) | 100 (67.6%)
Probably related | 8 (10.4%) | 7 (9.9%) | 7 (10.3%) | 5 (7.9%) | 2 (11.8%) | 5 (35.7%) | 17 (10.5%) | 17 (11.5%)
Definitely related | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 2 (11.8%) | 0 | 2 (1.2%) | 2(1.4%)

### 12.4.2 Display of Treatment-Emergent Adverse Events

Treatment-emergent AEs and SAE data are presented in the following tables:

- Summary of Primary and Secondary Safety Endpoints by Age Stratum and Treatment Group in Section 14, Table 14.3.1.1 and 14.3.1.2
- Overall summary of TEAEs by Age Stratum and Treatment Group in Section 14, Table 14.3.2
- TEAEs by MedDRA System Organ Class, Preferred Term, Age Stratum and Treatment Group in Section 14, Table 14.3.3.1.
- TEAEs by MedDRA System Organ Class, Preferred Term, Severity, Age Stratum and Treatment Group in Section 14, Table 14.3.3.2.
- TEAEs by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Stratum and Treatment Group in Section 14, Table 14.3.3.3.
- Serious Adverse Events by System Organ Class, Preferred Term, Age Stratum and Treatment Group in Section 14, Table 14.3.3.4.
- Summary of Adverse Events that have led to premature discontinuation of study medication by Age Stratum and Treatment Group in Section 14, Table 14.3.3.5.
- Summary of Adverse Clinical Events by Age Stratum and Treatment Group in Table 14.3.4.1.
- Adverse Clinical Events by MedDRA System Organ Class, Preferred Term, Age Stratum and Treatment Group in Section 14, Table 14.3.4.2.
- Adverse Clinical Events by MedDRA System Organ Class, Preferred Term, Severity, Age Stratum and Treatment Group in Section 14, Table 14.3.4.3.
- Adverse Clinical Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Stratum and Treatment Group in Section 14, Table 14.3.4.4.
- Summary of Critical or Near Critical Adverse Events by Age Stratum and Treatment Group in Section 14, Table 14.3.5.1.
- Critical or Near Critical Adverse Events by MedDRA System Organ Class, Preferred Term, Age Stratum and Treatment Group in Section 14, Table 14.3.5.2.
- Critical or Near Critical Adverse Events by MedDRA System Organ Class, Preferred Term, Severity, Age Stratum and Treatment Group in Section 14, Table 14.3.5.3.
- Critical or Near Critical Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Stratum and Treatment Group in Section 14, Table 14.3.5.4.

Individual participant data associated with TEAEs are listed in Section 16 as follows:

- All AEs (Listing 16.2.2.14),
- All SAEs (Listing 16.2.15),
- All AEs leading to premature discontinuation (Listing 16.2.2.14.1).
- All Adverse Clinical Events (Listing 16.2.2.14.2).
- All Critical or Near Critical Adverse Events (Listing 16.2.2.14.3).

### 12.4.3 Analysis of Treatment-Emergent Adverse Events

#### 12.4.3.1 Most Frequently Reported Treatment-Emergent Adverse Events

TEAEs reported by at least 10% of the randomizations are summarized in Table 12-5. Sedation was the most frequently reported TEAE, with 204 events occurring in 180 (58%) of the 310 randomizations (50% of the diazepam treated randomizations and 67% of the lorazepam treated randomizations). Respiratory depression was reported in 46% of the diazepam treated randomizations and in 37% of the lorazepam treated randomizations; hypercapnia was reported in 16% of the diazepam treated randomizations and in 18% of the lorazepam treated randomizations; hypoxia was reported in 8% of the diazepam treated randomizations and in 10% of the lorazepam treated randomizations. Another frequent TEAE was hypotension which was reported in 12% of the diazepam treated randomizations and in 10% of the lorazepam treated randomizations.

Table 12-5 Frequently Occurring (≥ 10% of the Randomizations) Treatment-Emergent Adverse Events

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Nervous system disorders
Sedation | 35 (45.5%) | 44 (62.0%) | 38 (55.9%) | 47 (74.6%) | 8 (47.1%) | 8 (57.1%) | 81 (50.0%) | 99 (66.9%)
Respiratory, thoracic and mediastinal disorders
Respiratory depression | 38 (49.4%) | 32 (45.1%) | 33 (48.5%) | 21 (33.3%) | 3 (17.6%) | 1 (7.1%) | 74 (45.7%) | 54 (36.5%)
Hypercapnia | 8 (10.4%) | 13 (18.3%) | 14 (20.6%) | 12 (19.0%) | 4 (23.5%) | 2 (14.3%) | 26 (16.0%) | 27 (18.2%)
Hypoxia | 7 (9.1%) | 4 (5.6%) | 5 (7.4%) | 10 (15.9%) | 1 (5.9%) | 1 (7.1%) | 13 (8.0%) | 15 (10.1%)
Vascular disorders
Hypotension | 4 (5.2%) | 7 (9.9%) | 10 (14.7%) | 7 (11.1%) | 5 (29.4%) | 0 | 19 (11.7%) | 14 (9.5%)

#### 12.4.3.2 Treatment-Emergent Adverse Events by Intensity

There were two deaths reported, one in the 3 year to <13 year age group in lorazepam arm due to anaplastic medulloblastoma and the other one in the ≥13 year age group in diazepam arm due to prolonged seizure. Both deaths were not related to study medication.

Overall there were 68 life threatening TEAEs in 54 randomizations: 28 (17%) in 162 diazepam randomizations and 26 (18%) in lorazepam randomizations. All deaths and life threatening TEAEs were considered to be SAEs.

There were 41 severe TEAEs reported in 26 randomizations: 12 (7%) in the diazepam arm and 14 (10%) in the lorazepam arm.

One hundred and thirty two (132) moderate TEAEs were reported in 54 randomizations: 17% of diazepam treated randomizations and 18% of lorazepam treated randomizations.

Four hundred and thirty-nine (64%) of the 682 TEAEs were of mild severity: 43% of the diazepam randomizations and 41% of the lorazepam randomizations reporting mild had the highest severity.

#### 12.4.3.3 Treatment-Emergent Adverse Events by Relationship

Four TEAEs were considered to be “definitely” related to study medication. These 4 TEAEs were reported in 2 (1%) of the diazepam randomizations (respiratory depression (N=1) and Sedation (N=1))) and 2 (1%) of the lorazepam randomizations (sedation (N=2)). Out of the 682 TEAEs, 41 (6%) were considered to be “probably” related to study medication. 21 occurred in diazepam treated randomizations and 20 occurred in lorazepam treated randomizations. These included 1 gastrointestinal disorders, 9 nervous system disorders and 11 respiratory, thoracic and mediastinal disorders. Probably related TEAEs in lorazepam randomizations included 13 nervous system disorder and 7 respiratory, thoracic and mediastinal disorders.

Four hundred and sixty two (68%) of the TEAEs were “possibly” related and 175 (26%) were “unrelated” to study medication. In the diazepam arm there were 104 (64%) randomizations with maximum relatedness of “possibly” and 14 (9%) randomizations with maximum relatedness of “unrelated”. In the lorazepam arm there were 100 (68%) participants with “possibly” and 9 (6%) with “unrelated” as maximum relatedness.

### 12.4.4 Listing of Adverse Events by Participant

All AEs for each participant are provided in listing 16.2.4. The listing includes system/organ/class (SOC), preferred term, study period, start and stop date/time for each TEAE, study medication dose at time of event, relationship to study medication, action taken, severity, outcome, treatment given, and SAE flag (Yes, No).

## 12.5 Deaths, Other Serious Adverse Events, and Other Significant Adverse Events

### 12.5.1 Listing of Deaths, Other Serious Adverse Events and Other Significant Adverse Events

#### 12.5.1.1 Deaths

See Section 12.4.3.2

#### 12.5.1.2 Other Serious Adverse Events

One hundred and twelve (112) SAEs were reported in 88 randomizations during the study as summarized in Table 12-6. One SAE was reported as being definitely related to diazepam treatment (respiratory depression). Six SAEs were reported as being probably related to diazepam and 4 SAEs were reported as being probably related to lorazepam.

Forty-three (27%) of the 162 diazepam randomizations reported 57 SAEs. Thirty (19%) diazepam randomizations reported SAEs in respiratory, thoracic and mediastinal disorders. Other SAEs were in blood and lymphatic system disorders, cardiac disorders, congenital, familial and genetic disorders, general disorders and administration site conditions, infections and infestations, neoplasms benign, malignant and unspecified, nervous system disorders, psychiatric disorders and vascular disorders.

Fifty-five (55) SAEs were reported in 45 (30%) lorazepam treated randomizations. Thirty-four (23%) lorazepam randomizations reported SAEs in respiratory, thoracic and mediastinal disorders. Other SAEs were in general disorders and administration site conditions infections and infestations, nervous system disorders, pregnancy, puerperium and perinatal conditions, psychiatric disorders and vascular disorders.

Table 12-6 Serious Adverse Events

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Number of Events/Randomizations
Number of SAEs | 31 | 29 | 20 | 24 | 6 | 2 | 57 | 55
Randomizations with at least one SAE | 22 (28.6%) | 27 (38.0%) | 17 (25.0%) | 17 (27.0%) | 4 (23.5%) | 1 (7.1%) | 43 (26.5%) | 45 (30.4%)

#### 12.5.1.3 Other Significant Adverse Events

#### 12.5.1.4 Adverse Clinical Events (ACE)

Four hundred and ninety six (496) adverse clinical events were reported in 240 randomizations: 122 (75%) in diazepam arm and 118(80%) in lorazepam arm. The adverse clinical events included respiratory depression, bradycardia, hypotension, hypercarbia measured at one hour, hypoxemia, aspiration of gastric contents, clinically significant agitation (Riker score >5), clinically significant sedation (Riker score <3). The overall summary of ACEs by age at enrollment and treatment arm is shown in Table 12-7.

The maximum severity of any ACE was mild for 66 (41%), moderate for 23 (14%), severe for 7 (4%) and life threatening for 26 (16%) of the 162 diazepam randomizations. The 148 lorazepam randomizations had a maximum severity of mild in 61 (41%) randomizations, moderate in 20 (14%), severe in 12 (8%) and life threatening in 25 (17%) randomizations. No deaths were reported as caused by ACE for either treatment arms. Diazepam randomizations had 18/162 (11%) ACEs that were probably or definitely related to study medication, compared to 18/148 (12%) of lorazepam treated randomizations.

Table 12-7 Adverse Clinical Events

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Number of Events/Randomizations
Number of Treatment-Emergent Adverse Clinical Events | 105 | 117 | 129 | 109 | 23 | 13 | 257 | 239
Randomizations with Adverse Clinical Events | 57 (74.0%) | 58 (81.7%) | 54 (79.4%) | 51 (81.0%) | 11 (64.7%) | 9 (64.3%) | 122 (75.3%) | 118 (79.7%)
Highest Severity Per Randomization
Mild | 34 (44.2%) | 27 (38.0%) | 25 (36.8%) | 27 (42.9%) | 7 (41.2%) | 7 (50.0%) | 66 (40.7%) | 61 (41.2%)
Moderate | 9 (11.7%) | 9 (12.7%) | 13 (19.1%) | 9 (14.3%) | 1 (5.9%) | 2 (14.3%) | 23 (14.2%) | 20 (13.5%)
Severe | 3 (3.9%) | 8 (11.3%) | 4 (5.9%) | 4 (6.3%) | 0 | 0 | 7 (4.3%) | 12 (8.1%)
Life threatening | 11 (14.3%) | 14 (19.7%) | 12 (17.6%) | 11 (17.5%) | 3 (17.6%) | 0 | 26 (16.0%) | 25 (16.9%)
Death | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Strongest Relationship Per Randomization
Unrelated | 2 (2.6%) | 3 (4.2%) | 2 (2.9%) | 0 | 1 (5.9%) | 1 (7.1%) | 5 (3.1%) | 4 (2.7%)
Possibly related | 48 (62.3%) | 48 (67.6%) | 45 (66.2%) | 45 (71.4%) | 6 (35.3%) | 3 (21.4%) | 99 (61.1%) | 96 (64.9%)
Probably related | 7 (9.1%) | 6 (8.5%) | 7 (10.3%) | 5 (7.9%) | 2 (11.8%) | 5 (35.7%) | 16 (9.9%) | 16 (10.8%)
Definitely related | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 2 (11.8%) | 0 | 2 (1.2%) | 2 (1.4%)

##### 12.5.1.4.1 Critical and Near Critical Adverse Events (CNCAE)

The critical and near critical adverse events included severe or life threatening respiratory depression, severe or life threatening bradycardia, severe or life threatening hypotension, ventricular dysrhythmia and Cardiac arrest. The overall summary of TEAEs by age at enrollment and treatment arm is shown in Table 12-8.

Sixty-four (64) CNCAEs were reported in 59 randomizations: 29 (18%) in diazepam arm and 30 (20%) in lorazepam arm.

The maximum severity of any CNCAE was severe for 4 (3%) and life threatening for 25 (15%) of the 162 diazepam randomizations. The 148 lorazepam randomizations had a maximum severity of severe in 6 (4%) and life threatening in 24 (16%) randomizations. No death was reported caused by CNCAEs for both treatment arms. Diazepam randomizations had 6/162 (4%) CNCAEs that were probably related and 1(1%) was definitely related to study medication, compared to 2/148 (1%) probably related for lorazepam treated randomizations.

Table 12-8 Critical and Near Critical Adverse Events

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Number of Events/Randomizations
Number of Critical and Near Critical Adverse Events | 13 | 18 | 15 | 14 | 4 | 0 | 32 | 32
Randomizations with Critical and Near Critical Adverse Events | 12 (15.6%) | 18 (25.4%) | 14 (20.6%) | 12 (19.0%) | 3 (17.6%) | 0 | 29 (17.9%) | 30 (20.3%)
Severity (All Critical and Near Critical AEs)
Severe | 2 | 5 | 3 | 1 | 0 | 0 | 5 | 6
Life threatening | 11 | 13 | 12 | 13 | 4 | 0 | 27 | 26
Highest Severity Per Randomization
Severe | 1 (1.3%) | 5 (7.0%) | 3 (4.4%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 6 (4.1%)
Life threatening | 11 (14.3%) | 13 (18.3%) | 11 (16.2%) | 11 (17.5%) | 3 (17.6%) | 0 | 25 (15.4%) | 24 (16.2%)
Relationship (All Critical and Near Critical AEs)
Unrelated | 1 | 3 | 4 | 3 | 0 | 0 | 5 | 6
Possibly related | 11 | 13 | 7 | 11 | 2 | 0 | 20 | 24
Probably related | 1 | 2 | 4 | 0 | 1 | 0 | 6 | 2
Definitely related | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0
Strongest Relationship Per Randomization
Unrelated | 1 (1.3%) | 3 (4.2%) | 4 (5.9%) | 1 (1.6%) | 0 | 0 | 5 (3.1%) | 4 (2.7%)
Possibly related | 10 (13.0%) | 13 (18.3%) | 6 (8.8%) | 11 (17.5%) | 1 (5.9%) | 0 | 17 (10.5%) | 24 (16.2%)
Probably related | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 0 | 1 (5.9%) | 0 | 6 (3.7%) | 2 (1.4%)
Definitely related | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0

### 12.5.2 Narratives of Deaths, other serious adverse events, and certain other significant adverse events

## 12.6 Clinical Laboratory Evaluation

Descriptive summaries (mean, standard deviation (SD), 95% confidence interval (CI) of mean, median, minimum, and maximum) of observed values and changes from baseline to 24 hour visit values were presented by age stratum and treatment group for hematology clinical laboratory values in Tables 14.3.6.1, 14.3.6.2 and Figure 14.4.3.1, chemistry clinical laboratory values in Tables 14.3.7.1, 14.3.7.2 and Figure 14.4.3.2. In these figures, treatment A refers to diazepam arm and treatment B is lorazepam arm.

### 12.6.1 Listing of individual laboratory measurements by participant and abnormal laboratory value

The listing of individual laboratory measurements by participants and abnormal laboratory value is presented in 16.2.16 and 16.2.17

## 12.7 Vital Signs, Physical Findings, and Other Observations related to Safety

Descriptive summaries (mean, standard deviation (SD), 95% confidence interval (CI) of mean, median, minimum, and maximum) of observed values and changes from baseline to 4 hour visit values were presented by age stratum and treatment group for respiration rate, pulse, O2 saturation, SBP, DBP in Tables 14.3.8.1, 14.3.8.2 and 14.3.9.1, ECG in Table 14.3.10 and Riker Score in 14.3.11.

## 12.8 Prior and Concomitant Medications/Procedures

Concomitant medications used during the study were coded according to the WHO (World Health Organization) drug classification system. Table 14.1.7.1 presents medications started before the first study dose and Table 14.1.7.2 presents medications started after the first study dose. Table 12-9 lists the most frequently used (≥10% of the randomizations) concomitant medications started before study medication and Table 12-10 lists the most frequently used (≥10% of the randomizations) concomitant medications started after study medication.

Before the start of study medication, 73 (52%) diazepam randomizations and 61(46%) lorazepam randomizations received concomitant medications. The most commonly used medication was paracetamol in 21% of the diazepam randomizations and 17% of the lorazepam randomizations.

After the start of study medication, 105 (75%) diazepam randomizations and 92 (69%) lorazepam randomizations received concomitant medications. Sixty (43%) of diazepam randomizations and 63 (47%) of lorazepam randomizations received paracetamol. Other frequently used concomitant medications included ceftriaxone (21% in diazepam vs. 20% in lorazepam), lidocaine (12% in diazepam vs. 19% in lorazepam), and ibuprofen (18% in diazepam vs. 13% in lorazepam).

Table 12-9 Concomitant Medications started before study medication

| Diazepam (N=140) | | Lorazepam (N=133)
WHO Class | Pts With Medn | Total Medns | Pts With Medn | Total Medns
Medication Name | N (%) | N | N (%) | N
NERVOUS SYSTEM
PARACETAMOL | 30 (21.4%) | 33 | 22 (16.5%) | 26
MUSCULO-SKELETAL SYSTEM
IBUPROFEN | 16 (11.4%) | 18 | 15 (11.3%) | 17

Table 12-10 Concomitant Medications started after study medication

| Total
| Diazepam (N=140) | | Lorazepam (N=133)
WHO Class | Pts With Medn | Total Medns | Pts With Medn | Total Medns
Medication Name | N (%) | N | N (%) | N
NERVOUS SYSTEM
PARACETAMOL | 60 (42.9%) | 105 | 63 (47.4%) | 101
ANTIINFECTIVES FOR SYSTEMIC USE
CEFTRIAXONE | 30 (21.4%) | 36 | 26 (19.5%) | 34
LIDOCAINE | 17 (12.1%) | 21 | 25 (18.8%) | 28
MUSCULO-SKELETAL SYSTEM
IBUPROFEN | 25 (17.9%) | 34 | 17 (12.8%) | 19
ANTIINFECTIVES FOR SYSTEMIC USE
CEFOTAXIME | 16 (11.4%) | 22 | 17 (12.8%) | 29
VANCOMYCIN | 22 (15.7%) | 34 | 17 (12.8%) | 29
NERVOUS SYSTEM
FENTANYL | 14 (10%) | 45 | 20 (15%) | 55
MUSCULO-SKELETAL SYSTEM
ROCURONIUM | 14 (10%) | 22 | 18 (13.5%) | 20
ALIMENTARY TRACT AND METABOLISM
RANITIDINE | 14 (10%) | 18 | 15 (11.3%) | 18
ANTIINFECTIVES FOR SYSTEMIC USE
ACICLOVIR | 14 (10%) | 19 | 13 (9.8%) | 21

## 12.9 Safety Conclusions

We found no significant differences in safety between the two study medications. Significant respiratory depression occurred in approximately 17% of randomizations in each group. Hypoxemia occurred in 8% of diazepam randomizations and 10.1% of lorazepam randomizations. Hypotension occurred in 11.7% of diazepam and 9.5% of lorazepam randomizations. Overall, life-threatening adverse events occurred in 17% and 18% of diazepam and lorazepam randomizations, respectively. The lorazepam group had a higher incidence of sedation and longer recovery time from sedation.