# 11 EFFICACY EVALUATION

A total of 303 unique participants were randomized in this study and all randomizations where the participant received at least one dose of study medication are included in the safety population. There were seven duplicative enrollments of participants that were previously enrolled in the study. If a participant was randomized more than once, the first randomization that met the MITT criteria was included in efficacy analysis.

Randomization errors were identified at one site (▬). All participants enrolled at this site prior to ▬ (16 participants, 17 randomizations, 15 participants met the MITT criteria) had randomization errors and were excluded from the MITT and per protocol populations.

## 11.1 Data Sets Analyzed

The Safety population was based on randomizations instead of participants because there were duplicate randomizations for some participants. There were 310 randomizations: 162 (52%) were randomized to diazepam and 148 (48%) were randomized to lorazepam. All randomizations where the participant received at least one dose of study medication were included. All safety analyses were performed on the safety population.

The MITT population included all randomized participants who received at least one dose of study medication and met the protocol definition of status epilepticus. The population also excluded participants with randomization errors from ▬ (as defined above). If a participant had more than one randomization, the MITT population only included data from the first enrollment in which the participant met the MITT definition. There were 258 MITT participants: 131 in diazepam and 127 in lorazepam.

Per protocol (PP) population included all participants in the MITT population without a major protocol deviation. Major protocol deviations were defined prior to the unblinding of the data. There were 209 per protocol participants: 102 in diazepam and 107 in lorazepam.

Sensitivity population (ITT) included all MITT population (258 participants) and qualified ▬ randomization errors (15 participants meeting the MITT criteria).

Efficacy analyses performed on the MITT population were regarded as the primary analyses to make statistical inferences regarding efficacy of the trial. The primary efficacy analyses performed based on the sensitivity population and the per protocol population were considered sensitivity analyses.

## 11.2 Demographic and Other Baseline Characteristics

Baseline demographics and disease characteristics are summarized for both ITT population in Table 11-1 and Tables 14.1.3.1.

For ITT population, diazepam participants had a median age of 2.8 years (range 0.3–28 years) and lorazepam participants’ median age was 3.3 (range 0.3–17.8 years). In the diazepam group, fifty-four percent of the participants were males and 50% of the participants were Caucasian while 47% were males and 46% were Caucasian in the lorazepam group. The percent of participants who identified themselves as being of Hispanic or Latino ethnicity were 32% in the diazepam group and 29% in the lorazepam group. Data for height and weight at baseline were not reported for some participants. Given the circumstances at the time of study medication administration, the number of missing height and weight data was not unexpected. The standardized height and weight percentiles were calculated by adjusting for the appropriate population, age- and sex-specific levels for the normal population provided by 2000 CDC growth charts. The median height and weight percentiles for the diazepam group were 32 and 34 respectively, 33rd and 34th percentile, respectively, for the lorazepam group. The median BMI percentile was 65th in the diazepam group and 52nd in the lorazepam group.

Table 11-1 Demographic Characteristics (ITT Population)

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=72) | Lorazepam (N=62) | Diazepam (N=55) | Lorazepam (N=60) | Diazepam (N=13) | Lorazepam (N=11) | Diazepam (N=140) | Lorazepam (N=133)
Age at Baseline (years)
Mean (SD) | 1.4 (0.6) | 1.4 (0.8) | 6.1 (2.6) | 6.2 (2.5) | 16.6 (4.1) | 16.1 (1.3) | 4.7 (4.9) | 4.8 (4.5)
Median (Min-Max) | 1.3 (0.3 – 2.9) | 1.3 (0.3 – 2.9) | 5.2 (3.0 – 11.7) | 5.8 (3.0 – 12.0) | 15.5 (13.1 – 28.0) | 16.1 (13.2 – 17.8) | 2.8 (0.3 – 28.0) | 3.3 (0.3 – 17.8)
Gender
Male | 39 (54.2%) | 30 (48.4%) | 27 (49.1%) | 29 (48.3%) | 9 (69.2%) | 4 (36.4%) | 75 (53.6%) | 63 (47.4%)
Female | 33 (45.8%) | 32 (51.6%) | 28 (50.9%) | 31 (51.7%) | 4 (30.8%) | 7 (63.6%) | 65 (46.4%) | 70 (52.6%)
Ethnicity
Hispanic or Latino | 26 (36.1%) | 17 (27.4%) | 17 (30.9%) | 19 (31.7%) | 2 (15.4%) | 2 (18.2%) | 45 (32.1%) | 38 (28.6%)
Not Hispanic or Latino | 44 (61.1%) | 44 (71.0%) | 37 (67.3%) | 40 (66.7%) | 9 (69.2%) | 8 (72.7%) | 90 (64.3%) | 92 (69.2%)
Not reported | 2 (2.8%) | 1 (1.6%) | 1 (1.8%) | 1 (1.7%) | 2 (15.4%) | 1 (9.1%) | 5 (3.6%) | 3 (2.3%)
Race
American Indian or Alaska Native | 0 | 0 | 0 | 1 (1.7%) | 1 (7.7%) | 0 | 1 (0.7%) | 1 (0.8%)
Asian | 3 (4.2%) | 1 (1.6%) | 1 (1.8%) | 2 (3.3%) | 0 | 0 | 4 (2.9%) | 3 (2.3%)
Black or African American | 25 (34.7%) | 23 (37.1%) | 18 (32.7%) | 23 (38.3%) | 4 (30.8%) | 6 (54.5%) | 47 (33.6%) | 52 (39.1%)
Native Hawaiian or Pacific Islander | 1 (1.4%) | 0 | 1 (1.8%) | 0 | 0 | 0 | 2 (1.4%) | 0
White or Caucasian | 34 (47.2%) | 26 (41.9%) | 29 (52.7%) | 31 (51.7%) | 7 (53.8%) | 4 (36.4%) | 70 (50.0%) | 61 (45.9%)
More Than 1 Race | 5 (6.9%) | 8 (12.9%) | 3 (5.5%) | 2 (3.3%) | 0 | 0 | 8 (5.7%) | 10 (7.5%)
Other | 4 (5.6%) | 2 (3.2%) | 2 (3.6%) | 1 (1.7%) | 1 (7.7%) | 0 | 7 (5.0%) | 3 (2.3%)
Not reported | 0 | 2 (3.2%) | 1 (1.8%) | 0 | 0 | 1 (9.1%) | 1 (0.7%) | 3 (2.3%)
Height Percentile at Baseline
N | 66 | 58 | 44 | 52 | 12 | 9 | 122 | 119
Mean (SD) | 43.3 (33.5) | 41.8 (36.2) | 31.8 (36.8) | 41.2 (34.0) | 28.7 (34.1) | 30.3 (35.3) | 37.7 (35.1) | 40.6 (35.0)
Median (Min-Max) | 39.8 (0.0 – 99.8) | 33.4 (0.0 – 100.0) | 11.2 (0.0 – 100.0) | 33.8 (0.0 – 99.9) | 3.1 (0.1 – 81.2) | 19.1 (0.0 – 98.1) | 31.9 (0.0 – 100.0) | 32.9 (0.0 – 100.0)
Weight Percentile at Baseline
N | 54 | 52 | 45 | 49 | 11 | 4 | 110 | 105
Mean (SD) | 32.8 (30.3) | 34.6 (29.7) | 49.1 (34.4) | 46.4 (35.2) | 34.4 (36.9) | 7.4 (8.5) | 39.6 (33.3) | 39.1 (32.8)
Median (Min-Max) | 21.7 (0.0 – 99.9) | 30.8 (0.0 – 100.0) | 49.1 (0.0 – 99.8) | 46.4 (0.0 – 99.9) | 15.1 (0.0 – 92.7) | 6.0 (0.0 – 17.5) | 34.1 (0.0 – 99.9) | 34.1 (0.0 – 100.0)
BMI Percentile at Baseline
N | 10 | 12 | 40 | 46 | 11 | 3 | 61 | 61
Mean (SD) | 42.7 (38.2) | 42.6 (41.4) | 63.4 (34.8) | 54.6 (35.1) | 47.3 (38.9) | 0.5 (0.8) | 57.1 (36.6) | 49.6 (37.3)
Median (Min-Max) | 33.8 (0.1 – 96.1) | 32.9 (0.0 – 97.2) | 72.0 (0.0 – 100.0) | 58.4 (0.0 – 99.8) | 64.7 (0.0 – 93.3) | 0.1 (0.0 – 1.5) | 64.7 (0.0 – 100.0) | 52.0 (0.0 – 99.8)

Medical History was coded using the Medical Dictionary for Regulatory Affairs (MedDRA v15.1) coding dictionary. Table 11-2 provides the most frequently (≥10% of the participants) reported preferred term in medical history. One hundred ninety six participants reported a history of seizures prior to the current illness: thirty six reported a history of febrile seizures and 159 reported a history of afebrile seizures. Other frequently reported events in the medical histories included developmental delay (34% in diazepam vs. 33% in lorazepam), pyrexia (28% in diazepam vs. 27% in lorazepam), vomiting (18% in diazepam vs. 24% in lorazepam), epilepsy (15% in diazepam vs. 21% in lorazepam) and cough (12% in diazepam vs. 20% in lorazepam).

Table 11-2 Most Frequently Reported Events in Medical History (ITT Population)

| Total
| Diazepam (N=140) | | Lorazepam (N=133)
System Organ Class | Pts With MH | Total MH | Pts With MH | Total MH
Preferred Term | N (%) | N | N (%) | N
General disorders and administration site conditions
Developmental delay | 48 (34.3%) | 49 | 44 (33.1%) | 44
General disorders and administration site conditions
Pyrexia | 39 (27.9%) | 41 | 36 (27.1%) | 37
Gastrointestinal disorders
Vomiting | 26 (18.6%) | 26 | 32 (24.1%) | 32
Nervous system disorders
Epilepsy | 21 (15%) | 21 | 28 (21.1%) | 30
Respiratory, thoracic and mediastinal disorders
Cough | 17 (12.1%) | 18 | 26 (19.5%) | 26

Table 14.1.7.1 summarizes prior medications by WHO drug coding (World Health Organization). Paracetamol was reported as the most frequently used prior medication. Thirty (21%) diazepam participants and 22(17%) lorazepam participants received Paracetamol and 16 (11%) diazepam participants and 15 (11%) lorazepam participants received Ibuprofen as the prior medication.

Table 11-3 (Table 14.1.4) summarizes the qualifying seizures just prior to administration of study medication. Prior to treatment, a higher percentage of lorazepam participants (87%) had a seizure lasting more than 1 minute compared to diazepam participants (78%). The most frequent primary qualifying seizure etiology was febrile seizure (35% in diazepam vs. 30% in lorazepam). The next most frequently reported seizure was idiopathic seizure (26% in diazepam vs. 33% in lorazepam).

Table 11-3 Summary of Qualifying Seizures (ITT Population)

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=72) | Lorazepam (N=62) | Diazepam (N=55) | Lorazepam (N=60) | Diazepam (N=13) | Lorazepam (N=11) | Diazepam (N=140) | Lorazepam (N=133)
Duration of Seizures <1 minute Prior to Treatment
Yes | 15 (20.8%) | 7 (11.3%) | 14 (25.5%) | 5 (8.3%) | 1 (7.7%) | 4 (36.4%) | 30 (21.4%) | 16 (12.0%)
No | 57 (79.2%) | 54 (87.1%) | 41 (74.5%) | 54 (90.0%) | 11 (84.6%) | 7 (63.6%) | 109 (77.9%) | 115 (86.5%)
N/A | 0 | 1 (1.6%) | 0 | 1 (1.7%) | 1 (7.7%) | 0 | 1 (0.7%) | 2 (1.5%)
Primary Seizures Etiology
Febrile | 36 (50.0%) | 32 (51.6%) | 13 (23.6%) | 8 (13.3%) | 0 | 0 | 49 (35.0%) | 40 (30.1%)
Remote Symptomatic | 5 (6.9%) | 6 (9.7%) | 7 (12.7%) | 6 (10.0%) | 1 (7.7%) | 2 (18.2%) | 13 (9.3%) | 14 (10.5%)
Acute Symptomatic | 13 (18.1%) | 7 (11.3%) | 8 (14.5%) | 8 (13.3%) | 2 (15.4%) | 0 | 23 (16.4%) | 15 (11.3%)
Idiopathic | 14 (19.4%) | 13 (21.0%) | 15 (27.3%) | 24 (40.0%) | 8 (61.5%) | 7 (63.6%) | 37 (26.4%) | 44 (33.1%)
Low Levels of Anti-Epileptic Drug | 2 (2.8%) | 4 (6.5%) | 8 (14.5%) | 9 (15.0%) | 2 (15.4%) | 0 | 12 (8.6%) | 13 (9.8%)
Other | 2 (2.8%) | 0 | 4 (7.3%) | 5 (8.3%) | 0 | 2 (18.2%) | 6 (4.3%) | 7 (5.3%)

## 11.3 Measurement of Treatment Compliance

All participants were treated in the ED. Therefore, each dose of study medication administration was given and monitored by ED staff, then reviewed by study personnel if the ED staff member was not a member of the study personnel. The manual of procedures provided guidelines for study medication dosing.

## 11.4 Efficacy Results and Tabulations of Individual Participant Data

### 11.4.1 Analysis of Efficacy

#### 11.4.1.1 Primary endpoint

The primary efficacy endpoint was a composite endpoint, defined as the proportion of participants who had both (1) a cessation of convulsions within 10 minutes of the initial administration of the study medication and (2) a sustained absence of convulsions for 30 minutes from the initial administration of the study medication.

The null and alternative hypotheses for the primary efficacy endpoint are as follows:

H0: There is no difference between the proportions of participants randomized and treated with either lorazepam or diazepam who have cessation of convulsions within 10 minutes of the initial administration of the study medication and a sustained absence of convulsions for 30 minutes from the initial administration of the study medication.

H1: There is a difference between the proportions of participants randomized and treated with either lorazepam or diazepam who have cessation of convulsions within 10 minutes of the initial administration of the study medication and a sustained absence of convulsions for 30 minutes from the initial administration of the study medication.

The analysis of the primary efficacy endpoint was based on a logistic regression model. Independent factors in the model were treatment assignment and age stratum.

Results are summarized in Table 11-4 and Table 14.2.1.1. There were 258 MITT participants in this analysis; 131 in the diazepam group, and 127 in the lorazepam group. Efficacy rates were 71% among the diazepam participants and 74% among the lorazepam participants, respectively, (p=0.69; reference to lorazepam adjusted odds ratio=0.89; 95% CI: 0.51–1.56) after adjusting for age stratum. There was an association of efficacy with age: the overall age effect was significant with p-value of 0.01. The comparison of the 3 yrs to <13 yrs to the 3 mo to <3 yrs age group was significant, odds ratio: 2.45 [95% CI: 1.3–4.5]; the comparison of the ≥13 yrs to the 3 mo to <3yrs comparison was not significant, odds ratio: 1.9 [95% CI: 0.7–5.5]).

Table 11-4 Primary Efficacy Endpoint (MITT Population)

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=68) | Lorazepam (N=60) | Diazepam (N=51) | Lorazepam (N=57) | Diazepam (N=12) | Lorazepam (N=10) | Diazepam (N=131) | Lorazepam (N=127)
Primary Efficacy Endpoint | 44 (64.7%) | 38 (63.3%) | 41 (80.4%) | 47 (82.5%) | 8 (66.7%) | 9 (90.0%) | 93 (71.0%) | 94 (74.0%)
P- Value (treatment difference) | 0.69

A sensitivity analysis for the primary endpoint was completed on the sensitivity population using the same method; the result is provided in Table 14.2.1.1S. There were 273 participants (140 diazepam, 133 lorazepam) after adding back the 15 ▬ randomization errors to the MITT population. Efficacy rates were 72% for diazepam population and 73% for lorazepam population. The overall p-value for the assessment of treatment difference was 0.99.

#### 11.4.1.2 Secondary endpoints

##### 11.4.1.2.1 Repeated analysis of primary endpoint on PP population

The analysis of the proportion of participants with a cessation of convulsions within 10 minutes of the initial administration of the study medication and a sustained absence of convulsions for 30 minutes from the initial administration of the study medication was repeated (as described above under primary efficacy analysis) as a secondary (sensitivity) analysis on the per protocol (PP) population.

Results are summarized in Table 11-5 below. There were 209 PP participants after excluding participants with the major protocol deviations from MITT population: 102 received diazepam, 107 received lorazepam. Efficacy rates were 76.5% in the diazepam population and 79.4% in the lorazepam population. The p-value from the logistic regression model shows that the treatment difference was not significant with a p-value of 0.66 (reference to Lorazepam, odds ratio=0.86; 95% CI: 0.44–1.68) after adjusting for age stratum. The p-value of overall age effect was 0.03 (3 yrs - <13 yrs vs. 3 mo - <3 yrs comparison was significant, odds ratio: 2.65 [95% CI: 1.3–5.5]; >13 yrs vs. 3 mo - <3 yrs comparison was not significant, odds ratio: 1.7 [95% CI: 0.5–5.7]).

Table 11-5 Secondary Endpoint (Per Protocol Population)

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=48) | Lorazepam (N=48) | Diazepam (N=43) | Lorazepam (N=50) | Diazepam (N=11) | Lorazepam (N=9) | Diazepam (N=102) | Lorazepam (N=107)
Primary Efficacy Endpoint | 35 (72.9%) | 32 (66.7%) | 36 (83.7%) | 44 (88.0%) | 7 (63.6%) | 9 (100.0%) | 78 (76.5%) | 85 (79.4%)
P- Value (treatment difference) | 0.66

##### 11.4.1.2.2 Analysis of sustained absence of convulsions, second dose of study medication and single dose of study medication without recurring seizures

The following secondary efficacy endpoints were defined –

- Number and proportion of participants with a sustained absence of convulsions for 30 minutes.
- Number and proportion of participants with a sustained absence of convulsions for 60 minutes.
- Number and proportion of participants requiring a second dose of study medication.
- Number and proportion of participants who require only a single dose of study medication and have no recurring seizures within 30 minutes.

The corresponding analyses are described below. The endpoints were evaluated without pre-specifying a hierarchical order for assessment. Additionally, no adjustment was made for multiplicity. The analysis was performed on the MITT Populations stratified by analysis site using the Cochran-Mantel-Haenszel (CMH) test. The test was performed to determine if there was a significant difference in proportions between the treatment groups for each of these endpoints. Additional sensitivity analysis was also performed on the sensitivity population though it was not mentioned in the SAP (Appendix 16.1.9).

These results are summarized in Table 11-6 below and in Tables 14.2.2.1 and 14.2.2.1S.

A total of 86 (65.6%) participants treated with diazepam and 86 (67.7%) participants treated with lorazepam reported a sustained absence of convulsions for 30 minutes. The p-value for the difference was 0.70 after adjusting for site, indicating no difference between treatment groups. The sensitivity result was similar (p-value =0.79).

The proportion of participants with a sustained absence of convulsions for 60 minutes was similar between the two treatment groups; eighty three (63.4%) participants in the diazepam group and 86 (67.7%) in the lorazepam group with a p-value of 0.21. P-value from sensitivity analysis was 0.26.

The proportion of participants requiring a second dose of study medication showed similar results in the two treatment groups: 41 (31.3%) in the diazepam group and 41 (32.3%) in the lorazepam group (p-value =0.81). Sensitivity analysis also shows no significant difference between the treatment groups (p-value=0.55).

In addition, the proportion of participants who required only a single dose of study medication and had no recurring seizures within 30 minutes were not significantly different between treatment groups: 81 (61.8%) in the diazepam group and 79 (62.2%) in the lorazepam group ( p-value = 0.74). The results were similar for the sensitivity analysis (p-value=0.65).

Table 11-6 Other Secondary Endpoints (MITT Population)

| Diazepam (N=131) | Lorazepam (N=127) | Total (N=258) | P value
Sustained absence of convulsions for 30 minutes | 86 (65.6%) | 86 (67.7%) | 172 (66.7%) | 0.70
Sustained absence of convulsions for 60 minutes | 83 (63.4%) | 86 (67.7%) | 169 (65.5%) | 0.21
Participants requiring a second dose of study medication | 41 (31.3%) | 41 (32.3%) | 82 (31.8%) | 0.81
Participants who require only a single dose of study medication and have no recurring seizures within 30 minutes | 81 (61.8%) | 79 (62.2%) | 160 (62.0%) | 0.74

##### 11.4.1.2.3 Analysis of time from the end of the first administration of the study medication (Lorazepam or Diazepam) to the cessation of the initial convulsion

The analysis of the time to initial cessation of convulsions was based on a time-to-event analysis using a Cox proportional hazards regression model. Participants who received second-line medication were censored at the time these treatments were initiated. Independent factor in the Cox proportional hazards regression model was treatment assignment. The model was stratified by age group. Time to cessation of convulsions was reported using quartiles (25th, 50th, 75th) with their 95% confidence intervals for each treatment group. Kaplan-Meier survival curves were constructed for each treatment group; the median time to cessation of convulsions was estimated using the Kaplan-Meier estimates.

These results are summarized in Table 11-7 and Figure 11-1 below and in Table 14.2.2.2.A and Figure 14.4.1.1.

One hundred and fifteen participants (87.8%) in the diazepam group and 110 participants (86.6%) treated with lorazepam reported cessation of the initial convulsions. The median time to cessation in the diazepam group was 1.0 minute (95% CI, 1.0–2.0) and 2.0 minutes (95% CI, 1.0–2.0) for the participants receiving lorazepam. Cox proportional hazards model stratified by age group shows there was no evidence to suggest that the time to initial cessation of convulsions differ between the treatment arms (p-value=0.39, hazard ratio: 1.1 [95% CI: 0.86–1.47]). Figure 11-1 graphically shows that time to cessation of initial convulsion was higher for the lorazepam group. However, the difference between the treatment groups was not statistically significant. The sensitivity analysis was performed and results were similar (Table 14.2.2.2S.A and Figure 14.4.1.1S).

Table 11-7 Analysis of Time to Initial Cessation of Convulsions (MITT Population)

| Diazepam (N=131) | Lorazepam (N=127)
Number of Participants
Num of Censored Participants | 16 (12.2%) | 17 (13.4%)
Num of Participants with Initial Cessation of Convulsion | 115 (87.8%) | 110 (86.6%)
Time to Cessation of Initial Convulsion (mins)
Median (95% CI) | 1.0 (1.00, 2.00) | 2.0 (1.00, 2.00)
25% Percentile (95% CI) | 0.0 (0.00, 1.00) | 1.0 (0.00, 1.00)
75% Percentile (95% CI) | 5.0 (3.00, 10.00) | 7.0 (4.00, 12.00)
Range | 0, 1285 | 0, 366
Cox Proportional Hazards Regression Stratified Analysis Stratified by Age Group
Hazard Ratio (Relative to lorazepam) | | 1.13
(95% CI) | | (0.86, 1.47)
p value (Log Rank) | | 0.39

Figure 11-1 Time to Cessation of Initial Convulsion by Treatment Group

##### 11.4.1.2.4 Analysis of time from study medication administration until observation of new seizure activity (within 24 hours)

The analysis of the time to new seizure activity was based on a time-to-event analysis using a Cox proportional hazards regression model. Participants who received second-line or third-line medication were censored at the time these treatments were initiated. In addition, participants undergoing coma induction or receiving paralytics/sedatives for intubation were censored at the time of the induction. Independent factors in the Cox proportional hazards regression model were treatment assignment and site. Time to new seizure activity was reported using quartiles (25th, 50th, 75th) with their 95% confidence intervals for each treatment group. Kaplan-Meier survival curves were constructed for each treatment group; the median time to new seizure activity was estimated using the Kaplan-Meier estimates.

These results are summarized in Table 11-8 and Figure 11-2 below and in Table 14.2.2.2.B and Figure 14.4.1.2.

Thirty-six participants (27.5%) in the diazepam group and 25 participants (19.7%) treated with lorazepam reported new seizure activities within 24 hours. The median time to event (among participants with an event) for the diazepam was 25.5 minutes and 22.0 minutes for lorazepam. Cox regression model shows no significant difference between treatment arms with respect to time to new seizure activity (p-value=0.12 adjusting for site, hazard ratio: 1.51 [95% CI: 0.9–2.53]). Figure 11-2 displays the Kaplan-Meier survival graph for MITT participants by treatment group. The curves shows separation for the 2 treatment arms after 50 minutes but no statistically significant difference was detected. The sensitivity analysis was performed and had a p-value of 0.15 (Table 14.2.2.2S.B and Figure 14.4.1.2S). The site effect was not significant (p-value=0.96).

Table 11-8 Analysis of Time to New Seizure Activity (MITT Population)

| Diazepam (N=131) | Lorazepam (N=127)
Number of Participants
Num of Censored Participants | 95 (72.5%) | 102 (80.3%)
Num of Participants with New Seizure Activity | 36 (27.5%) | 25 (19.7%)
Time to event (Time to New Seizure Activity in mins) *
Median (95% CI) | * | *
25% Percentile (95% CI) | 127.0 (32, *) | * (89, *)
75% Percentile (95% CI) | * | *
Range | 1, 1440 | 3, 1440
Cox Proportional Hazards Regression
Hazard Ratio (Relative to Treatment Lorazepam) | | 1.51
(95% CI) | | (0.90, 2.53)
p value (Log Rank) | | 0.12

* un-estimable

Figure 11-2 Time to New Seizure Activity by Treatment Group

##### 11.4.1.2.5 Number of minutes from study medication administration until there is a return to baseline functioning/mental status (duration of sedation within 4 hours)

In the analysis of number of minutes from study medication administration until there was a return to baseline functioning/mental status (duration of sedation within 4 hours), data were reviewed in a blinded manner case by case by the study PI. Participants who received second-line or third-line medication were censored at the time these treatments were initiated. Also, participants receiving paralytics/sedatives for intubation were censored at the time of the intubation. In addition, participants were censored due to the occurrence of additional seizures prior to return to baseline per study PI’s decision (these would prolong the return to baseline, independent of study medication). Participants with unreported (missing) date and time for return to baseline and without any qualifying censored event mentioned above were censored at 4 hours after the start of study medication. Independent factors in the Cox proportional hazards regression model were treatment assignment and site. The model was stratified by age group. Time to cessation of convulsions was reported using quartiles (25th, 50th, 75th) with their 95% confidence intervals for each treatment group. Kaplan-Meier survival curves were constructed for each treatment group; the median time to cessation of convulsions was estimated using the Kaplan-Meier estimates.

These results are summarized in Table 11-9 and Figure 11-3 below and in Table 14.2.2.2.C and Figure 14.4.1.3.

The diazepam group reported a higher rate of return to baseline functioning/Mental status than the lorazepam group (55.0% vs. 35.4%). The median time to event for the diazepam group was 120 and 239 minutes for the lorazepam group. Using the Cox regression model stratified by age group, there is significant difference between treatment arms (p-value<0.0001 after adjusting for site, hazard ratio: 2.18 [95% CI: 1.48–3.20]). Figure 11-3 shows a separation numerically favoring the diazepam arm. The sensitivity analysis shows consistent result (Table 14.2.2.2S.C and Figure 14.4.1.3S). Significant site effect is detected (p-value<0.0001).

Table 11-9 Analysis of Time to Return to Baseline Functioning/Mental status (MITT Population)

| Diazepam (N=131) | Lorazepam (N=127)
Number of Participants
Number of Censored Participants | 59 (45.0%) | 82 (64.6%)
Num of Participants Returning to Baseline Functioning/Mental Status | 72 (55.0%) | 45 (35.4%)
Time to return to baseline function (mins)
25% Percentile (95% CI) | 66.0 (60.0, 108.0) | 121.0 (63.0, 173.0)
Median (95% CI) | 120.0 (119.0, 125.0) | 239.0 (180.0, .^*^)
75% Percentile (95% CI) | 183.0 (163.0, 240.0) | *
Range | 0, 240 | 0, 240
Cox Proportional Hazards Regression
Hazard Ratio (Relative to lorazepam) | 2.18
(95% CI) | (1.48, 3.20)
p value (Log Rank) | <.0001

* un-estimable

Figure 11-3 Time to Return to Baseline Functioning/Mental Status by Treatment Group

##### 11.4.1.2.6 Incidence of status epilepticus refractory to benzodiazepines and incidence of status epilepticus that is refractory to benzodiazepines but is terminated by second-line medication (fos-phenytoin, phenytoin, phenobarbital)

The number and proportion of participants in whom status epilepticus refractory to benzodiazepines was terminated by second-line medication is summarized for each second-line medication for the combined treatment arms. The efficacy endpoint was the proportion of participants who had resolution of their convulsions within 10 minutes of the initial administration of the second-line medication without seizure recurrence for 30 minutes. Cochran-Mantel-Haenszel (CMH) test was used in this analysis. This secondary study endpoint was restricted to the subset of all randomized participants that were found to have status epilepticus that is refractory to benzodiazepines (defined in the preceding endpoint).

These results are summarized in Table 11-10 below and in Tables 14.2.2.3 and 14.2.2.3S.

The number and proportion of participants with status epilepticus refractory to benzodiazepines were similar between the two treatment groups: 20 (15.3%) in the diazepam group and 19 (15.0%) in the lorazepam group (p-value = 0.95). The sensitivity analysis had a p-value of 0.86.

Participants treated with diazepam had a reported higher rate of refractory status epilepticus terminated by second-line medication than the lorazepam group [6 (30%) vs. 2 (11%), respectively], However, this difference is not significant with a p-value of 0.14. No significant difference between treatment groups was detected from the sensitivity analysis.

Table 11-10 Analysis of Incidence of status epilepticus refractory to benzodiazepines

| Diazepam (N=131) | Lorazepam (N=127) | Total (N=258) | P value
Status Epilepticus refractory to benzodiazepines | 20 (15.3%) | 19 (15.0%) | 39 (15.1%) | 0.9453
Refractory Status Epilepticus terminated by second-line medication | 6 (30.0%) | 2 (10.5%) | 8 (20.5%) | 0.1373

##### 11.4.1.2.7 Identification of risk factors for status epilepticus refractory to benzodiazepines and risk factors for refractory status epilepticus not terminated by second-line medication

A logistic regression model was developed to identify risk factors related to unresponsiveness to benzodiazepines. The analyses to identify risk factors for refractory status epilepticus not terminated by second-line medication were not performed due to small sample size. Independent factors in the model included treatment assignment and age stratum. Other risk factors included gender, race, type of primary etiology and duration of status epilepticus. Some risk factors mentioned in the SAP were not included due to the sample size limitation.

Results are summarized in Table 11-11 below and in Table 14.2.2.4.A.

None of the risk factors significantly impacted the response to benzodiazepines for status epilepticus. The results of the sensitivity analyses were similar (Table 14.2.2.4.A.S).

Table 11-11 Risk factors for Status Epilepticus Refractory to Benzodiazepine

Risk Factor | P value
Age | 0.21
Gender | 0.57
Race | 0.79
Primary Etiology | 0.30
Duration of SE | 0.26
Treatment (Ref Trt= lorazepam) | 0.59

##### 11.4.1.2.8 Analysis of dose-response relationship for Fos-phenytoin

Due to sample size limitation, the analyses were restricted to participants receiving Fosphenytoin as second line medication. Twenty-seven participants were treated with Fos-Phenytoin, seven of whom reported cessation of seizure following receiving the medication.

Results are summarized in Table 11-12 below and in Table 14.2.2.5.

Table 11-12 Analysis of Dose-response Relationship for Fos-phenytoin

Second-line Medication Response Variable | Diazepam (N=131) | Lorazepam (N=127)
FOS Phenytoin
Total Dose
N | 15 | 12
Mean (SD) | 19.5 (3.9) | 20.8 (4.9)
Median | 20 | 20.0
Min – Max | 11.5, 27.5 | 15.0, 30.0
Cessation of seizures | 6/15 (40.0%) | 1/12 (8.3%)

##### 11.4.1.2.9 Analysis of associations between second-line medications and tachycardia,bradycardia, high blood pressure, low blood pressure, and respiratory depression

The proportion of participants developing each of the AEs/SAEs of interest was evaluated for each second-line medication. The analysis population was limited to the participants who used FOS Phenytoin, Phenytoin or Phenobarbital as the second-line of medication and reported the AEs/SAEs of interest after the use of above medications.

Results are summarized in Table 11-13 below and Table 14.2.2.6.

There were 93 participants who used Fos-Phenytoin, 29 used Phenytoin, 5 used both Fos-Phenytoin and Phenytoin and 31 participants used Phenobarbital as the second-line medication. Participants who used Phenytoin most frequently reported Hypercarbia (14%), participants who used Fos-Phenytoin most frequently reported Hypotension and participants who used both Phenytoin and Fos-Phenytoin most frequently reported Hypoxemia (20%) and Respiratory Depression (40%).

Table 11-13 Analysis of Associations between Second-line Medications and Tachycardia, Bradycardia, High Blood Pressure, Low Blood Pressure and Respiratory Depression

Second-line Medication Adverse event | Fos-Phenytoin | Phenytoin | Use Both Phenytoin and Fos-Phenytoin | Phenobarbital
Hypercarbia | 9/93(9.68%) | 4/29(13.8%) | 0/5(0.00%) | 1/31(3.23%)
Bradycardia | 0/93(0.00%) | 0/29(0.00%) | 0/5(0.00%) | 0/31(0.00%)
Hypoxemia | 6/93(6.45%) | 3/29(10.3%) | 1/5(20.0%) | 3/31(9.68%)
Hypotension | 13/93(14.0%) | 4/29(13.8%) | 0/5(0.00%) | 4/31(12.9%)
Respiratory Depression | 27/93(29.0%) | 4/29(13.8%) | 2/5(40.0%) | 1/31(3.23%)

##### 11.4.1.2.10 Analysis of incidence of status epilepticus that required coma induction and the medications employed for coma induction

Results of the descriptive analysis are presented in Table 11-14 below and in Table 14.2.2.7. Only two participants receiving lorazepam required coma induction and were treated with midazolam and pentobarbital. None of the participants in the diazepam group required coma induction.

Table 11-14 Medications employed for Coma Induction

Anit-Epileptic Medication | Diazepam (N=131) | Lorazepam (N=127) | Total (N=258)
MIDAZOLAM | 0 (0.0%) | 1 (0.8%) | 1 (0.4%)
PENTOBARBITAL | 0 (0.0%) | 1 (0.8%) | 1 (0.4%)

### 11.4.2 Statistical and Analytical Issues

#### 11.4.2.1 Adjustments for Covariate

Exploratory analyses were performed to assess the potential impact of various prognostic factors on efficacy for primary efficacy endpoint. Exploratory analyses included age, gender, febrile seizure etiology, and use of Antiepileptic drugs (AEDs) as potential risk factors. A Logistic regression model was fit with these factors as covariates, and the effect of treatment was assessed after adjusting for other significant risk factors. The use of AEDs was significant in the model. The use of AEDs was defined as the use of anti-epileptic medications other than study medication after 1st dose of study medication and before return to baseline status. After adjusting for use of AEDs, the treatment effect was not significant with a p-value of 0.66.

#### 11.4.2.2 Handling of Dropouts or Missing Data

While it was anticipated that the short-term nature of this study would preclude missing values, a final review of the primary efficacy endpoint and primary safety endpoint were completed. There is no missing data for primary endpoint.

#### 11.4.2.3 Interim Analysis and Data Monitoring

##### 11.4.2.3.1 Background of Discussion in Interim Analysis and Sample Size Increasing

In March 2010, a pre-specified interim analysis (Appendix 16.4.1.1) was conducted to examine the conditional power for the primary efficacy outcome based on the observed interim data. The objective of the interim analysis was to either increase the sample size up to a pre-specified maximum sample size or to continue the study as planned. This interim analysis was revised in June 2010 (Appendix 16.4.1.2) after excluding data from a site (▬) that was found to have randomization errors resulting in total evaluable sample size of 139 participants. The conditional power under current trend using data from the MITT cohort for the planned sample size of 240 MITT participants was 71% and 87% for maximum sample size of 360.

Under the protocol specified interim analysis plan, the sample size may be increased up to the maximum sample size considered feasible for the study to increase conditional power to 90% or higher. Since the conditional power for maximum sample size was less than 90%, the protocol defined analysis plan stated that a joint decision should be made by the BPCA Data Monitoring Committee (DMC), and the NICHD based on aggregated information such as cumulative safety data and actual conditional power with the maximum sample size considered feasible for the study.

Following further discussions between the DMC and NICHD, a decision was made to increase the sample size of MITT population to 262 participants. This sample size was chosen to remain consistent with the study objective to detect a clinically meaningful difference of 17% between the two treatment groups. A sample size of 262 MITT participants would provide 80% power to detect a 17% difference between treatment arms if the success rate in the Diazepam arm was 50% instead of 60% as assumed in the original sample size calculations. Further details about discussions related to change in sample size are provided in Appendix 16.4.1.3.

##### 11.4.2.3.2 Completed Interim Analyses (Appendix 16.4.1)

March 2010 (Appendix 16.4.1.1): Interim analysis to potentially modify sample size as per protocol –

June 2011 (Appendix 16.4.1.4): Interim safety analysis.

January 2012 (Appendix 16.4.1.5): Interim safety analysis.

#### 11.4.2.4 Multi-site Study Site Effects

Some secondary endpoints were adjusted for possible site effect in Cox proportional hazards regression model. There were 11 sites that enrolled 310 participants in this trial. Small sites (sites that have less than 4 participants per treatment arm: ▬ (n=9), ▬ (n=3), ▬ (n=8)) were combined to form a single analysis site in order to obviate non-estimable situations (i.e., at least 2 observations are needed to estimate variance) in the evaluation of site in the analysis.

#### 11.4.2.5 Multiple Comparison/Multiplicity

No adjustment was made for multiplicity.

#### 11.4.2.6 Use of an “Efficacy Subset” of Participants

Refer to efficacy analysis results in section 11.1.

#### 11.4.2.7 Examination of Sub-Groups

Refer to efficacy analysis results in section 11.4.1.1.1 and 11.4.1.1.2.

### 11.4.3 Tabulation of Individual Response Data

A by-participant listing of efficacy data is provided in Listing 16.2.9 and 16.2.10.

### 11.4.4 Drug Dose, Drug Concentration, and Relationship to Response

A population pharmacokinetic (PK) analysis was performed on the blood samples collected in the lorazepam arm of a comparative study in pediatric participants with acute status epilepticus aged 3 months to 18 years. A detailed report of the analysis and results are presented in Appendix 16.4.2. Only participants randomized to receive lorazepam were included in this analysis.

Lorazepam was administered by slow IV push at a dosage as a 0.1 mg/kg (up to 4mg). Pre-dose and up to 3 post-dose PK samples were collected over 24 hours or until discharge. Population (mixed effects) analysis was performed. A total of 174 lorazepam concentrations were included in the raw PK data set. Nine samples were excluded for pre-dose collection times, 5 were excluded due to missing critical dosing or time information and 4 were excluded as extreme outliers. This resulted in 156 samples from 83 subjects in the usable data set.

The population PK analysis was performed using allometrically scaled parameters and a one-compartment model. The small number of subjects and concentrations limited the search for predictors of lorazepam PK parameters. AST and HCT as covariates on CL provided modest improvement in the model at the p < 0.005 level. No other covariates improved the model fit beyond the allometric scaling used in the base model.

The typical population PK parameters estimates were: CL (L/hr/kg0.75) 0.0955, and V (L/kg) 1.16. Overall lorazepam PK post-hoc parameters from the population analysis were: CL (L/hr/kg) 0.053±0.025 (mean ± s.d.), V (L/kg) 1.22± 0.36 and half-life (hr) 17.80±5.53. The average lorazepam-glucuronide/lorazepam ratio was 1.69 ± 1.39. Weight adjusted CL was higher in younger infants and children compared to older children. Concomitant VPA or enzyme inducing anticonvulsant drugs (EIAED) did not appear to affect lorazepam CL. These PK results, along with safety and tolerability data, indicate that a dose of 0.1 mg/kg (4 mg max) achieves and maintains lorazepam concentrations in the range associated with anticonvulsant effects for 12 hours and would not exceed levels associated with heavy sedation.

### 11.4.5 Drug-Drug and Drug-Disease Interactions

Drug-drug and drug-disease interactions were not analyzed in this study.

### 11.4.6 By-Participant Displays

Not applicable.

### 11.4.7 Efficacy Conclusions

The results do not support the hypothesis that lorazepam is superior to diazepam in efficacy. There were no clinically significant or statistically significant differences between the two medications in efficacy. The point estimates for primary and secondary endpoints were nearly identical between the two groups with the exception of sedation, which was more likely with lorazepam. Time to return to baseline function was longer in the lorazepam group.