# 10 STUDY PARTICIPANTS

## 10.1 Disposition of Participants

Participant accounting is summarized in Table 10-1 and Table 14.1.1.1. Figure 10-1 presents the flow of enrollment and datasets analyzed (Section 11.1) in this study. Three hundred and three (303) unique participants were randomized in this study and all randomized participants who received at least one dose of study medication were included in the safety population. Seven participants were randomized in duplicate. Thus, there were 310 total randomizations; these duplicate randomizations were included in the safety analysis. Of the 310 randomizations, 162 (52%) were randomized to diazepam and 148 (48%) were randomized to lorazepam. Two hundred and fifty-eight participants (83%) were in the MITT population (randomized participants with confirmed SE and excluding randomization errors at ▬). Participants were only included once in the MITT population. If a participant was randomized more than once, the first randomization that met the MITT criteria was included. Among the 7 duplicate enrollments, the MITT criteria were met in both enrollments for 2 participants. The MITT criteria were met in the first enrollment only for 1 participant; it was met in second enrollment only for 2 participants and in neither enrollments for 2 participants. Eighty one percent (81%) of diazepam and 86% of lorazepam randomizations were eligible for MITT population.

A total of 259 (84%) out of the 310 randomizations completed the study; 133 (82%) in diazepam and 126 (85%) in lorazepam, respectively. Fifty-one (16%) of the 310 randomizations terminated the study early. The most common reasons for early termination included parent/guardian refusal for continued study participation (7% in each treatment group) and protocol non-compliance (7% in diazepam and 5% in lorazepam).

Participants were enrolled at 11 sites in this study. Participants enrolled by site are presented Table 10-2 and 14.1.1.2. The largest number of MITT participants were enrolled at ▬ (N=70) followed by the ▬ (N=45), ▬ (N=40) and ▬ (N=36).

Figure 10-1 Enrollment Flow Chart

Table 10-1 Participant Disposition (All Randomizations)

| 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Number of Randomizations
Randomized | 77 (100.0%) | 71 (100.0%) | 68 (100.0%) | 63 (100.0%) | 17 (100.0%) | 14 (100.0%) | 162 (100.0%) | 148 (100.0%)
Cohort 1 (Preconsented) | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 0 | 1 (5.9%) | 0 | 4 (2.5%) | 2 (1.4%)
Cohort 2 (EFIC) | 75 (97.4%) | 69 (97.2%) | 67 (98.5%) | 63 (100.0%) | 16 (94.1%) | 14 (100.0%) | 158 (97.5%) | 146 (98.6%)
MITT Population | 68 (88.3%) | 60 (84.5%) | 51 (75.0%) | 57 (90.5%) | 12 (70.6%) | 10 (71.4%) | 131 (80.9%) | 127 (85.8%)
Duplicate Enrollment | 0 | 2 | 3 | 1 | 1 | 0 | 4 | 3
Status of Randomized Participants
0–4 hr Assessment Completed | 76 (98.7%) | 69 (97.2%) | 67 (98.5%) | 58 (92.1%) | 16 (94.1%) | 13 (92.9%) | 159 (98.1%) | 140 (94.6%)
24 hr/Discharge Blood Tests Collected & Analyzed | 45 (58.4%) | 45 (63.4%) | 47 (69.1%) | 43 (68.3%) | 11 (64.7%) | 9 (64.3%) | 103 (63.6%) | 97 (65.5%)
Completed Study | 65 (84.4%) | 62 (87.3%) | 56 (82.4%) | 53 (84.1%) | 12 (70.6%) | 11 (78.6%) | 133 (82.1%) | 126 (85.1%)
Early Termination | 12 (15.6%) | 9 (12.7%) | 12 (17.6%) | 10 (15.9%) | 5 (29.4%) | 3 (21.4%) | 29 (17.9%) | 22 (14.9%)
Reasons for Early Termination
Parent/guardian withdrew consent | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Parent/guardian refused continued study participation (consent not signed) | 7 (9.1%) | 4 (5.6%) | 3 (4.4%) | 6 (9.5%) | 1 (5.9%) | 0 | 11 (6.8%) | 10 (6.8%)
Investigator judgment | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 0
Protocol non-compliance (after randomization) | 4 (5.2%) | 3 (4.2%) | 5 (7.4%) | 2 (3.2%) | 3 (17.6%) | 3 (21.4%) | 12 (7.4%) | 8 (5.4%)
Participant death | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Other | 0 | 2 (2.8%) | 3 (4.4%) | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 3 (2.0%)

Table 10-2 Participant Enrollment by Site (ITT Population)

| 3 mo - <3 yrs | | 3 yrs - <13 yrs | | >13 yrs | | Total
Site | Diazepam (N=72) | Lorazepam (N=62) | Diazepam (N=55) | Lorazepam (N=60) | Diazepam (N=13) | Lorazepam (N=11) | Diazepam (N=140) | Lorazepam (N=133)
▬ | 2 (25.0%) | 3 (37.5%) | 1 (12.5%) | 2 (25.0%) | 0 | 0 | 3 (37.5%) | 5 (62.5%)
▬ | 12 (26.7%) | 12 (26.7%) | 8 (17.8%) | 8 (17.8%) | 4 (8.9%) | 1 (2.2%) | 24 (53.3%) | 21 (46.7%)
▬ | 10 (25.0%) | 9 (22.5%) | 9 (22.5%) | 10 (25.0%) | 1 (2.5%) | 1 (2.5%) | 20 (50.0%) | 20 (50.0%)
▬ | 6 (28.6%) | 4 (19.0%) | 5 (23.8%) | 3 (14.3%) | 1 (4.8%) | 2 (9.5%) | 12 (57.1%) | 9 (42.9%)
▬ | 2 (66.7%) | 0 | 1 (33.3%) | 0 | 0 | 0 | 3 (100.0%) | 0
▬ | 8 (40.0%) | 6 (30.0%) | 2 (10.0%) | 2 (10.0%) | 1 (5.0%) | 1 (5.0%) | 11 (55.0%) | 9 (45.0%)
▬ | 1 (14.3%) | 0 | 3 (42.9%) | 2 (28.6%) | 0 | 1 (14.3%) | 4 (57.1%) | 3 (42.9%)
▬ | 9 (25.0%) | 7 (19.4%) | 7 (19.4%) | 8 (22.2%) | 3 (8.3%) | 2 (5.6%) | 19 (52.8%) | 17 (47.2%)
▬ | 3 (30.0%) | 2 (20.0%) | 1 (10.0%) | 3 (30.0%) | 0 | 1 (10.0%) | 4 (40.0%) | 6 (60.0%)
▬ | 16 (22.9%) | 16 (22.9%) | 14 (20.0%) | 20 (28.6%) | 2 (2.9%) | 2 (2.9%) | 32 (45.7%) | 38 (54.3%)
▬ | 3 (23.1%) | 3 (23.1%) | 4 (30.8%) | 2 (15.4%) | 1 (7.7%) | 0 | 8 (61.5%) | 5 (38.5%)

## 10.2 Protocol Deviations and Waivers

### 10.2.1 Summary of protocol deviations

There were a total of 1770 protocol deviations reported in 270 (99%) ‘Intent to Treat’ (ITT) population, also called the sensitivity population, in this study. The ITT population included all MITT population and qualified ▬ randomization errors. The protocol deviations are summarized in Table 14.1.2.1 and a complete list is provided in Appendix 16.2.5. Twenty-four participants had an informed consent/assent related deviation (27 deviations), 31 participants had an eligibility/enrollment related deviation (33 deviations), 59 participants had a study medication administration related deviation (81 deviations), 43 participants had deviations related to randomization (45 deviations: 31 due to the incorrect block assignment, 13 due to the incorrect age group and 1 due to the pre-dose lab out of window), 8 participants had unblinding related deviations (8 deviations: 7 due to the unblinded study coordinator, and 1 due to the temporary unblinding study Pis for study related issues), 264 participants had protocol procedure/assessment related deviations (1531 deviations), 4 participants had deviations related to concomitant treatment (4 deviations), 9 participants had deviations related to unreported serious adverse events (SAE) (9 deviations) and 21 participants had other deviations (32 deviations).

### 10.2.2 Major protocol deviations

The major protocol deviations were defined by study PI prior to unblinding of data and used to define per protocol population (MITT population without a major protocol deviation). The major protocol deviations are listed in Listing 16.2.3.2.

Major protocol deviations include the following:

1) Administration of a benzodiazepine within two hours prior to study medication administration;
2) Administration of the second dose of study medication ≥9 minutes after the initial study medication administration;
3) Administration of fosphenytoin, phenytoin or phenobarbital 10 minutes or sooner if the participant was still in status;
4) Administration of an open label benzodiazepine within 4–6 minutes of study medication administration if the participant was still in status;
5) Infiltration of the IV (leading to subcutaneous, rather than IV, administration of medication) during or immediately after study medication administration;
6) Administration of study medication 30% above or below the protocol-defined dose based on actual weight (use estimated weight if actual weight is not available); or
7) Administration of incorrect randomized study medication.

Due to the complexity and short time period of the study, some of the major protocol deviations were reviewed and created on a case-by-case basis after study completion by the Study PI and BPCA DCC prior to study unblinding. Therefore some of the major protocol deviations may not be presented in the protocol deviation list. There were 63 participants with major protocol deviations. Four participants were administered benzodiazepine within two hours of study medication administration. Twenty one participants received the second dose of study medication outside of the 9 minutes time window, 3 participants were administered fosphenytoin, phenytoin or phenobarbital within 10 minutes following initial study medication, 3 participants were administered open label benzodiazepine within 4–6 minutes of study medication administration. Three participants had infiltration of the IV immediately after study medication administration. Twenty seven participants received a dose of study medication 30% above or below the protocol defined dose based on actual weight and 2 participants had received the incorrect randomized study medication.