# 9 INVESTIGATIONAL PLAN

## 9.1 Overall Design and Plan Description

This study was a double-blinded, randomized, controlled trial comparing the efficacy and short-term safety of lorazepam versus diazepam in pediatric status epilepticus. For participants in whom SE was not terminated by benzodiazepines, data was collected prospectively regarding subsequent medications, dosing, and effectiveness.

Participants were grouped according to the following age groups:

- 3 months to less than 3 years;
- 3 years to less than 13 years; or
- 13 years to less than 18 years.

Fourteen hospitals from the United States and Canada participated in this study.

A Pediatric Off-Patent Drug Study (PODS) site was established at Children’s National Medical Center (Washington, DC) and had completed Study 1 (pharmacokinetics). The PODS site was responsible for the following:

- Providing technical assistance to participating sites in collaboration with the BPCA Data Coordinating Center (DCC);
- Maintaining regular communications with the Sponsor, BPCA DCC and participating sites;
- Providing regular study updates and progress reports to the Sponsor; and
- Collaborating with the BPCA DCC based at The EMMES Corporation in Rockville, MD for protocol monitoring, project management and data management activities.

## 9.2 Discussion of Study Design and Choice of Control Groups

This study was a double-blinded, randomized, controlled trial comparing the efficacy and short-term safety of lorazepam versus diazepam in pediatric status epilepticus. Because status epilepticus is a life-threatening emergency and there is FDA-approved therapy—diazepam--it was unethical to use a placebo. Therefore, the study compared lorazepam to diazepam rather than lorazepam to placebo. The study used a superiority design to test the hypothesis that lorazepam was superior to diazepam.

## 9.3 Selection of Study population and Informed Consent

### 9.3.1 Inability to Obtain Informed Consent at the Time of Intervention

For this study there were 2 cohorts of participants based on the process of informed consent:

Cohort 1 (preconsented) included potential participants whose parents or legally authorized representative (LAR) provided informed consent prior to a potential study participant presented to the ED in SE. Informed assent was obtained for older participants as per local IRB rules. Participants were approached in hospital clinics and Neurology practices in person, via telephone or through the mail. A trained research staff member conducted the informed consent process. The consent document (Appendix 16.1.3) informed parents that if their child comes to the ED and qualifies for the study based on study inclusion/exclusion criteria, they will be enrolled. Study staff also contacted families approximately every 90 days to confirm their continued willingness to participate. Every 12 months, or whenever the IRB required (e.g., a change in consent form version), families were contacted again to sign a new IRB approved consent form. It was expected that there would be families that could not be contacted during the 90 days or at the 12 month time point. The following attempts to contact families were documented before withdrawing their consent for continued participation:

- 5 telephone contact attempts
- 2 postal mail or email attempts
- 150 elapsed days from last contact with the parent/guardian

Participants who could not be contacted to confirm consent were enrolled in Cohort 2 (Exception from Informed Consent [EFIC]) as detailed below.

Cohort 2 (EFIC) included participants who appeared in the ED with SE and qualified for the study, but had not given prior consent. These participants were enrolled under the EFIC regulations. At the time that a child presented to the ED, if a parent/guardian was present, an ED clinician determined whether it was appropriate to approach them regarding the study. This determination was made based on the parent/guardian’s emotional state upon arrival to the ED. If an ED clinician determined that it was appropriate to approach the parent/guardian, the ED clinician informed the parent/guardian that a research study is ongoing in the ED and their child may automatically be enrolled in the study. This allowed the parent/guardian to object to participation or ask additional questions. The purpose of this contact with the parent/guardian in the ED was to allow those who object to research generally to refuse participation in the study. This contact was NOT meant to start the informed consent process and did not delay medical care.

The child was enrolled (dosed) with study medication under an EFIC. Once the child was stabilized, a research staff member approached the parent or LAR to obtain informed consent to continue the child’s participation in the study. If a parent or LAR refused continued participation, no further study procedures were performed. Safety data were collected in accordance with federal regulations

The randomized controlled trial represents the second phase of the lorazepam study (Study 2). The first phase was a pharmacokinetic study of lorazepam (Study 1). Study 1 was also conducted in two cohorts of participants. The first cohort consisted of participants who presented to the Emergency Department (ED) in SE and were given lorazepam as part of routine clinical care. The second cohort consisted of participants with previously diagnosed seizure disorders who were voluntarily admitted to the hospital and who received a dose of lorazepam while not actively seizing. Within the first cohort (those enrolled in the ED when experiencing SE), there were two subgroups. Cohort 1A participants were consented prior to their arrival in the ED through neurology clinics and other hospital based units. Approximately 1230 participants were screened for the study, of which only 105 participants were “pre-consented” for the study. Of these, only 10 participants returned to the ED, and were identified as study participants and enrolled into the protocol over approximately 18 months across 10 sites.

The challenge with cohort 1A participants was that it was difficult to obtain informed consent prior to enrollment as their actual participation was dependent on a potential visit to the ED and a chance that they would receive lorazepam and qualify under the study inclusion/exclusion criteria. In interviews with patients and LARs, we found that many could not provide informed consent for an abstract potential future event. Furthermore, these participants had to be rapidly identified in the ED which presented many logistical challenges. Several early blood samples and study measurements were missed for participants in Cohort 1A due to these logistical challenges.

In comparison, Cohort 1B participants were those who were identified in the ED when they presented with status epilepticus and consent was obtained in the ED after qualifying for the study. There were approximately 1767 Cohort 1B participants screened by this mechanism and 43 were enrolled. For many participants, it took over an hour after their arrival to the ED to obtain informed consent, resulting in several missed data points. Many parents/guardians were too distressed to be approached by an investigator for consent. Consequently, enrollment had to be increased to provide adequate pharmacokinetic estimates and Study 1 was extended 3 times for an overall delay of more than 12 months and an increase in cost of $518,418.

The results of Study 1 were submitted to FDA on 26 February, 2009, in the form of a Clinical Study Report (CSR). The sponsor was notified that Study 1 would be treated as a rolling submission and would be reviewed in conjunction with Study 2.

This study presented many more challenges than Study 1 in terms of obtaining informed consent prior to study enrollment. The primary difference in study design was the need to randomize the participant to study medication (Lorazepam) or standard care (Diazepam) within the narrow therapeutic window of 5 minutes, In Study 1, participants were receiving lorazepam as part of routine care and study data included only vital signs and blood samples. In Study 2, the addition of randomization created a process that requires more complex informed consent.

### 9.3.2 Inclusion Criteria

Participants were eligible for inclusion in the study if all of the following conditions applied:

1. Age 3 months to less than 18 years; and
2. Generalized tonic-clonic status epilepticus, defined as:
  a. Three or more generalized tonic-clonic seizures within the last hour of enrollment and experiencing a convulsion at that time (i.e., may have been the third convulsion within one hour); or
  b. Two or more generalized tonic-clonic seizures in succession with no recovery of consciousness between seizures and experiencing a convulsion at that time (i.e., t may have been the second convulsion without recovery of consciousness after the first convulsion); or
  c. A seizure that lasted at least 5 minutes that was either generalized tonic clonic in its entirety or started focal and then generalized. The seizure must have been associated with loss of consciousness.

### 9.3.3 Exclusion Criteria

Participants were not eligible for this study if they met any of the following criteria prior to study medication administration:

1. Known Pregnancy;
2. Shock prior to study medication (sustained hypotension requiring inotropic therapy);
3. Significant dysrhythmia prior to study medication (other than sinus tachycardia);
4. Need for emergent surgical intervention and general anesthesia for a condition present prior to study medication;
5. Known sensitivity to benzodiazepines or known contraindication to benzodiazepine use;
6. Use of a benzodiazepine within 1 week of presentation; or
7. Prior participation in this study.

### 9.3.4 Removal of Participants from Therapy or Assessment

Certain exclusion criteria were not known at the time of study medication administration due to the need for emergent treatment. Thus participants were terminated from the study (early terminators) if the investigators discovered any of the following conditions after administration of study medication:

1. Confirmed Pregnancy;
2. Use of a benzodiazepine within 1 week of presentation;
3. Parent/guardian refusal to give informed consent by the methods described; or
4. Participant’s refusal to assent (for participants ≥ 7 yrs old and mentally competent to understand study procedures) by the methods described, or as required by the local IRB.

Efficacy and safety data from participants who were terminated early from the study due to pregnancy or use of a benzodiazepine were retained. Sensitivity analyses were conducted for both efficacy and safety to determine whether exclusion of early terminated participants affects the results.

### 9.3.5 Enrollment Methods

Figure 9-1 and Figure 9-2 present the enrollment processes for cohort 1 and 2 respectively (see next page):

Figure 9-1 Identification and Participant Enrollment – Cohort 1 (Preconsented Participants)

Cohort 1 (preconsented patients) Enrollment Methods (See Figure 9-1):

a) A nurse or licensed independent practitioner (LIP) (herein referred to as participating clinician) at each site identified participants meeting eligibility criteria. An LIP herein refers to any of the following:
  a. staff or attending physician,
  b. resident or fellow who had a medical license, or
  c. nurse practitioner or physician assistant whowas credentialed to practice independently
b) Upon confirming eligibility using a standardized checklist, the participating clinician confirmed consent if a parent/guardian was available. Since the participant had been consented prior to ED arrival, if a parent/guardian was not available, then enrollment continued.
c) Pre-dose blood samples were obtained as soon as an IV was placed.
d) The medication nurse retrieved study medication using a pre-determined paper randomization scheme (see randomization procedures below).
e) A nurse or participating clinician administered the study medication in accordance with hospital policy.
f) Study staff at each site was paged to complete case report form (CRF) information.
g) Blood draws (see schedule below) and relevant CRF information were completed by the participating clinician, site coordinator, and ED staff. At some sites, other personnel, such as research assistants, medical assistants or specialized research nurses (study staff) were sometimes paged to complete the CRF.
h) A second dose of the study medication was administered after five minutes of ongoing convulsions, if applicable.
i) Study staff followed the participant through the inpatient process to ensure compliance with the study protocol for 24 hours or discharge, whichever came first.
j) For participants who signed the informed consent, study staff called the family 30–40 days following enrollment to conduct a follow up interview to determine participant wellbeing and to ascertain the presence or absence of late adverse events.
k) If the family could not be reached for the telephone follow-up, a survey was postal mailed to the family for follow-up information.
l) The family was considered a loss to follow-up if the study staff had made at least 5 telephone attempts, and at least 2 postal or email attempts and 150 days had elapsed since last contact.

Figure 9-2 Identification and Participant Enrollment Under Exception from Informed Consent -Cohort 2 (EFIC) Enrollment

Cohort 2 (EFIC) Enrollment Methods (See Figure 9-2):

1. A nurse or licensed independent practitioner (LIP) (herein referred to as participating clinician at each site identified participants meeting eligibility criteria. An LIP herein refers to any of the following:
  a. staff or attending physician,
  b. residents or fellow who had a medical license, and
  c. nurse practitioner or physician assistants who was credentialed to practice independently
2. Upon confirming eligibility using a standardized checklist, the participating clinician proceeded with enrollment as described in the informed consent procedures.
3. Pre-dose blood samples were obtained as soon as an IV was placed.
4. The medication nurse retrieved study medication using a pre-determined paper randomization scheme (see randomization procedures below).
5. A nurse or participating clinician administered the study medication in accordance with hospital policy.
6. Study staff at each site was paged to meet with the participant’s family to obtain informed consent as described in the section below.
7. Blood draws (see schedule below) and relevant case report form (CRF) information was completed by the participating clinician, site coordinator, and ED staff. At some sites, other personnel, such as research assistants, medical assistants or specialized research nurses (study staff) were sometimes paged to complete the CRF.
8. A second dose of the study medication was administered after five minutes of ongoing convulsion, if applicable.
9. Study staff followed the participant through the inpatient process to ensure compliance with the study protocol for 24 hours or discharge, whichever came first.
10. For participants who signed the informed consent, study staff called the family 30–40 days following enrollment to conduct a follow up interview to determine participant wellbeing and to ascertain the presence or absence of late adverse events.
11. If the family could be reached for the telephone follow-up, a survey was postal mailed to the family for follow-up information.
12. The family was considered a loss to follow-up if the study staff had made at least 5 telephone attempts and at least 2 postal or email attempts and 150 days had elapsed since last contact.

## 9.4 Treatments

### 9.4.1 Treatments Administered

The following dose of study medication was used for the first dose. A second dose, if required for ongoing convulsions, was half the first dose.

Lorazepam: 0.1 mg/kg slow IVP to maximum dose 4 mg

Diazepam: 0.2 mg/kg slow IVP to maximum dose 8 mg.

The treatment schedule is described in Section 9.4.5

### 9.4.2 Identity of Investigational Products

#### 9.4.2.1 Lorazepam

Lorazepam was supplied as lorazepam (Lorazepam) injection, solution and is manufactured byBaxter, Inc. lorazepam, a benzodiazepine with antianxiety and sedative and anticonvulsant effects, is intended for intramuscular or intravenous route of administration. It has the chemical formula 7-Chloro-5-(2-chlorophenyl)-1,3-dihydro-3-hydroxy-2H-1,4-benzodiazepin-2-one. The molecular weight is 321.16, and the C.A.S. No. is [846-49-1]. The molecular formula is C15H10Cl2N202. The structural formula is:

Lorazepam is a nearly white powder almost insoluble in water. Each mL of sterile injection contains either 2 or 4 mg of lorazepam, 0.18 mL polyethylene glycol 400 in propylene glycol with 2% benzyl alcohol as preservative

#### 9.4.2.2 Diazepam

Diazepam was supplied as diazepam (Diazepam) injection and is manufactured by Baxter Healthcare Corporation and Hospira, Inc. Each mL of diazepam Injection, USP, an anxiolytic, contains diazepam 5 mg, propylene glycol 0.4 mL, alcohol 0.1 mL, benzyl alcohol 0.015 mL and sodium benzoate/benzoic acid, a total of 50 mg, in Water for Injection. pH 6.2–6.9. Sealed under nitrogen. Sometimes solution may appear yellow.

Diazepam is a benzodiazepine derivative, identified chemically as 7-Chloro-1,3-dihydro-1-methyl-5-phenyl-2H-1,4-benzodiazepin-2-one. The molecular weight is 284.75 and the molecular formula is C16H13ClN2O. It is a colorless crystalline compound, insoluble in water and has the following structural formula:

### 9.4.3 Method of Assigning Participants to Treatment Groups

A stratified permuted block design was used to randomize participants in a 1:1 ratio (Lorazepam: diazepam). Each of the participating sites’ pharmacy received a randomization schedule, specific to their site, as defined below.

This randomization schedule identified for the pharmacist, the randomization numbers for each block and the study medication assigned to each randomization number. This schedule was kept in the pharmacy under double lock and was not accessible to anyone other than the pharmacist and unblinded BPCA DCC monitor. Based on the randomization schedule, the pharmacist assigned a block to each of the three age groups listed below. The pharmacist placed kits (which contained the vials of study medication) of study medication, from each block, in the PYXIS for administration to participants as they presented to the ED. Once a block was filled for an age group, the next block available from the randomization schedule was assigned to that age group for future participant enrollment.

- 3 months to less than 3 years
- 3 years to less than 13 years
- 13 years to less than 18 years

The BPCA DCC Central Pharmacies, (Fisher Bioservices until September 2009 and Eminent Services from September 2009 – March 2012), shipped medication kits along with dosing charts to the study sites within the United States. The Canadian sites used a local supply of study medication and the BPCA DCC provided the dosing charts. The dosing chart identified the study medication preparation instructions and the volume of study medication to be administered per kilogram of a child’s weight to the ED nurse or pharmacist. Each kit was separately packaged with the dosing chart by the local pharmacist and was placed in the PYXIS sequentially according to the randomization schedule. Due to the short time frame (i.e., within 5 minutes of ED arrival) in which the study medication had to be administered, a telephone or web-based randomization could not be used. Therefore, a paper-based system with sequential numbering was implemented. The sequential numbering followed the permuted block randomization scheme described above.

Once the participant was determined to be eligible, the following procedures were used:

a) A medication nurse or designee determined the appropriate age group for the participant.
b) The medication nurse or ED pharmacist accessed the first sequentially labeled study medication kit based on the pre-determined age group for the participant.
c) A dosing chart accompanied each study medication kit showing the volume of diluent to add to dilute the study medication, if applicable.
d) Study medication was packaged using the 5 mg/mL concentration of diazepam and a 4 mg/mL concentration of lorazepam. Because diazepam is unstable with dilution, the following instructions were used.
  a. For diazepam vials: Draw up 1.6 mL of Study Drug. Administer 0.04 mL/kg to maximum of 1.6 mL. If a second dose is required, please administer 0.02 mL/kg to a maximum of 0.8 mL.
  b. For lorazepam vials: Dilute1 mL of Study Drug with 0.6 mL of diluent. Administer 0.04 mL/kg to maximum of 1.6 mL. If a second dose is required, please repeat dilution of 1 mL of study drug with 0.6 mL diluent. Administer 0.02 mL/kg to a maximum of 0.8 mL.
  Note: this will achieve a drug volume of 1.6 mL with diazepam concentrated as 8 mg/1.6 mL and lorazepam concentrated as 4 mg/1.6 mL.
e) Administration instructions stated to deliver 0.04 mL per kilogram of child’s weight of the study medication up to a maximum of 1.6 mL. 0.04 mL/kg (maximum dose 1.6 mL) will deliver 0.1 mg/kg of lorazepam (maximum dose 4 mg) and 0.2 mg/kg of diazepam (maximum dose 8 mg). Half of this dose could be repeated in 5 minutes if the participant was still convulsing.
f) After masking the syringe with opaque tape, the medication nurse handed the final dilution to the bedside nurse or physician for slow IV push.
g) The medication nurse and/or ED pharmacist signed an affidavit attesting that she/he did not reveal the dilution volume or any impression of which medication was prepared.

### 9.4.4 Selection of Doses in the Study

#### 9.4.4.1 Lorazepam

As described in Section 7.2.2.1, a pharmacokinetic (PK) study of lorazepam was conducted as a part of the BPCA contract with NICHD, which evaluated the PK of lorazepam after intravenous administration to pediatric participants aged 3 months to 18 years (Study 1). The PK results, along with safety and tolerability data, indicated that a dose of 0.1 mg/kg (4 mg max), followed by 0.05 mg/kg (2 mg max) at 5 minutes, would achieve and maintain lorazepam concentrations in the range associated with anticonvulsant effects for 12 hours and would not exceed those associated with heavy sedation. Results of Study 1 study were used as guidance for dosing for the current study (Study 2).

#### 9.4.4.2 Diazepam

##### 9.4.4.2.1 Choice of control group

Lorazepam is only FDA-approved for treatment for SE in participants over 18 years of age. Textbooks and expert opinion recommend both diazepam and lorazepam as initial therapy for children in SE and provide recommended doses that are commonly used., However, data to support firm recommendations for one medication over another are lacking. Thus, either diazepam (FDA-approved) or lorazepam can be considered first-line agents for pediatric SE, and the physician’s choice of agent depends on local practice patterns and individual treatment styles. Thus, diazepam was chosen as the comparator medication to assess the safety and efficacy of lorazepam.

### 9.4.5 Selection and Timing of Dose for Each Participant

The following dose of study medication was used for the first dose. A second dose, when required for ongoing convulsions, was half the first dose.

- Lorazepam: 0.1 mg/kg slow IVP to maximum dose 4 mg
- Diazepam: 0.2 mg/kg slow IVP to maximum dose 8 mg.

Medication was administered per the following schedule (see Figure 9-3):

- Time zero minutes: a single dose of either lorazepam or diazepam was given. Time zero was defined as the end of the medication dose after a one-minute IV push.
- Time five minutes (ongoing SE): a second dose of the same study medication could be delivered if indicated. The second dose was half the first dose.
- Time twelve minutes (ongoing SE): fos-phenytoin at 15–20 mg/kg of phenytoin equivalent (PE) at an infusion rate of 1–3 mg PE/kg/min (maximum 150 mg PE/min) could be initiated as deemed necessary by the treating physician. If fos-phenyotin was unavailable, then phenytoin 15–20 mg/kg was administered. If fosphenytoin/phenytoin was contraindicated, phenobarbital was initiated at 15–20 mg/kg (maximum dose 800 mg).
- If the participant responded to the first dose, maintenance therapy could be started at time fifteen minutes.
- If the participant responds to the second dose, maintenance therapy could be started at time twenty minutes.
- Additional medications were administered at the discretion of the treating physician.

Figure 9-3 Early study participant flow

### 9.4.6 Blinding

This was a double-blinded study, where the participants as well as the PI and the staff administering the study medication to the participants were blinded. To ensure standardization and consistency in study medication distribution and randomization procedures, the BPCA DCC contracted services to provide a central pharmacy for all sites in the United States. Canadian sites used local supply of lorazepam and diazepam and adhered to regulatory and study specific requirements for labeling and preparation. Each local pharmacy ensured that the study medication was distributed to the ED and stored in a secure locked location. At most sites there was the (proprietary) PYXIS system used to dispense emergency medications. The site Investigational Pharmacist, per the study protocol and FDA requirements regarding study medicine dispensation, trained all pharmacy staff. One of the key concepts in determining the double blind procedure was the dose of lorazepam, which was established by Study 1 (the pharmacokinetics (PK) study). Diazepam was available as a 5 mg/mL and 10 mg/mL concentration and lorazepam was available as a 2 mg/mL and 4 mg/mL concentration. Neither drug is stable for an extended period of time if diluted into any other concentration. Thus volume-equivalent doses were not possible from the pharmacy, which required dilution by a medication nurse or ED pharmacist prior to blinded administration. Blinding was performed by the local pharmacy according to the randomization procedures described in Section 9.4.3. In brief, an ED pharmacist or medication nurse drew up the study medication (diluting the lorazepam) so that the final volume, based on estimated or actual participant weight, was the same for either study medication. Opaque tape was applied to the syringe barrel and the study medication was handed to the treatment team.

The BPCA DCC unblinded staff maintained a master list of the randomization numbers for each site that identified the study medication assigned to each number. This list was also only accessible by the pharmacy, the unblinded study monitors and statisticians conducting data analysis. Participating clinicians were masked to the contents of the study medication vials.

The BPCA DCC maintained a 24 hour-7 days a week hotline that could reveal the study medication administered to a participant in case an investigator needed to determine the study medication administered. No emergent unblinding was necessary in this study.

### 9.4.7 Prior and Concomitant Therapy

Medications taken seven days prior to and up to 24 hours after study medication administration were collected and recorded. The use of a benzodiazepine within 1 week of presentation to the ED was exclusionary if this was known prior to study medication administration.

### 9.4.8 Treatment Compliance

All participants were treated in hospital emergency departments. Therefore, each dose of study medication administration was given and monitored by hospital staff, then reviewed by study personnel.

## 9.5 Efficacy, Pharmacokinetic, and Safety Variables

### 9.5.1 Efficacy, Pharmacokinetic, and Safety Measurements Assessed and Flow Chart

#### 9.5.1.1 Primary Efficacy Endpoints

The primary efficacy endpoint is a composite endpoint, defined as the proportion of participants who have both (1) a cessation of convulsions within 10 minutes of the initial administration of the study medication and (2) a sustained absence of convulsions for 30 minutes from the initial administration of the study medication.

#### 9.5.1.2 Primary Safety Endpoints

The primary safety endpoint is the proportion of participants who experience severe or life-threatening respiratory depression within four hours of the initial administration of the study medication.

#### 9.5.1.3 Secondary Efficacy Endpoints

1. Number and proportion of participants with a sustained absence of convulsions for 30 minutes
2. Number and proportion of participants with a sustained absence of convulsions for 60 minutes.
3. Number and proportion of participants requiring a second dose of study medication.
4. Number and proportion of participants who require only a single dose of study medication and have no recurring seizures within 30 minutes.
5. Number of minutes from the end of the first administration of the study medication (lorazepam or diazepam) to the cessation of the initial convulsion.
6. Number of minutes from study medication administration until new seizure activity is observed (within 24 hours).
7. Number of minutes from study medication administration until there is a return to baseline functioning/mental status (duration of sedation).

#### 9.5.1.4 Secondary Safety Endpoint

The secondary safety endpoint is the proportion of participants who experienced any serious adverse events considered to be possibly, probably, or definitely related to the study medication (lorazepam or diazepam).

Participants were monitored continuously during convulsions and for one hour after termination of the index convulsion and a return to consciousness. Clinical parameters were recorded on the CRF per the schedule presented in Table 9-1.

Table 9-1 Schedule for recording clinical parameters on the Case Report Form

NOTE: Low respiratory rates, heart rates and blood pressure measurements observed on the monitor that are unconfirmed by a clinician were NOT reported as an Adverse Event.

Adverse Events | Data Recorded | Frequency of Monitoring | Clinical Definition
Cardiorespiratory
Respiratory depression (apnea longer than 20 seconds or RR age-specific criteria: < 2 yr: < 24 rpm; 2 yr to <7 yr: <20 rpm; 7yr to <13 yr: <16 rpm; 13 yr & above: <12 rpm) | RR | Continuous monitoring during index convulsions with Q15” documentation until one hour after termination of convulsions. If respiratory depression occurs then pt should be monitored until cessation of the resp. depression or until participant reaches the clinical endpoint of life-threatening as defined in right column. | RR low for more than 2 minutes or apnea requiring medical intervention for more than 2 minutes. Severity rated as follows:; Transient: resolves spontaneously without intervention; Mild: resolves with stimulation only; may require supplemental oxygen Moderate: requires airway manipulation (e.g., positioning, jaw thrust, chin lift) Severe: requires assisted BVM ventilation; Life-threatening: requires; - endotracheal intubation;; - tracheostomy; or; - ventilatory support above baseline for ventilator-dependent participants
Bradycardia (HR age- specific criteria: < 2 yr: < 80 bpm; 2 yr to <7 yr: <70 bpm; 7yr to <13 yr: <60 bpm; 13 yr & above: <50 bpm) | HR | Continuous monitoring during index convulsions with Q15” documentation, until one hour after termination of convulsions if bradycardia occurs then pt should be monitored until cessation of bradycardia | Lasting more than 2 mins or requiring medical intervention; Severity rated as follows:; Transient: resolves spontaneously without intervention; Mild: resolves with stimulation only; may require supplemental oxygen; Moderate: requires airway manipulation (e.g., positioning, jaw thrust, chin lift) Severe: requires assisted BVM ventilation; Life-threatening: requires; - endotracheal intubation;; - tracheostomy;; - ventilatory support above baseline for ventilator-dependent participants;; - chest compressions; or; - chronotropic/inotropic medications
Hypotension (Systolic BP age-specific criteria: <2 yr: <70 mmHg; 2 yr to <7 yr: <80 mmHg; 7yr to <13 yr: <85 mmHg; 13 yr & above: <90 mmHg) | BP | Q 15” during convulsions, until one hour after termination of index convulsions | Lasting more than 10 minutes; Severity rated as follows:; Transient: resolves spontaneously without intervention; Mild: resolves with stimulation only; Moderate: requires a single fluid bolus of up to 20 mL/kg; Severe: requires more than one fluid bolus (i.e., more than 20 mL/kg); Life-threatening: requires chronotropic/inotropic medication (s)
Hypercarbia measured at one hour | Arterial, venous, or ETCO2 pCO_2_ | On insertion of IV line or arterial blood sampling or placement of end-tidal CO2 monitor | Mild: pCO_2_ > 50 arterial or end-tidal or >55 venous; Moderate: pCO_2_ >60 arterial or end-tidal or >65 venous; Severe: pCO_2_ >70 arterial or end-tidal or >75 venous
Hypoxemia (Oxygen saturation < 90% on room air or <95% on supplemental oxygen) | Oxygen saturation | Continuous monitoring during index convulsions with Q15” documentation, until one hour after termination of convulsions. | Lasting more than 2 minutes or requiring medical intervention beyond supplemental oxygen; Severity rating as above for respiratory depression
Ventricular dysrhythmia | ECG | Continuous monitoring during index convulsions with Q15” documentation, until one hour after termination of convulsions | Lasting more than 2 minutes or requiring medical intervention
Cardiac arrest | ECG | Continuous monitoring during index convulsions with Q15” documentation, until one hour after termination of convulsions | Asystole or pulseless electrical activity
Aspiration of gastric contents | Clinical exam, Chest X-ray | PRN chest radiograph | Defined by treating clinician
Neurologic
Duration of sedation after cessation of status epilepticus | Modified Riker Score | 30 mins following study drug administration and then Q 1 hours for 4 hours or until Riker Score of 4, whichever comes first | Riker score < 3
Agitation | Modified Riker score | 30 mins following study drug administration and then Q 1 hours for 4 hours or until Riker Score of 4, whichever comes first | Riker score > 5

Blood specimens were drawn per the schedule presented in Table 9-2

Table 9-2 Schedule for Drawing Blood Specimens

Biochemical Marker | Baseline (Prior to study drug administration) | 1 hour | 24 hours or Discharge
CBC^1^ | X * | | X
AST, ALT | X ** | | X
Glucose | X ** | | X
Gamma GT | X ** | | X
Electrolytes^2^ | X * | | X
Calcium | X ** | | X
BUN, Creatinine | X * | | X
Blood gas (arterial or venous) | X ** | X

* Samples were obtained as part of routine clinical care.

** Samples were obtained before informed consent had been obtained from families for cohort 2 (EFIC) participants. 1 mL of blood was only drawn when samples for clinical care were obtained to avoid an extra needle-stick to the child.

1 A differential was not required.

2 Electrolyes included sodium, potassium, chloride, and carbon dioxide or bicarbonate.

### 9.5.2 Appropriateness of Measurements

The study was powered on a primary efficacy endpoint. Although we are interested in both efficacy and safety, it would be difficult to use a combined endpoint. Lorazepam could succeed or fail for either efficacy or safety, making interpretation of the results difficult. For example, lorazepam might fail because of higher rates of need for assisted ventilation, even though it was the more effective drug for stopping status. Therefore, we used efficacy as the primary endpoint. Readers of the results of the study can make inferences about usefulness for treatment based on both efficacy and safety because we will report both outcomes.

### 9.5.3 Primary Efficacy Variables

The primary efficacy endpoint was a composite endpoint, defined as the proportion of participants who have both (1) a cessation of convulsions within 10 minutes of the initial administration of the study medication and (2) a sustained absence of convulsions for 30 minutes from the initial administration of the study medication.

### 9.5.4 Drug Concentration Measurements

#### 9.5.4.1 Pharmacokinetic Samples

The schedule for PK sample draws is presented in Table 9-3.

Table 9-3 Schedule of Pharmacokinetic Sample Draws

Sample Collection Time | First Line | Second Line Insertion at:
Time | 1 Line Only | 0–10min | 10–30min | 0.5–2h | 2–6h | 6–12h | 12–16h | 16–24h
0 - Pre Dose | X^*^ | X | X | X | X | X | X | X
10 min | | X
30 min | | X | X
Insertion of Second Line | | | | X | X | X | X | X
4–6 h post 2nd Line Insertion | | | X | X | X | X | X
24 h/discharge | X | X | X | X | X | X | X | X

* The Pre-Dose sample was obtained before informed consent was obtained from families for cohort 2 (EFIC) patients. 1.0 mL of blood was drawn to avoid any risks of blood sampling; this sample was only drawn when samples for routine clinical care were obtained. Following the consent process, the 24 hour or discharge sample (if earlier than 24 hours) was also obtained.

## 9.6 Data Quality Assurance

The following steps were outlined to assure the accuracy and reliability of data, including the selection of qualified investigators and appropriate study sites, review of protocol procedures with the investigator and associated personnel prior to the study, and ongoing review of the site data and reports by the PODS site and by the BPCA DCC.

### 9.6.1 Investigators Meetings and Training

Initial site training occurred at an Investigators’ Meeting on ▬. An initiation visit was conducted at all sites prior to activation. All study procedures were reviewed and an overview of the protocol was provided to all enrolling staff by the study PI. Sites conducted training on an ongoing basis to ED and research staff at staff meetings, medical rounds and other meetings. If enrollment ceased for several consecutive months, sites were required to complete competency training. All training documentation was stored in the regulatory meeting and reviewed by Site Monitors.

### 9.6.2 Site Monitoring Visits

Monitoring visits to the trial sites were scheduled and conducted consistent with the BPCA DCC Dynamic Monitoring Plan during the study to ensure that all aspects of the protocol were followed. Source documents were reviewed for verification of data collected on the eCRFs. The PODS and participating PODS sites and investigators guaranteed access to source documents by the BPCA DCC and the IRB; and this access was given when required. The Investigator and relevant site personnel were available during the monitoring visit and set aside sufficient time for the process.

On ▬, the Sponsor suspended enrollment at ▬ due to randomization errors discovered during a routine monitoring visit. After retraining, new Standard Operating Procedures (SOP) implementation and review of the CAPA (Corrective and Preventive Actions) submitted by the site, the sponsor reactivated enrollment on ▬. After reactivation no further issues were identified at this site. Data from participants enrolled at ▬ prior to ▬ were not included in the primary efficacy analysis.

On ▬, the Sponsor suspended enrollment at ▬ due to protocol non-compliance issues identified in the first two enrollments at the site. After retraining and submission of documented staff competencies, the sponsor reactivated enrollment on ▬. Since that time, there were no further issues identified at this site.

### 9.6.3 Regulatory Agency Audits

The FDA conducted an inspection of the study site at ▬ ▬ from ▬ through ▬ and concluded that the corrective actions already instituted in response to the randomization errors (see Section 9.6.2 above) were sufficient. Audit reports are presented in Appendix 16.1.8.

### 9.6.4 Clinical Data Management

This study initially used paper CRFs to record study data. The BPCA DCC transferred the data from the previous CC (Premier Research) Data Sets to the DCC’s electronic data capture system AdvantageEDCSM (Advantage Electronic Data Capture System). An extensive QC process was followed prior to uploading the data into the DCC EDC system. Prior to the initiation of AdvantageEDC, some of the paper CRFs were collected from the sites and manually entered into AdvantageEDC by DCC staff. The study solely used AdvantageEDC for data capture at sites after November 2009 and study site personnel completed all data entry. A User’s Guide and Forms Instructions for AdvantageEDC were provided to sites and updated as required to ensure site understanding of system navigation, associated reports and instructions for form completion.

Source documents were developed and distributed by the BPCA DCC. These documents were based on the protocol requirements and were approved by the PODS PI. Source documents were stored in a locked, restricted access space at study sites. At all times, only research personnel and Investigators had access to the source documents. These documents were maintained as required by federal regulations at all participating sites.

Electronic CRFs (eCRFs) were created by the BPCA DCC, reviewed by the Administrative Executive Committee (AEC), PODS PI and staff and approved by the NICHD Project Officer. At all times only research personnel had access to the data contained within the eCRFs. A copy of the study data at each site, at study end, will be maintained under double lock for 2 years post label change. Participant numbers were used to identify study participants; no personal identifiers were included on publicly accessible databases.

## 9.7 Statistical Methods and Determination of Sample Size

A complete Statistical Analysis Plan (SAP) was finalized prior to locking the database for the study, and can be found in Appendix 16.1.9

### 9.7.1 Statistical and Analytical Plans

All analyses and data summaries were produced using SAS® Software version 9.2 or later.

#### 9.7.1.1 Analysis Population

Due to duplicate enrollments, the safety population was based on total number of randomizations instead of total number of participants. All randomizations where the participant received at least one dose of study medication were included. Modified ITT (MITT) population included all randomized participants who received at least one dose of study medication and are diagnosed as status epilepticus participants. The MITT population also excluded participants with randomization errors from a single site (▬), at which randomization was performed incorrectly by the Investigational Pharmacy (Described in Section 9.6.2). If a participant had more than one randomization, the MITT population only included data from the first enrollment in which the participant met the MITT definition. Per protocol (PP) population included all participants in the MITT Population without a major protocol deviation. Major protocol deviations were defined prior to the unblinding of the data. Sensitivity population (ITT population) included all MITT population and the participants with the randomization errors. All safety analyses were performed on the safety population. The primary safety analysis was also performed on the safety population with participants with the randomization errors excluded and on the per protocol populations as a part of the sensitivity analyses. Efficacy analyses were performed on MITT population, per protocol population and sensitivity population.

#### 9.7.1.2 Low Enrollment at Some Sites

Small sites (sites that enrolled less than 4 participants in at least one treatment arm: ▬ (N=9), ▬ (N=3), ▬ (N=8)) were combined to fonn a single analysis site in order to obviate non-estimable situation (i.e., at least 2 observations are needed to estimate variance) in the evaluation of site effect in the analysis.

### 9.7.2 Determination of Sample Size

Sample size estimates were generated to achieve the primary study objective (defined in Section 8.1) that lorazepam is superior to diazepam in treating pediatric SE. The primary efficacy endpoint is defined as the proportion of participants who had cessation of convulsions within 10 minutes of receiving the study medication and a sustained absence of convulsions for 30 minutes from the initial administration of the study medication.

Based on the estimates presented in the Written Request, if the difference in proportions for the primary efficacy endpoint between treatment groups is ≥17%, there would be sufficient power (>80%) to reject the null hypothesis. Table 9-4 shows that if the success rate in diazepam arm is 60% then a sample size of 240 MITT participants would be sufficient to detect at least 17% difference between treatment groups. However, if the true success rate in the diazepam arm in the pediatric population is lower than the observed rate in the pivotal adult trial, the study would be underpowered to detect a 17% difference between treatment arms. If the success rate in the diazepam arm is 50%, a sample size of 262 participants would provide 80% power to detect a 17 percentage point difference and 91.5% power to detect a 20 percentage point difference. The power calculations in the table below are based on two-sided Z test with pooled variance and a significance level of 0.05.

Table 9-4 Power to Detect 17 Percentage Points Difference Between Treatment Groups

(Lorazepam Success Rate) | (Diazepam Success Rate) | Power with N=240 | Power with N=262
0.67 | 0.50 | 0.765 | 0.800
0.70 | 0.50 | 0.890 | 0.915
0.72 | 0.55 | 0.785 | 0.819
0.75 | 0.55 | 0.906 | 0.929
0.77 | 0.60 | 0.813 | 0.846
0.80 | 0.60 | 0.927 | 0.946

## 9.8 Changes in the conduct of the Study or the Planned Analyses

### 9.8.1 Changes in conduct of study

There were five amendments implemented to the original protocol (dated January 19, 2007). The original protocol and the five amended protocols are provided in Appendix 16.1.1.

The five amendments to the protocol are summarized below.

#### 9.8.1.1 Protocol Amendment 1

Protocol Amendment 1, dated March 10, 2008, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol affected the overall study design and study conduct. Changes made in Protocol Amendment 1 are presented in the table below –

AMENDMENT CHANGE | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Changed: Lack of [struck: serious] severe or life-threatening respiratory depression.; Primary safety [struck: hypothesis] endpoint’.; Deleted: H_o_ and H_a_; Added: ‘No formal hypothesis testing will be performed on the primary safety endpoint. Rates will be presented as a proportion with exact 95% binomial confidence limits.’ | Primary Safety Endpoint
[underlined: Clarified that] study staff will call family 30–40 days following enrollment to conduct a follow up interview to determine participant well-being and to ascertain the presence of late adverse events for participants who signed the informed consent. | Section 5.1 Enrollment Methods -; Cohort 1 (preconsented pts) Enrollment Methods.; Cohort 2 (EFIC) Enrollment Methods; Section 5.7 Telephone Follow up
[underlined: Replaced] ‘Lorazepam or diazepam’ [underlined: with] ‘benzodiazepine’ | Section 4.3.2.2 Exclusion Criteria, Figure 1, Figure 2
[underlined: Added the following] – Primary efficacy and safety data from participants who are early terminators from the study for pregnancy or use of a benzodiazepine will be retained. We will perform sensitivity analyses for both efficacy and safety to determine whether exclusion of early terminators affects the results. | Section 4.3.2.2 Exclusion Criteria
[underlined: Added bold text-] participating clinician will proceed with enrollment as described in the informed consent procedures if a parent or legal guardian is not available or if time or emotional distress does not allow. | Section 5.1 Enrollment Methods - Cohort 2 (EFIC) Enrollment Methods; Section 5.7 Telephone Follow up
[underlined: Clarified] details of block randomization at each site | Section 5.4 Randomization and Masking Procedures
[underlined: Clarified] that the emergency unblinding hotline will be housed at the Coordinating Center (BPCA-CC) rather than a central pharmacy - [struck: Central pharmacy] BPCA-CC unblinding service will maintain randomization master list. They will also maintain 24hr-7 days a week hotline. | Section 5.4.1 Emergency Unblinding Procedures
[underlined: Changed] Seizures [underlined: To] Generalized Tonic-Clonic Seizures | Figure – Early Study participant Flow
[underlined: Clarified] the duties and meeting schedule of the DSMB. Added that ‘out of the 4 times they will meet, 3 will be via teleconference, 1 in person | Section 6.2 Data and Safety Monitoring Board
[underlined: Inserted text in bold –]; 1. Response latency time, defined as the time from completion of the initial dose of study medication administration to the end of the convulsion before the participant regains consciousness;; 2. Sustained absence of generalized tonic-clonic seizures for 60 minutes;; 3. Presence and severity of respiratory depression (see Table below); 4. Time from completion of the initial dose of study medication administration to return to normal consciousness, defined as a Riker Score of 4 or 5; | Section 7.1 Monitoring Parameters and Outcomes
Corrected error in age-specific respiratory rate – 13yr & above RR age-specific criteria changed from <[struck: 44] bpm to <12 bpm; Clarified clinical definitions of sedation and agitation - Riker score for clinical definition for ‘Duration of sedation after cessation of status epilepticus’ changed from <[struck: 4] to <3. Riker score for clinical definition for ‘Agitation’ changed from >[struck: 4] to >5 | Adverse Event Table
[underlined: Replaced] eCRFs [underlined: with] CRFs. Reference to username and password deleted. ‘Copy of study data [underlined: at each site]’ added | Section 9.3 Case Report Forms (CRFs)
[underlined: Clarified] statistical analysis to account for site and to clarify that all other analyses are secondary.; Added: ‘The primary analysis model will include treatment assignment and center, allowing a clear declaration of the effectiveness of the 2 study drugs.’ Added: ‘All subsequent analyses, considering different factors in the model, will be considered secondary analyses of the primary endpoint.’ | Section 9.4 Data Analysis
[underlined: Inserted the following -]; Primary Endpoints:; The primary efficacy endpoint for the study will be evaluated based on the null and alternative hypothesis. Following a step-down approach, the primary safety endpoint will be summarized by randomized treatment assignment.; #1 and #2 separated into ‘Efficacy’ and ‘Safety’ respectively.; Null and alternative hypothesis for #2 deleted.; Added ‘The secondary endpoints will be evaluated without pre-specifying a hierarchical order for assessment. Additionally, no adjustment will be made for multiplicity.’; [underlined: Secondary Endpoints]: Following additions (underlined) made; - Number of minutes from the [underlined: end of the first] administration of the study drug (Lorazepam or diazepam) to [underlined: the] cessation of [underlined: the initial] convulsion.; - Number of minutes from the cessation of convulsions until new convulsions are observed [underlined: (within 4 hours).]; - Adverse Clinical Events; - Number of minutes [underlined: from end of first] study drug treatment (Lorazepam, diazepam) to respiratory depression.; Deleted: ‘[struck: none or unconfirmed]’ from categorical classification of severity of respiratory depression, bradycardia and hypotension; Added Definition of a convulsion; Removed Hypercarbia, hypoxemia and aspiration of gastric contents as critical or near critical cardiorespiratory events; Deleted: ‘[struck: critical or near critical neurologic event]’ as proportion of pts that will be compared between randomized treatment groups. Paradoxical excitation defined as Riker score of 7 | Section 9.4.1 Study Endpoints
Changed: ‘[underlined: As a secondary analysis] the proportion of participants with a sustained absence of convulsions for 30 minutes after the administration of the study drug (Lorazepam or diazepam) will also be compared.’; Secondary efficacy analysis: analysis will be repeated to compare the proportion of participants requiring 1, 2 and [struck: >2] doses between treatment arms | Section 9.4.3 Efficacy Evaluation
[underlined: Changed and inserted bold text –]; [struck: Statistical] Efficacy and safety analyses will be based primarily on the modified intention-to-treat ([struck: M]ITT) population.; [underlined: Deleted] [struck: This MITT population is defined as all randomized participants who were exposed to either study drug for any period of time. Efficacy will be analyzed using the modified intention-to-treat population.]; [underlined: Added -] If the interaction term is significant, the interaction term will remain in the primary model for analysis.; Added: ‘If the treatment by study center interaction is found to be significant (p<0.1), [underlined: the interaction term will remain in the primary model for analysis].’ | Section 9.4.5 Analysis Plan
Text stating that analysis will be based on a general linear model deleted and replaced with ‘The proportion of participants who have respiratory depression will be summarized and presented using counts, percentages, and exact 95% binomial confidence limits. No formal hypothesis testing will be performed for the primary safety endpoint.’ | Analysis of Safety Endpoints
Clarified that we will not be analyzing PK samples for diazepam. Only lorazepam and its metabolite will be measured. | 9.5 Pharmacokinetic Analysis
[underlined: Inserted] new section titled – ‘Monitoring Based on Conditional Power’. | Section 9.4.6 Monitoring Based on Conditional Power
[underlined: Changed] - The impact of lorazepam concentration, age, [struck: albumin] and concomitant medications on free fraction will be assessed using a general linear models approach. | Section 9.5 Pharmacokinetic Analysis
[underlined: Changed]- Thus the primary risks of the study are those from randomization to lorazepam or diazepam, blood draws, and the inconvenience of [struck: potentially having to return to the hospital to complete study procedures] a follow-up phone call. | Section 10.1.1 Human subjects involvement and characteristics
[underlined: Inserted] - Under no circumstances will this delay the provision of care. | Section 10.1 Risk to the Subjects
[underlined: Replaced] ‘inotropic’ with ‘chronotropic/inotropic’ | Page 57 – Clinical definition of Safety Issue
[underlined: Addedd] - A serious adverse event (SAE) is any untoward medical occurrence that at any dose:............ Because the vast majority of pediatric seizure subjects will be admitted after the seizure, irrespective of study medication, subjects admitted for observational purposes only will not be considered to have; had an SAE | Section 11.2 Adverse Events and Critical and Near Critical Incidents
[underlined: Inserted] bold text in footnote – If participantparticipant did not respond to study drug and still in a generalized tonic-clonic seizure. (+/− 10 minute window does not apply) | Appendix B: Time and Events Table
[underlined: Inserted] Appendix C titled ‘Overview of the DSMB Monitoring Strategy- NICHD-2003-10-2 – Use of lorazepam for the Treatment of Pediatric Status Epilepticus: A Randomized, Double-Blinded Trial of lorazepam and diazepam | Appendix C

#### 9.8.1.2 Protocol Amendment 2

Protocol Amendment 1, dated March 26, 2009, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol affected the overall study design and study conduct. Changes made in Protocol Amendment 2 are presented in the table below –

AMENDMENT CHANGE | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Minor formatting, grammatical and spelling errors replaced. | All applicable sections
The following changes to company names have been made:; □ Premier Research Group plc changed to Premier Research Group Limited; □ ▬ changed to ▬ | Study Contact Information; Section 4.2 – Specific Study Design
Primary Objective changed to Primary Study Objective; Changed: ‘The primary efficacy objective of this study is to test [underlined: the hypothesis that lorazepam is superior to diazepam in treating pediatric SE.]; Deleted: [struck: following: lorazepam is efficacious in treating pediatric SE when compared to diazepam.]; Deleted: [struck: The primary safety endpoint will be lack of severe or life-threatening respiratory depression within 4 hours of the initial administration of the study drug. No formal hypothesis testing will be performed on the primary safety endpoint. Rates will be presented as a proportion with exact 95% binomial confidence limits.] | Section 3.1 Primary Study Objective
Secondary Study Objectives added:; For participants in whom SE is not terminated by benzodiazepines, data will be collected prospectively regarding subsequent medications, dosing, and effectiveness for the following.; - To determine the incidence of status epilepticus refractory to benzodiazepines; To determine whether there are risk factors for status epilepticus refractory to benzodiazepines;; - To determine the incidence of status epilepticus that is refractory to benzodiazepines but is terminated by second-line medication (phenytoin, phenobarbital);; - To determine whether there are risk factors for refractory status epilepticus not terminated by second-line medication;; - To determine whether there is a dose-response relationship for second-line medication;; - To examine the associations between specific second line medications and tachycardia, bradycardia, high blood pressure, low blood pressure, and respiratory depression;; - To determine the incidence of status epilepticus that requires coma induction, and describe the medications employed for coma induction;; - To correlate clinicians’ impression of cessation of status epilepticus with electroencephalographic tracings in a convenience sample of participants | Synopsis; Section 3.2 Secondary Objectives
Paragraph added:; Prior studies suggest that about one third of children continue seizing after administration of benzodiazepines. This may relate to seizure induced internalization of GABA receptors which reduces benzodiazepine efficacy [3, 4]. Thus, these children require treatment with additional anti-convulsant medications. Upon reaching the stage of benzodiazepine refractory SE, most published protocols list several options since there is no clear standard. These options include phenytoin, fosphenytoin, phenobarbital, and levetiracetam. If these are ineffective, generally suggesting the RSE stage, then most protocols suggest midazolam, pentobarbital, or inhaled anesthetics to induce a coma with electroencephalographic burst-suppression. However, there have not been prospective studies of these second and third line medications in pediatric SE. Data collected prospectively in this study regarding subsequent medications, dosing, and effectiveness will help guide the development of optimal treatment algorithms for children with benzodiazepine refractory SE. | Section 2.2. Need for Clinical Trials and the BPCA
Added: For participants in whom SE is not terminated by benzodiazepines, data will be collected prospectively regarding subsequent medications, dosing, and effectiveness | Section 4.1: Study Design Overview
Paragraph changed and added text in bold:; [struck: Primary] Efficacy and safety data from participants who are early terminators from the study for pregnancy or use of a benzodiazepine will be retained. [struck: We will perform] sensitivity analyses will be conducted for both efficacy and safety to determine whether exclusion of early terminators affects the results. | Section 4.3.2.2 Exclusion Criteria
Changed A medical monitor who will also [struck: be a member of the DSMB will review 100% of the CRFs] [underlined: serve as a liaison to the DSMB, will assure that all adverse event CRFs are reviewed by him or under his direction.]; Changed All other adverse events documented during the course of the trials will be included in quarterly reports to the [underlined: DSMB] [struck: BPCA-CC] and the NICHD.; Added: [underlined: The BPCA-CC will be responsible for preparing these quarterly reports.]; Changed: The DSMB will also [struck: be tasked with] examin[underlined: e][struck: ing] the conditional power [underlined: of the study] after 120 participants have been evaluated, relative to the primary efficacy endpoint.; Changed: Conditional power and re-estimation will be calculated based [underlined: on a binomial extension of] the method described by Chen et al [underlined: (2004).]; Deleted: [struck: Under this framework, the maximum enrollment of 240 participants may not be required if the re-estimation using 90% power reveals a target sample size of <120 participants per arm is sufficient.]; Changed: The purpose of these analyses is to determine whether there are statistical trends supporting the safety [struck: or efficacy] of one medication compared to the other.; Changed: In addition, the DSMB may request [underlined: additional] data review at any time and for any reason, [underlined: and] the DSMB may recommend to the Sponsor that the trial be interrupted or discontinued. | Section 6.2 Data and Safety Monitoring Board
Changed: 4. Time from completion of the initial dose of study medication administration [underlined: to return to baseline functionality/mental status] [struck: normal consciousness, defined as a Riker Score of 4 or 5];; Added: [underlined: 7. EEG determination of cessation of seizure activity in a convenience sample of participants;] | Section 7.1 Monitoring Parameters and Outcomes
Changed: [struck: bpm] changed to [underlined: rpm]; Changed: Neurologic adverse event -; Frequency of monitoring for Duration of sedation after cessation of status epilepticus: [struck: Q 15 mins for one hour after cessation of index convulsions] [underlined: 30 mins following study drug administration]; Frequency of monitoring for Agitation: [struck: Q 15” for one hour after cessation of index convulsions, then Q 1 hour for 4 hours or until Riker score of 4, whichever comes first] [underlined: 30 mins following study drug administration and then Q 1 hours for 4 hours or until Riker Score of 4, whichever comes first] | Secondary Outcome Table
Changed: Baseline [underlined: prior to] [struck: at the time of] study drug administration | Blood specimen schedule table
Following sections have been changed:; □ 9.4.1 [struck: Study Endpoints] [underlined: General Considerations]; □ 9.4.2[struck: Safety Evaluation] [underlined: determination of Sample Size]; □ 9.4.3[struck: Efficacy Evaluation] [underlined: Analysis Populations]; □ 9.4.4[struck: Sample Size Calculation] [underlined: Subject Disposition]; □ 9.4.5[struck: Analysis Plan] [underlined: Baseline Characteristics]; □ 9.4.6[struck: Monitoring Based on Conditional Power] [underlined: Efficacy Analysis]; Following sections have been added:; □ [underlined: 9.4.6.1 Primary Efficacy Endpoint and Analysis]; □ [underlined: 9.4.6.2 Secondary Efficacy Endpoints and Analyses]; Following section has been changed:; □ 9.4.7[struck: Pooling of Centers] [underlined: Safety Endpoints and Analyses]; Following sections have been added:; □ [underlined: 9.4.7.1 Primary Safety Endpoint and Analyses]; □ [underlined: 9.4.7.2 Secondary Safety Endpoint and Analysis]; □ [underlined: 9.4.7.3 Extent of Exposure]; □ [underlined: 9.4.7.4 Adverse Events]; □ [underlined: 9.4.7.5 Adverse Clinical Events and Critical or Near Critical Adverse Events]; □ [underlined: 9.4.7.6 Clinical Laboratory Assessments]; □ [underlined: 9.4.7.7 Vital Signs]; □ [underlined: 9.4.7.8 Concomitant Medications]; Following section heading changed:; 9.4.8 [struck: Determination of Treatment Group Comparability] [underlined: Secondary Study Endpoints and Analyses]; Following sections have been added:; □ [underlined: 9.4.9 Statistical and Analytical Issues]; □ [underlined: 9.4.9.1 Adjustment for Covariates]; □ [underlined: 9.4.9.2 Handling of Dropouts or Missing Data]; □ [underlined: 9.4.9.3 Interim Analysis and Data Monitoring]; □ [underlined: 9.4.9.4 Multicenter Studies]; □ [underlined: 9.4.9.5 Multiple Comparisons / Multiplicity]; □ [underlined: 9.4.9.6 Use of an Efficacy Subset of Subjects]; □ [underlined: 9.4.9.7 Exploration of the Effects of Various Prognostic Factors on Efficacy]; □ [underlined: 9.4.9.8 Criteria for Unblinding the Results]; □ [underlined: 9.4.9.9 Criteria for Stopping the Study] | Section 9.4 Data Analysis
Deleted from first paragraph - [struck: Thus, the common adverse effects associated with SE and with benzodiazepines will be monitored statistically using group sequential analyses and will be presented during routine DSMB meetings.] | Section 11.2 Adverse Events and Critical and Near Critical Incidents:
Deleted Whole Section | Section: 11.3 Stopping Rules
Changed: * ([struck: +/− 1 minute window applies] [underlined: +/− 10 minute window apply]; Added: [underlined: *** End-tidal CO2 will be collected when available.]; Added: [underlined: The +/− 10 min window does not apply for blood samples collected at discharge. For consented participants, a Protocol Violation will be filed only if the discharge samples were not collected.] | Appendix B: Time and Events Table -Table key
Changed Paragraph 1- [struck: The sample size was based on an expected 17% difference in treatment response rate; however], [underlined: The sample size was determined based on an expected 17% difference in treatment response rate. Under this assumption. a total of 240 participants (120 participants per arm) will provide 80% power to detect the difference between treatment arms at the end of study (Table No. 1). An unblinded interim analysis is planned when 50% of the participants are enrolled and have data available to determine the primary outcome. According to a procedure described by Chen. DeMets and Lan (2004), the DSMB will examine conditional power based on observed interim data, and either recommend a sample size increase or to continue the study as planned] for logistical reasons. the maximum number of participants that can be enrolled is 360 participants (a 50% increase from the original sample size of 240 participants).; Deleted: Paragraphs 2-6:; Operational Plan for Sample Size Re-estimation –; 1st Paragraph; Inserted: [underlined: A SAS program to calculate conditional power based on observed data and to reestimate sample size to achieve a desirable conditional power will be developed and validated by the study team using dummy data.]; Changed: In order for the DSMB to [struck: calculate] review; Added: [underlined: using the validated SAS program provided by the study team. This independent statistician will communicate results to the DSMB directly.]; 2nd Paragraph; Inserted: [underlined: The DSMB will communicate all decisions to the NICHD.]; Changed: If an increase in the sample size is required and agreed [struck: approved] by the DSMB [struck: NICHD], and the re-estimation is within the defined sample size limits pre-specified for the study ([underlined: 180 participants per arm]). the DSMB will communicate the revised target sample size to the [underlined: NICHD] [struck: randomization vender] for approval [struck: the trial].; Inserted: [underlined: If it is approved by NICHD, NICHD will communicate the decision to the BPCA coordinating center.]; 1st set: 1 and 2 amended from; 1. Compute conditional power for the primary hypothesis;; 2. If the conditional power is > 0.5. compute the sample size necessary to increase conditional power to 0.9.; to:; 1. Compute conditional power for the primary hypothesis [underlined: based upon the target sample size.]; 2. [underlined: If the conditional power is ≥ 0.9, no further computation is necessary.]; 3. If the conditional power is > 0.[underlined: 5 but < 0.9], compute the sample size necessary to increase conditional power to ≥0.9.; 4. [underlined: If the conditional power is ≤ 0.5, perform futility analysis (refer to the 3rd bullet point below).] | Appendix C
2nd set 1 and 2 amended from:; 1. If the conditional power is > 0.5, the sample size will be increased up to the maximum sample size considered feasible for this study;; 2. If the conditional power is ≤ 0.5, a futility analysis will be performed based on the predictive probability of achieving the endpoint within the maximum target sample size allocated for the study.; to:; 1. If the conditional power [underlined: based upon the original target sample size is ≥ 0.9, continue study as planned to enroll a total of 240 participants.]; 2. [underlined: If the conditional power based upon the original target sample size is > 0.5 but < 0.9, the sample size will be increased up to the maximum sample size considered feasible for this study to increase conditional power to ≥ 0.9. If conditional power is < 90% with the maximum sample size, decision will be made jointly by the DSMB and NICHD based on aggregated information, such as the cumulative safety data and actual conditional power with the maximum sample size considered feasible for this study. Additional information may be required and will be provided by the disinterested statistician. Decisions may include:]; a) [underlined: Continue study to enroll the maximum number of participants if the conditional power is sufficiently high.]; b) [underlined: Continue study as planned to enroll a total of 240 participants (to collect enough safety data).]; c) [underlined: Discontinue study. Perform all demographic/baseline and safety analyses as planned in the statistical analysis plan. Summarize efficacy data descriptively.]; 3. If the conditional power is ≤ 0.5, a futility analysis will be performed based on the predictive probability of achieving the endpoint within the maximum target sample size allocated for the study. [underlined: The following decision will be made jointly by the DSMB and NICHD based on aggregated information:]; a) [underlined: Continue the study as planned to enroll a total of 240 participants (to collect enough safety data).]; b) [underlined: Discontinue study. Perform all demographic/baseline and safety analyses as planned in the statistical analysis plan. Summarize efficacy data descriptively.]; Inserted: Calculation Details,; Inserted: Table No. 1 Two Independent Proportions Numeric Results of Tests Based on the Difference: P1 - P2; H0: P1-P2=0. H1: P1-P2=D1<>0. Test Statistic: Z test with pooled variance; Inserted: Table No. 2 Two Independent Proportions Numeric Results of Conditional Power and Revised Sample Size to Achieve 90% Conditional Power Based on the Estimated p1 and p2 at Interim.; Inserted: Table No. 3 Two Independent Proportions Numeric Results of Conditional Power with Maximum Sample Size Based on the Estimated p1 and p2 at Interim.

#### 9.8.1.3 Protocol Amendment 3

Protocol Amendment 1, dated December 16, 2009, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol affected the overall study design and study conduct. Changes made in Protocol Amendment 3 are presented in the table below –

AMENDMENT CHANGE | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Subject or participant replaced with participant | All applicable sections
Minor formatting, grammatical and spelling errors replaced | All applicable sections
BPCA Coordinating Center, BPCA-CC changed to BPCA Data Coordinating Center, BPCA DCC | All applicable sections
Medical Monitor changed from ▬ to ▬ | All applicable sections
Data Safety and Monitoring Board, DSMB changed to Data Monitoring Committee, DMC | All applicable sections
“Analysis center” is replaced with “age group” | All applicable sections
New DCC contact information replaced prior DCC | Study Contact Information
Added the word “Dose” in Table 1 and Table 2 for lorazepam and diazepam columns | Section 2.1.1 Potential Advantages of lorazepam in treating Pediatric SE
Added Exclusion Criteria #7: Prior participation in this study | Section 4.3.2.2 Exclusion Criteria
Added “Investigators located outside of the U.S. must also complete and sign a Form FDA 1572, as well as complete any additional documents required by their local research ethics committee and national health authority.” | Section 6.1 Responsibilities of the Clinical Investigator
Removed reference to a requirement by the Request for Proposal (RFP) in the second paragraph | Section 6.2 Data and Safety Monitoring Board
Deleted “by facsimile transmission” in the third paragraph | Section 6.2 Data and Safety Monitoring Board
Inserted “local” institutional requirements in the third paragraph | Section 6.2 Data and Safety Monitoring
Added “Advantage EDC” for data capture and storage | Section 9.1 Clinical Data Management
Deleted “under double lock for six years” | Section 9.2 Source Documents
Added terms “Electronic” and “eCRF” | Section 9.3 Electronic Case Report Forms
Deleted “including the treatment by analysis center interaction term. If the probability value from the treatment by analysis center interaction term is ≥ 0.10, the interaction term will be excluded from the final model. If the treatment by analysis center interaction is found to be significant (p < 0.1), the interaction term will remain in the primary model for analysis, and separate summaries of the primary efficacy endpoint will be provided for each of the analysis centers.” in the first and fourth paragraphs | Section 9.4.6.1 Primary Efficacy Endpoint and Analysis
Deleted “and analysis center” in the fourth paragraph | Section 9.4.6.2 Secondary Endpoints and Analysis
Deleted “Further assessment of the potential interaction between treatment and analysis center will be conducted on an as-needed basis (e.g., a significant interaction effect was found in the primary efficacy analysis and was not simply quantitative in nature).” in the first paragraph | Section 9.4.6.2 Secondary Endpoints and Analysis
Added “The model will be stratified by age group” in the fourth paragraph | Section 9.4.6.2 Secondary Endpoints and Analysis
“Analysis center” deleted in the second paragraph and added “The model will also be stratified by age group.” | Section 9.4.7.1 Primary Safety Endpoint and Analysis
Deleted “include age” in the third paragraph | Section 9.4.8 Secondary Study Endpoints and Analysis
Added “Additional exploratory analyses of the primary, secondary and tertiary efficacy endpoints will be conducted to assess center-by-treatment interaction in order to assess potential heterogeneity of treatment effect across the participating centers” to the first paragraph | Section 9.4.9.4 Multicenter Studies
Deleted “In order to minimize the risks of pain and discomfort to pediatric participants, we will limit the measurement of these biochemical markers to the sickest subset of participants, i.e. those admitted to intensive care units. Such participants have indwelling intravenous or intra-arterial lines for frequent blood sampling.” from the seventh paragraph | Section 10.1 Risks of Randomization
Removed the last two sentences from the first paragraph related to the recording of critical, near critical, and serious adverse events | Section 11.1.3 Critical and Near Critical Adverse Events
Added the header “Adverse Event Reporting Period” | Section 11.2 Adverse Events and Critical and Near Critical Incidents
Added “from product administration through” | Section 11.2 Adverse Events and Critical and Near Critical Incidents
Added a subsection “Assessment of Severity and Relatedness” | Section 11.2 Adverse Events and Critical and Near Critical Incidents
Updated the procedures for assessing, reporting and managing adverse events and severe adverse events | Section 11.2 Adverse Events and Critical and Near Critical Incidents
Added a severity grading table | Section 11.2 Adverse Events and Critical and Near Critical Incidents
Removed the sentence “In addition the medical monitor will review all CRF forms and report any discrepancies to the safety officer and DSMB.” | Section 11.2.1 Treatment monitoring

#### 9.8.1.4 Protocol Amendment 4

Protocol Amendment 4, dated September 9, 2010, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol affected the overall study design and study conduct. Changes made in Protocol Amendment 4 are presented in the table below:

AMENDMENT CHANGE | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Minor formatting, grammatical and spelling errors replaced | All applicable sections
Replaced “Subject” or “participant” with “participant.” | All applicable sections
Added zip code for Jim Chamberlain. | Study Contact Information
Replaced “Project Administrator” with “Project Director” for ▬. | Study Contact Information
Clarified the definition of the Modified Intent-to-Treat (MITT) group. | Synopsis
Replaced “eleven” with “fourteen” and “PECARN” with “United States and Canada.” | Section 14.1 Participating Sites
Clarified definition of generalized tonic-clonic status epilepticus. The definition is “a seizure that lasts at least 5 minutes that is either generalized tonic clonic in its entirety or starts focal and then generalizes; the seizure must be associated with loss of consciousness.” | Section 4.3.2.1 Inclusion Criteria
| Figure 1 Identification and Participant Enrollment Cohort 1 (preconsented participants)
| Figure 2 Identification and Participant Enrollment Under Exception from Informed Consent Cohort 2 (EFIC) Enrollment
Added “known” and “confirmed” to clarify pregnancy exclusion criteria. | Section 4.3.2.2 Exclusion Criteria
Added “known” and “confirmed” to clarify pregnancy exclusion criteria. | Figure 1 Identification and Participant Enrollment Cohort 1 (preconsented participants)
Added “known” and “confirmed” to clarify pregnancy exclusion criteria. | Figure 2 Identification and Participant Enrollment Under Exception from Informed Consent Cohort 2 (EFIC) Enrollment
Clarified that no other samples can be drawn from the same IV line that was used to administer the study drug with the exception of the pre-dose and 24-hr PK samples. | Section 5.2.1 Pharmacokinetic Samples
Clarified that sites should limit any other PK samples besides the pre-dose and 24-hr samples to those children who will receive two IV lines as part of standard clinical care and sign informed consent or those who consent to placement of a second line. | Section 5.2.1 Pharmacokinetic Samples
Re-formatted table to list suggested sampling times dependent upon time of insertion of the second line. | Section 5.2.1 Pharmacokinetic Samples
Clarified that participants whose parents have provided consent and/or who have provided assent for a second IV line are expected to have additional PK samples drawn from the second IV line | Section 5.2.1 Pharmacokinetic Samples
Replaced “Study Coordinator” with “Investigational Pharmacist” and “ED” with “pharmacy.” | Section 5.3 Pharmacy
Added reference to the BPCA DCC Pharmacy, Eminent Services. | Section 5.4 Randomization and Masking Procedures
Clarified that all SAEs should be reported to the DCC, PI, and DMC chair via the electronic data system. | Section 6.2 Data Monitoring Committee
Added provision that follow-up reports will be will be distributed by the BPCA DCC to the PI, DMC and NICHD. | Section 6.2 Data Monitoring Committee
Clarified that the DMC will confer electronically to review submitted SAEs at any time rather than solely on a monthly basis. | Section 6.2 Data Monitoring Committee
Clarified that Low respiratory rates, heart rates and blood pressure measurements observed on the monitor that are unconfirmed by a clinician should NOT be reported as an Adverse Event nor entered on an AE form. | Section 7.1 Monitoring Parameters and Outcomes
Deleted notations throughout the table that unconfirmed respiratory rate, heart rate, or low blood pressure noted on a monitor reading that is not confirmed by a clinician will not be recorded as AEs. | Section 7.1 Monitoring Parameters and Outcomes
Added Glucose to the list of biochemical markers to be collected at baseline and 24 hours. | Section 7.1 Monitoring Parameters and Outcomes
Clarified 1 mL of blood is expected to be drawn for biochemical markers and will only be drawn when samples for clinical care are obtained for AST, ALT, Gamma GT, Calcium, Blood gas. | Section 7.1 Monitoring Parameters and Outcomes
Added “Electrolytes include” to Table footnote 2. | Section 7.1 Monitoring Parameters and Outcomes
Clarified that Monitoring visits to the trial sites will be scheduled and conducted consistent with the BPCA DCC Dynamic Monitoring Plan. | Section 8.1 Site Monitoring Visits
Added sentence describing an AdvantageEDC User’s Guide will be provided to sites and updated as required to ensure site understanding of system navigation, associated reports and instructions for form completion. | Section 9.1 Clinical Data Monitoring
Replaced “data sheets” with “source documents” throughout the section. | Section 9.2 Source Documents
Clarified that all source documents are created and distributed by the BPCA DCC and maintained at all participating sites. | Section 9.2 Source Documents
Added sentence stating randomization will continue until there are 240 subjects meeting the MITT definition. | Section 9.4.3 Analysis Populations
Deleted number of minutes to cessation of electroencephalographic seizure activity in a convenience sample of participants and explanation as a secondary endpoint for analysis. | Section 9.4.6.2 Secondary Efficacy Endpoints and Analyses
Added that a laboratory adverse event should be recorded on an Adverse Event form. | Section 11.1.2 Clinically Significant Laboratory Values
Clarified that if the laboratory value abnormality is consistent with a current diagnosis, it may be documented as a part of that diagnosed disease and not be separately reported as an adverse event. | Section 11.1.2 Clinically Significant Laboratory Values
Added statement clarifying that adverse event start dates entered in AdvantageEDC may precede the date of study drug administration, details regarding AE form completion are provided in the User’s Guide to provide further guidance with respect to AE reporting | Section 11.2 Adverse Event Reporting Period
Added “clinically” before “resolved.” | Section 11.2 Adverse Event Reporting Period
Added a specific example for reporting a Riker score and updating the severity of the event with the most severe state identified. | Section 11.2 Assessment of Severity and Relatedness
Clarified “local” SAEs. | Section 11.2 Reporting and Management Procedures of AE/SAEs
Added reference to Section 7.1 for detailed monitoring parameters to be collected. | Appendix B Time and Events Table
Clarified all events are expected to be collected within a ± 10 minute window from the scheduled time point. | Appendix B Time and Events Table
Added column for Glucose to be collected at Pre-dose and 24 hrs or discharge. | Appendix B Time and Events Table
Replaced column header “LFTs” to “ALT/AST.” | Appendix B Time and Events Table
Moved “X’s” for Vitals, ECG Lead II, Pulse Ox, Physical Exam, and Neuro Exam and Riker Score from the “Start” row to the “Pre-dose+” row. | Appendix B Time and Events Table
Added PK sample to be obtained at +24 hr or discharge. | Appendix B Time and Events Table
Replaced “next Table” with “Protocol Section 5.2.1 and Appendix C” in the table footnote. | Appendix B Time and Events Table
Added footnote clarifying Pregnancy testing should be performed on females of childbearing potential broadly defined greater than 10 years of age, as those who have menses or are known to be sexually active. | Appendix B Time and Events Table
Changed Appendix B (continued) to Appendix C: Time Schedule for PK Sampling. | Appendix C Time Schedule for PK Sampling
Replaced “C” with “D.” | Appendix D Overview of the DMC Monitoring Strategy

#### 9.8.1.5 Protocol Amendment 5

Protocol Amendment 5, dated June 9, 2011, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol affected the overall study design and study conduct. Changes made in Protocol Amendment 5 are presented in the table below.

AMENDMENT CHANGE | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Minor formatting, grammatical and spelling errors replaced. | All applicable sections
Added updated phone numbers for ▬. | Study Contact Information
Deleted “To correlate clinicians’ impression of cessation of status epilepticus with electroencephalographic tracings in a convenience sample of participants.” | Synopsis
Updated the name of the new Pharmacokinetic Lab. | Section 5.2.1 Pharmacokinetic Samples
Added the source of the study medication for the Canadian Sites. | Section 5.3 Pharmacy and Section 5.4 Randomization and Masking Procedures
Clarified that no other samples can be drawn from the same IV line that was used to administer the study drug with the exception of the pre-dose and 24-hr PK samples. | Section 5.2.1 Pharmacokinetic Samples
Replaced “Study Coordinator” with “Investigational Pharmacist” and “ED” with “pharmacy.” | Section 5.3 Pharmacy
Added “Forms Instructions”. | Section 9.1 Clinical Data Management
The following statements were added to justify the increase in the MITT population: “The following table shows that if the success rate in diazepam arm is 60 then a sample size of 240 MITT participants will be sufficient to detect at least 17% difference between treatment groups. However, if the true success rate in the diazepam arm in the pediatric population is lower than the observed rate in the pivotal adult trial, the study will be underpowered to detect a 17% difference between treatment arms. A sample size of 262 participants would provide 80% power to detect a 17 percentage point difference and 91.5% power to detect a 20 percentage point difference. The power calculations in the table below are based on two-sided Z test with pooled variance and a significance level of 0.05.” | Section 9.4.2 Determination of Sample Size
Deleted the table for Two Independent Proportions. Added a new table along with an explanation for the modified analysis. | Section 9.4.2 Determination of Sample Size
Changed the MITT population to 262. | Section 9.4.2 Determination of Sample Size
Added “Number and proportion of participants who experience severe or life-threatening respiratory depression” | Section 9.4.7.5 Adverse Clinical Events and Critical or Near Critical Adverse Events
Changed 120 to 131 to reflect the new MITT population of 262. | Section 9.5 Pharmacokinetic Analysis
Deleted “SAS”. | Appendix D Overview of the DMC Monitoring Strategy

### 9.8.2 Changes in Planned Analyses

No changes were made to the planned analyses.