# 8 STUDY OBJECTIVES

## 8.1 Primary Study Objective

Based on the FDA’s Written Request, this study was designed as a superiority trial. The primary efficacy objective of this study was to test the hypothesis that lorazepam is superior to diazepam in treating pediatric SE. The primary efficacy endpoint was the cessation of convulsions within 10 minutes of the initial administration of the study medication, and a sustained absence of convulsions for 30 minutes from the initial administration of the study medication.

The primary efficacy hypothesis evaluated was as follows:

H0: There is no significant difference between the proportions of participants randomized and treated with either lorazepam or diazepam who have cessation of convulsions within 10 minutes of the initial administration of the study medication and a sustained absence of convulsions for 30 minutes from the initial administration of the study medication.

H1: There is a significant difference between the proportions of participants randomized and treated with either lorazepam or diazepam who have cessation of convulsions within 10 minutes of the initial administration of the study medication and a sustained absence of convulsions for 30 minutes from the initial administration of the study medication.

## 8.2 Secondary Objectives

This study had the following secondary objectives:

- To determine population pharmacokinetics (PK) of lorazepam using sparse sampling.
- To determine the feasibility of identifying participants for informed consent prior to arrival in SE for a RCT of lorazepam vs. diazepam for pediatric SE. To describe the experience of community consultation and public disclosure. To determine the feasibility of enrolling pediatric participants under an exception from informed consent. To determine participants’ and parents’ attitudes and reactions to an exception from informed consent approach.
- To determine the incidence of status epilepticus refractory to benzodiazepines.
- To determine whether there are risk factors for status epilepticus refractory to benzodiazepines.
- To determine the incidence of status epilepticus that is refractory to benzodiazepines but is terminated by second-line medication (phenytoin, phenobarbital).
- To determine whether there are risk factors for refractory status epilepticus not terminated by second-line medication.
- To determine whether there is a dose-response relationship for second-line medication.
- To examine the associations between specific second line medications and tachycardia, bradycardia, high blood pressure, low blood pressure, and respiratory depression.
- To determine the incidence of status epilepticus that requires coma induction, and describe the medications employed for coma induction.