# 7 INTRODUCTION

## 7.1 Background Information

### 7.1.1 Epidemiology of Pediatric Status Epilepticus

Status epilepticus (SE) is a condition of prolonged or repeated seizures. SE has been defined as “a seizure [that] persists for a sufficient length of time or is repeated frequently enough to produce a fixed and enduring epileptic condition [1].” The duration of time which is sufficient to qualify a seizure as SE was historically 30 minutes, but more recent publications have proposed a much shorter duration [2] based on videotape evidence in adults that isolated seizures are generally less than 5 minutes in duration [3]. Not all experts agree on this newer definition [4], however, most investigators agree that initiation of treatment should be early to avoid the potential for neuronal damage secondary to prolonged seizure activity [5,6].

There are approximately 50,000–60,000 episodes of status epilepticus annually in the United States in children and adults [7]. It is estimated that 4–8 children per 1000 may be expected to experience an episode of SE before age 15 years [8]. In the pediatric population, SE may present in participants with a known seizure disorder (epilepsy), or may occur in participants without epilepsy who experience a febrile seizure, metabolic imbalance, acute infection of the central nervous system, or a traumatic head injury. There are two major studies documenting the etiology of seizures in children. One study included participants from the pediatric intensive care unit (ICU) [9], and the other included pediatric inpatient and Emergency Department (ED) patients [10]. Although each reported a different distribution of etiologies, there were three major groups: 1) known patients with epilepsy (32% to 47%); 2) acute neurological conditions such as meningitis, trauma, tumors, stroke or encephalitis (23% to 44%); and 3) atypical febrile seizures (14% to 24%). SE has a mortality rate in children of approximately 4% and mortality is related to the underlying etiology of the SE [10]. The rate of occurrence of neurologic sequelae is age-dependent. Sequelae such as epilepsy, motor deficits, learning difficulties and behavior problems occur a rate of 29% in those who experience SE in infancy but at a rate of 6% in those who experience SE at an age over 3 years.

The majority of participants in SE present to an emergency department during or shortly after their seizure and treatments are rendered by ED or emergency medical services (EMS) without the direct involvement of a neurologist [11]. A study designed to look at treatment of SE should ideally be located in the setting where these participants are most often treated.

### 7.1.2 Benzodiazepine Therapy for SE

Participants who present in SE are treated with pharmacologic agents designed to terminate the seizure activity. Termination of the seizure activity with pharmacologic treatment may result in immediate benefit through improved maintenance of vital functions and long-term benefit through a decrease in neurologic sequelae. Benzodiazepines in general are considered to be the most effective agents for the initial treatment of SE, achieving lasting control in up to 80% of patients [12,12] They work by enhancing the inhibitory effect of the neurotransmitter Gamma-Aminobutyric Acid (GABA), by specific binding to the benzodiazepine-GABA-phenobarbital receptor complex [14]. Several studies have examined the use of benzodiazepines for pediatric SE, with results suggesting shortened duration and reduced seizure recurrence [15,15,16].Three specific benzodiazepines, diazepam, lorazepam, and midazolam, have all been reported to be effective in treating pediatric patients with SE [18]. These findings are important in initial seizure management since longer seizure duration has been associated with difficulty in controlling future seizure activity and risk for neurological damage [19]. However, benzodiazepines have serious side effects, most importantly respiratory depression. Management of respiratory depression and respiratory failure are the most common complications of benzodiazepine administration in the emergency setting; data on pediatric efficacy and safety are scant [20].

Effective drugs for SE are lipid-soluble. Benzodiazepines are typically weak bases and lipophilic due their hydrophobic rings. They are highly protein bound (70–99%) in the blood, and cross the blood-brain barrier by passive diffusion to enter the central nervous system (CNS) and cause their inhibitory effects. The rate of CNS distribution is proportional to the lipid solubility of the benzodiazepine. Thus, more lipohilic drugs generally have lower response times in controlling seizures. Structural differences at the N-1 and C-3 substituents account for differences in lipophilicity between benzodiazepines and are also responsible for variations in the drug half-life (see Table 7-1).

Table 7-1 Benzodiazepine Comparison Chart

Benzodiazepine | Diazepam | Lorazepam
Rate of Onset | Very fast | Intermediate
Elimination (t_1/2_), (hours) | 20–80 | 10–20
Duration | > 48 hours for sedation; 20 min for seizure control | 12–18 hours for seizure control
Formulation: for injection (per mL) | 5 mg diazepam compound; 40% propylene glycol; 10% ethyl alcohol; 5% sodium benzoate; 5% benzoic acid (buffer); 1.5% benzyl alcohol (preservative) | 2 mg or 4 mg lorazepam; 0.18 mL polyethylene glycol 400 in propylene glycol 2.0% benzyl alcohol (preservative)

## 7.2 Chemistry of Diazepam and Lorazepam

### 7.2.1 Diazepam

Diazepam is a benzodiazepine derivative, belonging to the N-1-substituted-3-unsubstituted class. As a result of the production of two intermediate active metabolites, diazepam has a longer half-life in comparison to other benzodiazepines like lorazepam. In spite of this, for acute seizure treatment, diazepam has been reported to only have a duration of action of 20 minutes. Diazepam has an onset of action within 3 minutes of a Gamma-Aminobutyric Acid (GABA) intravenous (IV) dose. However, diazepam blood concentrations decrease by 34% to 50% within the first 20 minutes after IV administration and by 62% to 72% within 2 hours. Due to its large volume of distribution, the drug ends up rapidly redistributing in lipid stores throughout the body, and is no longer available at the CNS to prevent recurrence of seizure activity.

### 7.2.2 Lorazepam

Lorazepam is not labeled for the treatment of SE and is not FDA-approved for children under 18 years of age. However, it is frequently used to treat SE and to provide sedation in children. There are two studies that have looked at the pharmacokinetics of lorazepam in children. McDermott et al studied pharmacokinetics of IV lorazepam at 0.05 mg/kg and 0.1 mg/kg in 10 term neonates with seizures [21]. Cessation of seizure activity was noted within 5 minutes with 6 participants experiencing a recurrence of seizures at a mean of 6.5 hours. The mean half-life elimination was 40.2 hours with a mean volume of distribution of 0.76 L/kg, which is lower than adult values at 1.3 L/kg volume distribution, but consistent with lower anatomic adipose tissue in neonates. The mean systemic clearance was 0.232 mL/min/kg. These pharmacokinetic parameters did not vary between participants receiving just lorazepam versus lorazepam and other anticonvulsants. Relling et al [22] evaluated pharmacokinetics in a group of 16 children age 2.8 to 14.2 years and found wide variations. There was a 2.4-fold range in clearance (mean=1.3, SD=0.4), a 12-fold range in 24-hour plasma concentrations, and a 3-fold range in terminal half-life (mean=10.5, SD=2.9).

#### 7.2.2.1 Lorazepam Pharmacokinetic Study

A pharmacokinetic study of lorazepam was conducted as part of the BPCA contract with NICHD. This study (Study 1) evaluated the pharmacokinetics (PK) of lorazepam after intravenous administration to pediatric participants aged 3 months to 18 years. Participants received lorazepam as part of clinical care for treatment for SE (Cohort 1) or had a history of SE with prior lorazepam therapy and were studied while not in SE (Cohort 2). Sparse PK samples were collected from Cohort 1 participants while intensive PK samples were collected from Cohort 2 participants. Both population (mixed effects) and non-compartmental (Cohort 2) PK modeling were performed. Protein binding was assessed in a subset of samples. Data summarized in this preliminary report were those available as of Sept 2006 and include 50 Cohort 1 and 15 Cohort 2 participants. The overall lorazepam PK post-hoc parameters from the population analysis were clearance (CL) (L/hr/kg) 0.070+0.051 (mean ± s.d.), volume of distribution at steady state (Vdss) (L/kg) 1.52±0.52 and half-life (hr) 17.3±7.3. The free-fraction was 10%. These are within the range previously reported in adults and clearance was similar to that previously reported in pediatric cancer participants. Weight adjusted CL and Vdss were higher in younger infants and children compared to older children but the magnitude of these differences was modest. Concomitant valproic acid (VPA) or enzyme inducing anticonvulsant drugs (EIAED) did not appear to affect lorazepam CL. Seizure activity did not appear to affect lorazepam protein binding and CL. These PK results, along with safety and tolerability data, indicate that a dose of 0.1 mg/kg (4 mg max) would achieve and maintain lorazepam concentrations in the range associated with anticonvulsant effects for 12 hours and would not exceed those associated with heavy sedation. Results of this study were submitted to the FDA on February 26, 2009 (IND 71,325/A0020) and were used as guidance for dosing for the current study. The results of this study were also published in the peer-reviewed literature [62].

## 7.3 Rationale for the Proposed Study

### 7.3.1 Advantages and Disadvantages of Lorazepam

#### 7.3.1.1 Potential Advantages of Lorazepam in treating Pediatric SE

Textbooks and expert opinion recommend both diazepam and lorazepam as initial therapy for children in SE and provide recommended doses that are commonly used [23,23]. However, unlike diazepam, lorazepam is only FDA-approved for treatment for SE in participants over 18 years of age. Despite this fact, many experts support the use of lorazepam over diazepam in pediatric SE [25,25,26,27,28]. Increased duration of action, increased effectiveness in terminating SE, and a lower incidence of respiratory depression have been cited as potential advantages of lorazepam over diazepam. However, data to support firm recommendations for one medication over another are lacking. Thus, either diazepam (FDA-approved) or lorazepam can be considered first-line agents for pediatric SE, and the physician’s choice of agent depends on local practice patterns and individual treatment styles. In the prehospital (Emergency Medical Services) setting, diazepam is commonly chosen because of a longer shelf life without refrigeration.

The evidence for increased duration of activity comes from the pharmacologic data discussed above. Because it is less lipid soluble than diazepam, lorazepam has a longer duration of activity in the central nervous system (CNS) than diazepam as demonstrated by animal studies. Lorazepam is thought to be effective as an anticonvulsant medication for up to 24 hours versus diazepam, which is effective for less than 1 hour [30]. Clinical evidence to support this is noted in several trials. A published retrospective analysis conducted in adult participants in the United Kingdom looked at both effectiveness in termination of seizure activity and seizure recurrence with need for repeat dosing in adult ED and in-hospital participants treated with lorazepam versus those treated with diazepam. They found no difference in the rate of terminating seizures, but did note that participants treated with lorazepam had a lower rate of recurrence of seizure activity and need for additional anticonvulsants [31].

Two large prospective clinical trials in adult participants looked at the rate of termination of seizures with lorazepam as compared with diazepam in emergency department and in-hospital patients [32], and in the prehospital setting [33]. Both studies found a trend towards a higher rate of effectiveness in the lorazepam treated participants, but in neither of these studies was the difference statistically significant. Both sets of authors did recommend use of lorazepam over diazepam, citing “ease of use” [32] and “preference as in-hospital therapy” as advantages [33]. As noted above, a large retrospective study also looked at the rate of seizure termination in adult participants treated with lorazepam versus those treated with diazepam and found no difference. They also, however, advocated the use of lorazepam, citing a lower rate of seizure recurrence [31]. Unfortunately these trials did not include pediatric participants and there are not similar large-scale, multisite, randomized controlled trials (RCTs) in pediatric participants with SE.

There are a few published studies that have directly compared diazepam with lorazepam in pediatric SE. These trials have all reported single institution results or small sample sizes that cannot be used to produce generalizable results. A retrospective study performed by Giang et al [34] reviewed 45 episodes of status epilepticus in children between the ages of 2 weeks and 18 years. Diazepam terminated status epilepticus in 11 of 16 episodes (69%) at a mean dose of 0.38 mg/kg (SD=0.21 mg/kg). Lorazepam resulted in cessation of 18 of 22 episodes (81%) with a mean dose of 0.11 mg/kg (SD=0.05 mg/kg). The study did not find any significant difference in the need for mechanical ventilation between the groups. Qureshi et al [35] compared data for a 6-month and 1-year period in which a protocol change dictated the change to lorazepam instead of diazepam. IV Diazepam at 0.32 mg/kg was used in 17 of 26 participants and IV lorazepam at 0.13 mg/kg was used in 31 of 59 participants. Seizure cessation was noted within 15 minutes for 65% of the participants in each group. However, the study noted, but did not control for administration of rectal diazepam in the prehospital setting. Appleton et al [36] conducted the only published prospective, randomized trial directly comparing lorazepam and diazepam in pediatric participants with SE. They evaluated 102 participants, one month to 16 years of age with SE, presenting to an ED at a large Children’s Hospital. One or two doses of intravenous medication stopped the convulsion in 19 of 27 (70%) of the lorazepam-treated participants and 22 of the 34 (65%) diazepam treated participants. (RR =1.09, 95% CI 0.77, 1.54). They also looked at the frequency in which additional drugs were needed to terminate the seizure. One of 27 participants (4%) who received intravenous lorazepam compared to five of 34 participants (15%) who received intravenous diazepam required additional antiepileptic drugs to terminate the presenting seizure. (RR =0.25, 95% CI 0.03, 2.03). Thus, while there was a trend favoring lorazepam, no statistically significant difference was noted. A Cochrane review of this topic concluded that there was “no evidence to suggest that intravenous lorazepam should be preferred to diazepam as the first-line drug in treating acute tonic-clonic convulsions including convulsive status epilepticus in children [37].

The third suggested advantage of lorazepam over diazepam is a lower rate of the serious side effect of respiratory depression. Older, retrospective data suggest that this may be true in children [38,39]. Orr et al [39] performed a retrospective case control study of the need for endotracheal intubation in children who were transported to a pediatric tertiary care center, after treatment for SE. They found that treatment with diazepam versus phenytoin or phenobarbital was associated with a significant increase in the need for intubation (adjusted OR=49;p<.001). However this study did not include participants treated with lorazepam, and thus did not compare the rates of respiratory depression between these two drugs. Chiulli et al [38] reported the only published data that demonstrated a statistically significant increased rate of respiratory depression with diazepam versus lorazepam when used to treat SE in children. This study was a retrospective chart review of 26 children with SE. They found an endotracheal intubation rate of 27% (4/15) in the participants treated with lorazepam and 73% (8/11) in those treated with diazepam. An important limitation of this methodology was the inability to control for medication dosages and rates of administration; pharmacokinetic principles suggest that rapid intravenous push of benzodiazepines should be associated with higher peak levels and thus higher rates of respiratory depression.

Prospective data on the rate of endotracheal intubation in children with SE do not demonstrate a statistically significant difference between treatment with lorazepam and diazepam. In the trial discussed above by Appleton et al, a lower incidence of respiratory depression occurred in the lorazepam-treated group-one of 27 (4%) participants compared to seven of 34 in the diazepam-treated group (21%), but this difference was not statistically significant (RR 0.21, 95% CI 0.02,1.37). In the retrospective study performed by Giang et al [34], the authors did not find any significant difference in the need for mechanical ventilation between the lorazepam or diazepam treated groups. Norris et al [40] demonstrated a 9% rate of respiratory depression in children given diazepam for an ongoing seizure in a prospective trial. However, they did not compare this rate to that of untreated children with seizures or children who received other drugs for seizure activity. In a retrospective review by Stewart et al. [41] of respiratory depression in 56 children treated for SE, the incidence of respiratory depression was correlated not with which benzodiazepine was used but rather with the use of multiple small doses of Lorazepam, suggesting that long duration of ongoing convulsions is important in predicting which participants will develop respiratory depression. Finally, large-scale prospective studies in adults have not demonstrated a difference in the rate of respiratory depression in participants treated with lorazepam versus those treated with diazepam [31,32,33, ]. Thus there is not clear evidence that there is a lower rate of respiratory depression in pediatric participants treated with lorazepam compared with those treated with diazepam.

#### 7.3.1.2 Possible Disadvantages of Treating Pediatric SE with Lorazepam

The literature does note some potential disadvantages of treating pediatric SE participants with lorazepam versus diazepam. One potential disadvantage is the fact that refrigerated storage is required for lorazepam but not diazepam. This is a potentially important issue in the emergent setting, especially in the pre-hospital setting. The authors of the study -- which compared the use of lorazepam versus diazepam for adults in SE in the pre-hospital setting -- recommended that lorazepam be restocked in ambulances every 60 days in their environment [33]. This may be a significant expense and may prove cost-prohibitive for many EMS agencies. Another potential disadvantage of lorazepam is the fact that it is available in a solution that contains benzyl alcohol, polyethylene glycol and propylene glycol. Diazepam solution also contains propylene glycol and benzyl alcohol. However, the benzyl alcohol is at a lower concentration in the diazepam solution. Benzyl alcohol has been suggested to be potentially toxic especially in newborns. The “gasping syndrome,” characterized by CNS depression metabolic acidosis, and gasping respirations, has been described in neonates and low-birth weight infants. This syndrome has been associated with high levels of benzyl alcohol and its metabolites measured in the blood and urine [42]. Other reported complications of benzyl alcohol toxicity include hepatic and renal failure, hematologic abnormalities, hypotension, and bradycardia. Propylene glycol has been associated with central nervous system toxicity, including seizures, intraventricular hemorrhage, tachycardia, tachypnea, and diaphoresis. There have been several case reports in both pediatric and adult participants of large doses of lorazepam producing a hyperosmolar state and metabolic acidosis presumably due to the propylene glycol component [42,43,44,44,45]. In other reported cases hyperosmolar acidosis and renal failure have been attributed to the polyethylene glycol 400 component of the lorazepam solution [46,47]. In a prospective study of 11 pediatric ICU participants treated with long term (3–14 days) lorazepam infusions, it was found that there was a correlation between the dose of lorazepam and serum propylene glycol concentration at the end of therapy [48]. However, the propylene glycol concentration was not associated with any significant clinical or laboratory abnormalities. Although the amount of propylene glycol, polyethylene glycol or benzyl alcohol in a therapeutic dose of lorazepam is very small and toxicity therefore rare, there is little data demonstrating at what level and in which participants these complications are more likely to occur [49].

Table 7-2, Table 7-3, Table 7-4 and Table 7-5 summarize the literature regarding efficacy and safety outcomes comparing diazepam and lorazepam and dosing information available from PK studies.

Table 7-2 Diazepam vs. Lorazepam for Status Epilepticus in Adult Patients

Authors/ Date | Patients | Methods | Lorazepam Dose | Diazepam Dose | Results: Respiratory Depression | Results: Efficacy | Comments
Leppik et al; JAMA 1983 [51] | 78 adults with SE | RCT, DB | 4 mg X 1–2 doses | 10 mg X 1–2 doses | “Adverse effects”; 13% lorazepam; 12% diazepam | Control with 1–2 doses; Lorazepam = 89%; Diazepam = 76%
Alldredge et al; NEJM 2001[33] | 205 adults with SE (> 5 min) | RCT, DB | 2 mg; repeated in 4 mins PRN | 5 mg; repeated in 4 mins PRN | “Respiratory complications” = BVM or ETI; Lorazepam =10.6%; Diazepam= 10.3%; Placebo 22.5% | Terminated on arrival to ED; Diazepam= 42.6%; Lorazepam=59.1%; OR= 1.9 (0.8–4.4) | Prehospital patients
Treiman et al; NEJM 1998 [32] | 518 adult patients (VA) with SE (overt and “subtle”) | RCT, DB | 0.1 mg/kg; max 2 mg/min | 0.15 mg/kg combined with phenytoin; maximum 5 mg/min | Endpoint = hypoventilation; Lorazepam= 10.3%; Diazepam/phenytoin=16.8%; p= NS | Endpoint = resolution within 20 minutes (clinical and EEG) without recurrence in 60 minutes; Lorazepam= 52.2%; Diazepam/phenytion= 43.1%; p= NS | Lower success rates than previous studies; but also more stringent criteria (EEG + clinical)
Cock et al; QJM 2002 [31] | 72 patients > 16 yo with SE | Retrospective review after protocol change | 4 mg | 10 mg | No difference in rate of “complications”; Only one case of respiratory depression and one case of respiratory arrest | Termination of seizures; Lorazepam= 65% (11/17); Diazepam =75% (41/55); p=NS | Fewer recurrences after lorazepam; 2/11 vs. 31/45; p=.005

Table 7-3 Diazepam vs. Lorazepam for Status Epilepticus in Pediatric Patients

Authors/ Date | Participants | Methods | Lorazepam Dose | Diazepam Dose | Results: Respiratory Depression | Results: Efficacy | Comments
Qureshi et al; Seizure 2002 [35] | 57 children in ED | Prospective review after protocol, change | 0.13 mg/kg | 0.32 mg/kg | Not discussed | Seizure control with in 5 minutes; Lorazepam = 65% (11/31); Diazepam = 65% (20/26) | Median time; Diazepam= 3 min.; Lorazepam = 5 min.
Appleton et al; Dev Med Child Neurol 1995 [36] | 61 children (1 mo-16 yrs) with SE in ED | Prospective odd even day trial | 0.05–0.1 mg/kg | 0.3–0.4 mg/kg | Respiratory depression (admission to PICU); Lorazepam = 4% (1/24); Diazepam = 21% (7/34); RR=0.21 (0.02–1.37) | Control after 1 or 2 doses; Lorazepam = 70% (19/27); Diazepam = 65% (22/34); RR=1.09 (0.77–1.54) | Data presented for IV doses only; Not blinded
Chiulli et al; J Emerg Med 1991 [38] | 38 participants < 16 yo in SE | Retrospective chart review (Cohort) | Unknown | Unknown | ETI rate; 27% (4/15) for lorazepam; 73% (8/11) for diazepam; p=.026 | Not Discussed | Retrospective, small numbers
Giang et al; Pediatric Neurol 1988 [34] | 45 children 2 weeks-18 years | Retrospective review | 0.11 mg/kg mean dose | 0.38 mg/kg mean dose | Need for mechanical ventilation; p=NS | Termination of SE; Diazepam = 69% (11/16) lorazepam = 81% 18/22; p=NS

Table 7-4 Other studies

Authors/ Date | Participants | Methods | Lorazepam Dose | Comparator Dose | Results: Respiratory Depression | Results: Efficacy | Comments
Silbergleit at el; NEJM 2012 [52] | 893 total; 149 children | RCT, DB, prehospital. Non-inferiority margin = 10%. | 4 mg IV for > 40 kg or greater, 2 mg IV for 40 kg or less | Midazolam 10 mg IM for > 40 kg or greater, 5 mg IM for 40 kg or less | 14.1% lorazepam; 14.1% midazolam | Seizure control on arrival to hospital; Lorazepam = 63.4%; Midazolam = 73.4%;; Children: 68%; lorazepam, 70% midazolam | Median time to seizure cessation (includes time needed to start IV); Lorazeapm = 6.4 min.; Midazolam = 5.5.min.

Table 7-5 Pharmacokinetic Studies

Authors/ Date | Participants | Methods | Lorazepam Dose | Diazepam Dose | Comments
Browne TR Neurol 1990 | Adults | PK | 4 mg IV | 10 mg IV | More rapid elimination diazepam
Ramsay, RE et al; Arch Neurol 1979 | Adults | PK with CSF levels | | 0.3 mg/kg IV

#### 7.3.1.3 Need for Clinical Trials and the BPCA

The fact that there are few data demonstrating the superiority of one benzodiazepine over another in the treatment of children with SE results in individual and institutional variation in the treatment of pediatric SE. While many experts prefer lorazepam for the initial treatment of SE in both adults and children for the reasons discussed above, many published protocols still advise using diazepam as the initial agent [55,56,57 ]. In a study looking at existing published guidelines for the management of childhood SE, it was noted that none used the same three initial drugs in the same order [58]. In fact the management of SE in children is based largely, if not wholly, on the management of SE in adults, including an extrapolation of the dosages of the anticonvulsant drugs. This may be inappropriate for a number of reasons, including different etiologies of seizures in children, unique airway considerations in children, the wide range of body weights in children and intravenous access issues resulting in different routes of administration in children. In addition, there may be differences in the pharmacokinetics and metabolism of the anticonvulsant drugs when treating children in SE. In fact, the sparse data that exist on the pharmacokinetics of lorazepam in neonates and children suggest that both the volume of distribution (normalized for body weight) and the mean serum half-life may differ from that found in adults [22,59,60 ]. Data are needed to determine the pharmacology of the benzodiazepines commonly used to treat SE (diazepam and lorazepam) in children, and to determine if there is a difference in the effectiveness and safety between these drugs when used to treat children with SE.

Prior studies suggest that about one third of children continue seizing after administration of benzodiazepines. This may relate to seizure induced internalization of GABA receptors which reduces benzodiazepine efficacy [3,4]. Thus, these children require treatment with additional anti-convulsant medications. Upon reaching the stage of benzodiazepine refractory SE, most published protocols list several options since there is no clear standard. These options include phenytoin, fosphenytoin, phenobarbital, and levetiracetam. If these are ineffective, generally suggesting the RSE stage, then most protocols suggest midazolam, pentobarbital, or inhaled anesthetics to induce a coma with electroencephalographic burst-suppression. However, there have not been prospective studies of these second and third line medications in pediatric SE. Data collected prospectively in this study regarding subsequent medications, dosing, and effectiveness will help guide the development of optimal treatment algorithms for children with benzodiazepine refractory SE.

Federal legislation and the regulations of the Food and Drug Administration (FDA) require that drugs be tested for safety and efficacy before they are approved for clinical use. This testing must take place in all populations in which the drug will be used. Since both the qualitative and quantitative aspects of pharmacodynamics and pharmacokinetics are different in immature individuals, and clinical efficacy and safety may not be extrapolated from older participant populations to pediatric populations, studies must be conducted in the appropriate pediatric population before pediatric use information may be appropriately incorporated in the label. The Best Pharmaceuticals for Children Act (BPCA) was enacted to enhance pediatric clinical studies leading to new pediatric labeling in accordance with FDA rules and regulations. Lorazepam as therapy for pediatric SE has been chosen by the Secretary of the Department of Health and Human Services, acting through the Director of the National Institutes of Health (NIH) and in consultation with the Commissioner of the FDA and experts in pediatric research, as a priority “off-patent” drug for which pediatric studies are most urgently needed. The FDA made a formal Written Request (WR), pursuant to Section 505A of the Federal Food, Drug, and Cosmetic Act, to obtain needed pediatric information on treatment of Status Epilepticus with lorazepam. This written request is provided in Appendix 16.1.13. The WR requested that two studies be conducted for the purpose as follows –

Study 1: Pediatric Pharmacokinetic Study. This study was to be completed prior to conducting the Pediatric Efficacy and Safety Study.

Study 2: Pediatric Efficacy and Safety Study. This study is a randomized, double blind, active-control, parallel group study in pediatric participants with generalized tonic clonic status epilepticus.

Study 1 enrolled its last participant on October 3, 2006 and the CSR for this study was submitted on February 26, 2009. These two clinical trials were designed to achieve the objective of better understanding the treatment of Status Epilepticus with lorazepam in pediatric populations.

##### Exception from Informed Consent

One of the primary challenges of performing research in the emergency setting is the inability to obtain informed consent. Frequently, parents are not available with their child. When parents or family members are present, they are too distressed by the situation to understand the study procedures and there is not enough time to get informed consent. This study presented with exactly these challenges:

- Seizures are a life-threatening emergency that requires immediate therapy;
- There is insufficient time to obtain informed consent within the therapeutic window;
- Parents may not be present;
- Even when parents are present, seizures are very distressing and trigger significant emotional distress;
- Patients with seizures are frequently transported via ambulance in an environment that is very noisy and chaotic, preventing the opportunity to present a research study in a calm, systematic manner.

In recognition of the unique circumstances pertaining to research in emergency situations, the Food and Drug Administration (FDA) has established regulations that provide a narrow exception to the requirement for informed consent from participants or their legally authorized representatives in such situations. These regulations, known as the Exception from Informed Consent (EFIC) for Emergency Research (21 CFR 50.24), are harmonized with the regulations set forth by the Department of Health and Human Services (DHHS) and known as the Waiver of Informed Consent Requirements in Certain Emergency Research (45 CFR 46.101(i)). Both sets of regulations, often referred to as the “Final Rule” represent a single common standard for this type of research and were published together in the Federal Register on October 2, 1996. [21 CFR 50.24 and 45 CFR 46 in Federal Register] [61].

The use of EFIC requires that the protocol meet the following standards:

- Study of a life threatening condition.
- Current standard of treatment is unproven or unsatisfactory.
- There is prospect of direct benefit to the participant.
- Informed consent is not possible within the therapeutic window.
- The research cannot practicably be conducted without utilizing the EFIC guidelines.

The regulations also stipulate additional processes to ensure the protection of human subjects. These include:

- Community consultation;
- Public disclosure;
- Contact of the legally authorized representative as soon as reasonably possible.

Each participating hospital submitted a site-specific plan to their IRB regarding the activities to address the requirements of the EFIC regulation.