# 6 INVESTIGATORS AND STUDY ADMINISTRATIVE STRUCTURE

## 6.1 Principal Investigators

The study was initiated at 12 sites in the United States and 2 sites in Canada. A list of investigators is provided in Appendix 16.1.4.1.

## 6.2 Administrative Structure

The following is a list of organizations that were critical to the conduct of the study:

IND SPONSOR | Eunice Kennedy Shriver National Institutes of Child Health and Human Development (NICHD); National Institutes of Health; ▬; 31 Center Drive; Bethesda, MD 20892
PODS Site | James Chamberlain, MD; PODS Site Principal Investigator; Children’s National Medical Center, Division of Emergency Medicine, 111 Michigan Ave NW, Washington DC 20010
BPCA-CC; Project Management, Data Management | Premier Research Group Limited; 1500 Market Street, ▬; Philadelphia, PA 19102
BPCA DCC as of 29 July 2009; Project Management, Data Management, Statistical Analysis, Programming, and Medical Writing | The EMMES Corporation; 401 N. Washington Street, ▬; Rockville MD 20850
Pharmacokinetic Sample Analysis | Optimized Analytical Solutions (OpAns); 4134 S. Alston Avenue, ▬; Durham, NC 27713, USA; ▬
Pharmacokineticist | ▬; University of California San Diego; 9500 Gilman Drive, ▬; La Jolla, CA 92093-0657