# 15 REFERENCE LIST

1 A proposed international classification of epileptic seizures. Epilepsia. 1964;5:297–306.14273591
2 Lowenstein DH. Status epilepticus: an overview of the clinical problem. Epilepsia. 1999; 40(suppl 1):S3–S8.
3 Theodore WH, Porter RJ, Albert P, The secondarily generalized tonic-clonic seizure: a videotape analysis. Neurology. 1994; 44:1403–1407.8058138
4 DeLorenzo RJ, Garnett LK, Towne AR, Comparison of status epilepticus with prolonged seizure episodes lasting from 10 to 29 minutes. Epilepsia. 1999; 40:164–169.9952262
5 Manno EM. New management strategies in the treatment of status epilepticus. Mayo Clinic Proceedings. 2003; 78(4);508-18.12683704
6 The Status epilepticus working party. The treatment of convulsive status epilepticus in children. Arch Dis Child 2000; 83:415–419.11040151
7 Hauser WA. Status epilepticus: Epidemiologic considerations. Neurology 1990; 40(suppl):9–13.2185441
8 Shinnar S, Berg AT, Moshe SL, The risk of seizure recurrence after a first unprovoked afebrile seizure in childhood: an extended follow-up. Pediatrics 1996; 98:216–225.8692621
9 Lacroix J, Deal C, Gauthier M, Rousseau E, Farrell CA. Admissions to a pediatric intensive care unit for status epilepticus: a 10-year experience. Crit Care Med. 1994; 22:827–32.8181292
10 Maytal J, Shinnar S, Moshe SL, Alvarez LA. Low Morbidity and Mortality of Status Epilepticus in Children. Pediatrics 1989; 83:323–331.2919138
11 Mitchell WG. Status Epilepticus and Acute Repetitive Seizures in Children, Adolescents, and Young Adults: Etiology, Outcome and Treatment. Epilepsia 1996;37(1):S74–80.8647055
12 De Negri M, Baglietto MG. Treatment of Status Epilepticus in Children. Pediatric Drugs 2001; 3(6):411–420.11437186
13 Treiman DM. The role of benzodiazepines in the management of status epilepticus. Neurology 1990; 40(5 Suppl 2):32–42.2159132
14 McDonald RE, McLean MJ. Anticonvulsant drugs: mechanisms of action. In: Delgado-Escueta AV, Ward JR AA, Woodbury DM, ; editors. Basic Mechanisms of the Epilepsies: molecular and cellular approaches. Advances in neurology. New York (NY): Raven Press, 1986; Vol 44;115–25.
15 Alldredge BK, Wall DB, Ferriero DM. Effect of prehospital treatment on the outcome of status epilepticus in children, Pediatric Neurology 1995;12:213–216.7619187
16 Dieckmann RA. Rectal diazepam for prehospital pediatric status epilepticus. Ann Emerg Med 1994; 23:216–223.8304602
17 Lacey DJ, Singer WD, Horwitz SJ, Gilmore H. Lorazepam therapy of status epilepticus in children and adolescents. J Peds 1986; 108:771–774.
18 The Status epilepticus working party. The treatment of convulsive status epilepticus in children. Arch Dis Child 2000; 83:415–419.11040151
19 Lowenstein DH, Alldredge BK, Status Epilepticus at an urban public hospital in the 1980’s, Neurology 1993; 43:483–488.8450988
20 Mitchell WG. Status Epilepticus and Acute Repetitive Seizures in Children, Adolescents, and Young Adults: Etiology, Outcome and Treatment. Epilepsia 1996; 37(1):S74–80.8647055
21 McDermott CA, Kowalczyk AL, Schnitzler ER, Mangurten HH, Rodvold KA, Metrick S. Pharmacokinetics of Lorazepam in Critically Ill neonates with seizures. Clinical and laboratory observations. J Peds. 1992; 120:479–483.
22 Reilling MV, Mulhern RK, Dodge RK, Johnson D, Pieper JA, Rivera GK, Evans WE. Lorazepam pharmacodynamics and pharmacokinetics in children. Pediatric Pharmacology and Therapeutics. 1989; 114 (4)(1):641–646.
23 Graneto JW, Strange, GR. Seizures. In: Fleisher GR, Ludwig S eds. Textbook of Pediatric Emergency Medicine (3rd ed.) Baltimore. Williams and Wilkins. 1993; 468.
24 The Harriet Lane Handbook. A Manual for Pediatric House Officers. Gunn VL, Nechyba C. eds. St Louis. Mosby. 2002.
25 The Status epilepticus working party. The treatment of convulsive status epilepticus in children. Arch Dis Child 2000; 83:415–419.11040151
26 Mitchell WG. Status epilepticus and acute repetitive seizures in children, adolescents, and young adults: etiology, outcome, and treatment. Epilepsia 1996; 37(Suppl 1):S74–80.8647055
27 Bleck TP. Management approaches to prolonged seizures and status epilepticus. Epilepsia 1999; 40 Suppl 1:S59–63.10421562
28 Sabo-Graham T, Seay AR. Management of status epilepticus in children. Peds Rev 1998; 19(9):306–9.
29 Manno EM. New management strategies in the treatment of status epilepticus. Mayo Clinic Proc 2003; 78(4):508–18.
30 Greenblatt DJ, Divoll M. Diazepam versus lorazepam: relationship of drug distribution to duration of clinical action. In: Delgado-Escueta A, Wasterlain CG, Treiman DM, Porter RJ, eds. Status epilepticus: mechanisms of brain damage and treatment. New York: Raven Press, 1983;487–491.
31 Cock HR, Schapira AHV. A comparison of lorazepam and diazepam as initial therapy in convulsive status epilepticus. QJM 2002; 95:225–231.11937649
32 Treiman DM, Meyers PD, Walton NY, A comparison of four treatments for generalized status epilepticus. N Engl J Med 1998;339:792–8.9738086
33 Alldredge BK, Gelg AM, Isaacs SM, Corry MD, Allen F, Ulrich S, Gottwald MD, O’Neil N, Neuhaus JM, Segal MR, Lowenstein DH. A comparison of lorazepam, diazepam, and placebo for the treatment of out-of-hospital status epilepticus. N Engl J Med 2001;345:631–637.11547716
34 Giang DW, McBride MC. Lorazepam versus diazepam for the treatment of status epilepticus. Pediatric Neurology. 1998; 4:358–361.
35 Qureshi A, Wassmer E, Davies R, Berry K, Whitehouse WP. Comparitive Audit of Intravenous Lorazepam and Diazepam in the Emergency Treatment of Convulsive Status Epilepticus in Children. Seizure 2002; 11:141–144.12018955
36 Appleton RE, Sweeney A, Choonara I, Robson J, Molyneux E. Lorazepam versus diazepam in the acute treatment of epileptic seizures and status epilepticus. Dev Med Child Neurol 1995; 37:682–8.7672465
37 Appleton R, Martland T, Philips B. Drug management for acute tonic clonic convulsions including convusive status epilepticus in children. The Cochrane Database of Systematic Reviews 2003; Volume 1.
38 Chiulli DA, Terndrup TE, Kanter RK. The influence of diazepam or lorazepam on the frequency of endotracheal intubation in childhood status epilepticus. J Emerg Med 1991;9:13–7.2045642
39 Orr RA, Dimand RJ, Shekhar TV, Diazepam and intubation in emergency treatment of seizures in children. Ann Emerg Med 1991; 20:107–111.1984718
40 Norris E, Marzouk O, Nunn A, Respiratory depression in children receiving diazepam for acute seizures: a prospective study. Dev Med Child Neurol 199(year?),41:340–343.
41 Stewart WA. Harrison R. Dooley JM. Respiratory depression in the acute management of seizures. Arch Dis Child. 2002; 87(3):225–6.12193434
42 Gershanik J. Boecler B. Ensley H. McCloskey S. George W. The gasping syndrome and benzyl alcohol poisoning. N Eng J Med 1982; 307(22):1384–8.
43 Arbour RB. Propylene glycol toxicity related to high-dose lorazepam infusion: case report and discussion. Am J Crit Care 1999; 8:499–506.9987548
44 Cawley MJ. Short-term lorazepam infusion and concern for propylene glycol toxicity: case report and review. Pharmacotherapy 2001; 21:1140–4.11560204
45 Reynolds HN, Teiken P, Regan ME, Hyperlactatemia, increased osmolar gap, and renal dysfunction during continuous lorazepam infusion. Crit Care Med 2000; 28:1631–4.10834725
46 Seay RE, Graves PJ, Wilkin MK. Possible toxicity from propylene glycol in lorazepam infusion. Ann Pharmacother 1997; 31:647–648.
47 Laine GA, Hamid-Hossain SM, Solis RT, : Polyethylene glycol nephrotoxicity secondary to prolonged high-dose intravenous lorazepam. Ann Pharmacother 1995; 29:1110–1114.8573954
48 Tayar J, Jabbour G, Saggi SJ. Severe hyperosmolar metabolic acidosis due to a large dose of intravenous lorazepam. N Engl J Med 2002; 346:1253–4.11961161
49 Chicella M, Jansen P, Parthiban A, Propylene glycol accumulation associated with continuous infusion of lorazepam in pediatric intensive care patients. Crit Care Med 2002; 30:2752–2756.12483068
50 Ativan injection (lorazepam) (package insert). Philadelphia, Wyeth-Ayerst Laboratories, 2002.
51 Leppik IE, Derivan AT, Homan RW, Walker J, Ramsay RE, Patrick B. Double-blind study of lorazepam and diazepam in status epilepticus. JAMA 1983;249:1452–4.6131148
52 Silbergleit R, Durkalski V, Lowenstein D at al. Intramuscular versus intravenous therapy for prehospital status epilepticus. N Engl J Med 2012;366:591–600.22335736
53 Browne TR. The pharmacokinetics of agents used to treat status epilepticus. Neurology. 1990;40(5 Suppl 2):28–32.
54 Ramsay RE, Hammond EJ, Perchalski RJ, Wilder BJ. Brain uptake of phenytoin, phenobarbital, and diazepam. Arch Neurol 1979;36:535–9.475617
55 Shorvon SD. Emergency treatment of epilepsy: acute seizures, serial seizure clusters and status epilepticus. In: Handbook of Epilepsy Treatment. 1st edn. Oxford, Blackwell Science, 2000.
56 Dodson WE, DeLorenzo RJ, Pedley TA, Shinnar S, Treiman DM, Wannamaker BB. Treatment of convulsive status epilepticus: recommendations of the epilepsy foundation of America working group on status epilepticus. JAMA 1993; 270:854–9.8340986
57 Sabo-Graham T, Seay AR. Management of status epilepticus in children. Pediatrics in Review. 1998;19(9):306–9.9745313
58 Martland T, Baxter P, Rittey C. Is there an agreed treatment for children in status epilepticus. Dev Med Child Neurol 1998; 40:286–287.9593503
59 Ativan injection (lorazepam) (package insert). Philadelphia, Wyeth-Ayerst Laboratories, 2002.
60 McDermott CA, Kowalczyk AL, Schnitzler ER, Mangurten HH, Rodvold KA, Metrick S. Pharmacokinetics of Lorazepam in Critically Ill neonates with seizures. J Peds. 1992; 120(3):479–483.
61 Food and Drug Administration. Guidance for Institutional Review Boards, Clinical Investigators, and Sponsors. Exception from Informed Consent Requirements for Emergency Research (Draft). July 2006.
62 Chamberlain JM, Capparelli EV, Brown KM, Vance CW, Lillis K, Mahajan P, Lichenstein R, Stanley RM, Davis CO, Gordon S, Baren JM, Van den Anker J for the Pediatric Emergency Care Applied Research Network. The pharmacokinetics of intravenous lorazepam in pediatric patients with and without status epilepticus. J Pediatr 2012;160:667–672 22050870