# 14 TABLES, FIGURES, AND GRAPHS REFERRED TO BUT NOT INCLUDED IN THE TEXT

## 14.1 Demographic Data

Table Number | Population | Table Title / Summary
14.1.1.1 | ITT population | Participant Accounting and Final Study Disposition by Age Stratum and Treatment Group
14.1.1.2.1 | ITT population | Participant Enrollment by Site and Age Stratum
14.1.1.2.2 | MITT population | Participant Enrollment by Site and Age Stratum
14.1.2.1 | ITT population | Protocol Deviations by Site
14.1.3.1 | ITT population | Baseline Demographics and Physical Characteristics by Age Stratum and Treatment Group
14.1.3.2 | MITT population | Baseline Demographics and Physical Characteristics by Age Stratum and Treatment Group
14.1.4 | ITT population | Summary of Diseases by Age Stratum and Treatment Group
14.1.5 | ITT population | Medical History Summary by System Organ Class, Preferred Term, Age Stratum, and Treatment Group
14.1.6.1 | ITT population | Summary of Prior Anti-Epileptic Medications by Age Stratum and Treatment Group
14.1.6.2 | ITT population | Summary of Concomitant Anti-Epileptic Medications by Age Stratum and Treatment Group
14.1.7.1 | ITT population | Concomitant Medications before Start of Study Dose by Age Stratum and Treatment Group
14.1.7.2 | ITT population | Concomitant Medications after Start of Study Dose by Age Stratum and Treatment Group
14.1.8 | ITT population | Summary of Dosing by Age Stratum and Treatment Group

## 14.2 Efficacy Data

14.2.1.1; 14.2.1.1.S | MITT population; ITT Population | Summary of Primary Efficacy Endpoint by Treatment Group
14.2.1.2; 14.2.1.2.S | PP(MITT) population; PP(ITT) Population | Summary of Primary Efficacy Endpoint by Treatment Group
14.2.2.1; 14.2.2.1.S | MITT population; ITT Population | Summary of Secondary Efficacy Endpoints by Treatment Group
14.2.2.2.A; 14.2.2.2.A.S | MITT population; ITT population | Summary of Secondary Endpoints (Time to Cessation of Initial Convulsion) by Treatment Group
14.2.2.2.B; 14.2.2.2.B.S | MITT population; ITT population | Summary of Secondary Efficacy Endpoint (Time to New Seizure Activity) by Treatment Group
14.2.2.2.C; 14.2.2.2.C.S | MITT population; ITT population | Summary of Secondary Efficacy Endpoint (Time to Return to Baseline Function) by Treatment Group
14.2.2.3; 14.2.2.3.S | MITT population; ITT population | Summary of Status Epilepticus Refractory to Benzodiazepines by Treatment Group
14.2.2.4.A; 14.2.2.4.A.S | MITT population; ITT population | Summary of Risk Factors For Status Epilepticus Refractory to Benzodiazepines
14.2.2.5; 14.2.2.5.S | MITT population; ITT population | Analysis of Dose-Response Relationship for Second-Line Medication
14.2.2.6 | MITT population | Association of Adverse Events with Second-Line Medication by Usage
14.2.2.7 | MITT Population | Summary of Medications Employed for Coma Induction by Age Stratum and Treatment Group

## 14.3 Safety Data

14.3.1.1 | Safety population | Summary of Safety Endpoints by Treatment and Age Group
14.3.1.2 | Safety population | Summary of Primary Safety Endpoint (Time to Severe or Life-Threatening Respiratory Depression) by Treatment Group
14.3.1.3 | Per Protocol Population | Summary of Safety Endpoints by Treatment and Age Group
14.3.1.4 | Per Protocol Population | Summary of Primary Safety Endpoint (Time to Severe or Life-Threatening Respiratory Depression) by Treatment Group
14.3.2 | Safety | Summary of Treatment Emergent Adverse Events by Age Stratum and Treatment Group
14.3.3.1 | Safety | Treatment Emergent Adverse Events by MedDRA System Organ Class, Preferred Term, Age Stratum and Treatment Group
14.3.3.2 | Safety | Treatment-Emergent Adverse Events by MedDRA System Organ Class, Preferred Term, Severity, Age Stratum and Treatment Group
14.3.3.3 | Safety | Treatment-Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Stratum and Treatment Group
14.3.3.4 | Safety | Serious Adverse Events by MedDRASystem Organ Class, Preferred Term, Age Stratum and Treatment Group
14.3.3.5 | Safety | Summary of Adverse Events that Led to Premature Discontinuation of Study Medication by Age Stratum and Treatment Group
14.3.4.1 | Safety | Summary of Treatment-Emergent Adverse Clinical Events by Age Stratum and Treatment Group
14.3.4.2 | Safety | Treatment-Emergent Adverse Clinical Events by MedDRA System Organ Class, Preferred Term, Age Stratum and Treatment Group
14.3.4.3 | Safety | Treatment-Emergent Adverse Clinical Events by MedDRA System Organ Class, Preferred Term, Severity, Age Stratum and Treatment Group
14.3.4.4 | Safety | Treatment-Emergent Adverse Clinical Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Stratum and Treatment Group
14.3.5.1 | Safety | Summary of Critical or Near Critical Adverse Events by Age Stratum and Treatment Group
14.3.5.2 | Safety | Critical or Near Critical Adverse Events by MedDRA System Organ Class, Preferred Term, Age Stratum and Treatment Group
14.3.5.3 | Safety | Critical or Near Critical Adverse Events by MedDRA System Organ Class, Preferred Term, Severity, Age Stratum and Treatment Group
14.3.5.4 | Safety | Critical or Near Critical Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Stratum and Treatment Group
14.3.6.1.1 to 14.3.6.1.10 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group (white blood count, Red Blood Count, hemoglobin, hematocrit, platelet count, neutrophils, lymphocytes, monocytes, Eosinophils, Basophils)
14.3.6.2.1 to 14.3.6.2.10 | Safety | Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group (white blood count, Red Blood Count, hemoglobin, hematocrit, platelet count, neutrophils, lymphocytes, monocytes, Eosinophils, Basophils)
14.3.7.1.1 – 14.3.7.1.11- | Safety | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group (Glucose, GGT, Sodium, Potassium, Chloride, Carbon dioxide, BUN, Creatinine, Calcium, ALT, AST)
14.3.7.2.1 – 14.3.7.2.11- | Safety | Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group (Glucose, GGT, Sodium, Potassium, Chloride, Carbon dioxide, BUN, Creatinine, Calcium, ALT, AST)
14.3.8.1.1 – 14.3.8.1.5 | Safety | Summary of Clinical Laboratory ABG-VBG Gases Measurement by Age Stratum and Treatment Group (pH, PCO2, PO2, SO2, HCO3)
14.3.8.2.1 – 14.3.8.2.5 | Safety | Summary of Clinical Laboratory ABG-VBG Gases Assessment by Age Stratum and Treatment Group (pH, PCO2, PO2, SO2, HCO3)
14.3.9.1.1 – 14.3.9.1.5 | Safety | Summary of Vital Signs by Visit and Treatment Group (respiration rate, pulse rate, O2 sat, SBP, DBP)
14.3.10 | Safety | Summary of ECG Results by Age Stratum and Treatment Group
14.3.11 | Safety | Summary of Riker Score by Age Stratum and Treatment Group

## 14.4 Figures

Figure Number | Population | Table Title / Summary
14.2.1; 14.2.1.S | MITT Population; ITT Population | Secondary Efficacy Endpoint: Time to Cessation of Initial Convulsion by Treatment Group
14.2.2; 14.2.2.S | MITT Population; ITT Population | Secondary Efficacy Endpoint: Time to New Seizure Activity by Treatment Group
14.2.3; 14.2.3.S | MITT Population; ITT Population | Secondary Efficacy Endpoint: Time to Return to Baseline Functioning/Mental Status by Treatment Group
14.4.2 | Safety | Primary Safety Endpoint: Kaplan-Meier Estimates of Time to severe or life-threatening respiratory depression by treatment arm
14.4.3.1 | Safety | Box Plot of Each Clinical Laboratory Hematology Measurement by Visit and Age Stratum (white blood count, red blood count, hemoglobin, hematocrit, platelet count, neutrophils, lymphocytes, monocytes, eosinophils, basophils)
14.4.3.2 | Safety | Box Plot of Each Clinical Laboratory Serum Chemistry Measurement by Visit and Age Stratum (glucose, GGT, sodium, potassium, chloride, carbon dioxide, BUN, creatinine, calcium, ALT, AST)

Table 14.1.1.1 Participant Accounting and Final Study Disposition by Age Stratum and Treatment Group All Randomized Population

| Age Strata | | | | | | Total
| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Number of Participants
Randomized | 77 (100.0%) | 71 (100.0%) | 68 (100.0%) | 63 (100.0%) | 17 (100.0%) | 14 (100.0%) | 162 (100.0%) | 148 (100.0%)
Cohort 1 (Preconsented) | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 0 | 1 (5.9%) | 0 | 4 (2.5%) | 2 (1.4%)
Cohort 2 (EFIC) ^1^ | 75 (97.4%) | 69 (97.2%) | 67 (98.5%) | 63 (100.0%) | 16 (94.1%) | 14 (100.0%) | 158 (97.5%) | 146 (98.6%)
MITT Population ^2^ | 68 (88.3%) | 60 (84.5%) | 51 (75.0%) | 57 (90.5%) | 12 (70.6%) | 10 (71.4%) | 131 (80.9%) | 127 (85.8%)
Duplicate Enrollment ^3^ | 0 | 2 | 3 | 1 | 1 | 0 | 4 | 3
Status of Randomized Participants
0–4 hr Assessment Completed | 76 (98.7%) | 69 (97.2%) | 67 (98.5%) | 58 (92.1%) | 16 (94.1%) | 13 (92.9%) | 159 (98.1%) | 140 (94.6%)
24 hr/Discharge Blood Tests Collected & Analyzed | 45 (58.4%) | 45 (63.4%) | 47 (69.1%) | 43 (68.3%) | 11 (64.7%) | 9 (64.3%) | 103 (63.6%) | 97 (65.5%)
Completed Study | 65 (84.4%) | 62 (87.3%) | 56 (82.4%) | 53 (84.1%) | 12 (70.6%) | 11 (78.6%) | 133 (82.1%) | 126 (85.1%)
Early Termination | 12 (15.6%) | 9 (12.7%) | 12 (17.6%) | 10 (15.9%) | 5 (29.4%) | 3 (21.4%) | 29 (17.9%) | 22 (14.9%)
Reasons for Early Termination
Parent/guardian withdrew consent | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Parent/guardian refused continued study participation (consent not signed) | 7 (9.1%) | 4 (5.6%) | 3 (4.4%) | 6 (9.5%) | 1 (5.9%) | 0 | 11 (6.8%) | 10 (6.8%)
Investigator judgment | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 0
Protocol non-compliance (after randomization) | 4 (5.2%) | 3 (4.2%) | 5 (7.4%) | 2 (3.2%) | 3 (17.6%) | 3 (21.4%) | 12 (7.4%) | 8 (5.4%)
Subject death | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Other | 0 | 2 (2.8%) | 3 (4.4%) | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 3 (2.0%)

Note: Ns in the column header represent number of randomized participants in each treatment group.

Denominator is the number of randomized participants in each treatment group in all sites.

1 EFIC = Exception from Informed Consent.

2 Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and without ▬ randomization errors.

3 Duplicate Enrollment are duplicates of already enrolled participants.

Table 14.1.1.2.1 Participant Enrollment by Site, Treatment and Age Group ITT population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
Site | Diazepam (N=72) | Lorazepam (N=62) | Diazepam (N=55) | Lorazepam (N=60) | Diazepam (N=13) | Lorazepam (N=11) | Diazepam (N=140) | Lorazepam (N=133)
▬ | 2 (25.0%) | 3 (37.5%) | 1 (12.5%) | 2 (25.0%) | 0 | 0 | 3 (37.5%) | 5 (62.5%)
▬ | 12 (26.7%) | 12 (26.7%) | 8 (17.8%) | 8 (17.8%) | 4 (8.9%) | 1 (2.2%) | 24 (53.3%) | 21 (46.7%)
▬ | 10 (25.0%) | 9 (22.5%) | 9 (22.5%) | 10 (25.0%) | 1 (2.5%) | 1 (2.5%) | 20 (50.0%) | 20 (50.0%)
▬ | 6 (28.6%) | 4 (19.0%) | 5 (23.8%) | 3 (14.3%) | 1 (4.8%) | 2 (9.5%) | 12 (57.1%) | 9 (42.9%)
▬ | 2 (66.7%) | 0 | 1 (33.3%) | 0 | 0 | 0 | 3 (100.0%) | 0
▬ | 8 (40.0%) | 6 (30.0%) | 2 (10.0%) | 2 (10.0%) | 1 (5.0%) | 1 (5.0%) | 11 (55.0%) | 9 (45.0%)
▬ | 1 (14.3%) | 0 | 3 (42.9%) | 2 (28.6%) | 0 | 1 (14.3%) | 4 (57.1%) | 3 (42.9%)
▬ | 9 (25.0%) | 7 (19.4%) | 7 (19.4%) | 8 (22.2%) | 3 (8.3%) | 2 (5.6%) | 19 (52.8%) | 17 (47.2%)
▬ | 3 (30.0%) | 2 (20.0%) | 1 (10.0%) | 3 (30.0%) | 0 | 1 (10.0%) | 4 (40.0%) | 6 (60.0%)
▬ | 16 (22.9%) | 16 (22.9%) | 14 (20.0%) | 20 (28.6%) | 2 (2.9%) | 2 (2.9%) | 32 (45.7%) | 38 (54.3%)
▬ | 3 (23.1%) | 3 (23.1%) | 4 (30.8%) | 2 (15.4%) | 1 (7.7%) | 0 | 8 (61.5%) | 5 (38.5%)

Note: N= Number of ITT populations.

Denominator is the total number of ITT population at the site.

Table 14.1.1.2.2 Participant Enrollment by Site, Treatment and Age Group MITT population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
Site | Diazepam (N=68) | Lorazepam (N=60) | Diazepam (N=51) | Lorazepam (N=57) | Diazepam (N=12) | Lorazepam (N=10) | Diazepam (N=131) | Lorazepam (N=127)
▬ | 2 (25.0%) | 3 (37.5%) | 1 (12.5%) | 2 (25.0%) | 0 | 0 | 3 (37.5%) | 5 (62.5%)
▬ | 12 (26.7%) | 12 (26.7%) | 8 (17.8%) | 8 (17.8%) | 4 (8.9%) | 1 (2.2%) | 24 (53.3%) | 21 (46.7%)
▬ | 10 (25.0%) | 9 (22.5%) | 9 (22.5%) | 10 (25.0%) | 1 (2.5%) | 1 (2.5%) | 20 (50.0%) | 20 (50.0%)
▬ | 2 (33.3%) | 2 (33.3%) | 1 (16.7%) | 0 | 0 | 1 (16.7%) | 3 (50.0%) | 3 (50.0%)
▬ | 2 (66.7%) | 0 | 1 (33.3%) | 0 | 0 | 0 | 3 (100.0%) | 0
▬ | 8 (40.0%) | 6 (30.0%) | 2 (10.0%) | 2 (10.0%) | 1 (5.0%) | 1 (5.0%) | 11 (55.0%) | 9 (45.0%)
▬ | 1 (14.3%) | 0 | 3 (42.9%) | 2 (28.6%) | 0 | 1 (14.3%) | 4 (57.1%) | 3 (42.9%)
▬ | 9 (25.0%) | 7 (19.4%) | 7 (19.4%) | 8 (22.2%) | 3 (8.3%) | 2 (5.6%) | 19 (52.8%) | 17 (47.2%)
▬ | 3 (30.0%) | 2 (20.0%) | 1 (10.0%) | 3 (30.0%) | 0 | 1 (10.0%) | 4 (40.0%) | 6 (60.0%)
▬ | 16 (22.9%) | 16 (22.9%) | 14 (20.0%) | 20 (28.6%) | 2 (2.9%) | 2 (2.9%) | 32 (45.7%) | 38 (54.3%)
▬ | 3 (23.1%) | 3 (23.1%) | 4 (30.8%) | 2 (15.4%) | 1 (7.7%) | 0 | 8 (61.5%) | 5 (38.5%)

Note: N= Number of MITT populations.

Denominator is the total number of MITT population at the site.

Table 14.1.2.1 Protocol Deviations by Site ITT population

| Informed Consent/Assent | | Eligibility/Enrollment | | Study Medication Administration | | Randomization | | Unblinding | | Protocol Procedure/Assessment | | Concomitant Treatment | | Unreported SAE | | Other | | Total
| Participants with PD | Total PDs | Participants with PD | Total PDs | Participants with PD | Total PDs | Participants with PD | Total PDs | Participants with PD | Total PDs | Participants with PD | Total PDs | Participants with PD | Total PDs | Participants with PD | Total PDs | Participants with PD | Total PDs | Participants with PD | Total PDs
Site | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N
▬ | 2 (25%) | 2 | 0 | 0 | 3 (37.5%) | 4 | 0 | 0 | 2 (25%) | 2 | 8 (100%) | 49 | 0 | 0 | 0 | 0 | 2 (25%) | 2 | 8 (100%) | 59
▬ | 1 (2.2%) | 1 | 6 (13.3%) | 6 | 2 (4.4%) | 3 | 6 (13.3%) | 6 | 0 | 0 | 43 (95.6%) | 189 | 1 (2.2%) | 1 | 1 (2.2%) | 1 | 1 (2.2%) | 1 | 44 (97.8%) | 208
▬ | 3 (7.5%) | 3 | 2 (5%) | 2 | 11 (27.5%) | 15 | 8 (20%) | 9 | 1 (2.5%) | 1 | 40 (100%) | 282 | 2 (5%) | 2 | 2 (5%) | 2 | 0 | 0 | 40 (100%) | 316
▬ | 2 (9.5%) | 2 | 4 (19%) | 6 | 5 (23.8%) | 10 | 7 (33.3%) | 7 | 4 (19%) | 4 | 18 (85.7%) | 117 | 0 | 0 | 0 | 0 | 0 | 0 | 21 (100%) | 146
▬ | 0 | 0 | 0 | 0 | 2 (66.7%) | 2 | 1 (33.3%) | 1 | 0 | 0 | 3 (100%) | 42 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (100%) | 45
▬ | 4 (20%) | 4 | 2 (10%) | 2 | 12 (60%) | 20 | 3 (15%) | 3 | 0 | 0 | 18 (90%) | 100 | 0 | 0 | 0 | 0 | 8 (40%) | 19 | 19 (95%) | 148
▬ | 0 | 0 | 0 | 0 | 4 (57.1%) | 4 | 1 (14.3%) | 1 | 0 | 0 | 7 (100%) | 66 | 0 | 0 | 1 (14.3%) | 1 | 4 (57.1%) | 4 | 7 (100%) | 76
▬ | 4 (11.1%) | 4 | 4 (11.1%) | 4 | 7 (19.4%) | 7 | 4 (11.1%) | 5 | 0 | 0 | 36 (100%) | 257 | 0 | 0 | 2 (5.6%) | 2 | 6 (16.7%) | 6 | 36 (100%) | 285
▬ | 5 (50%) | 8 | 0 | 0 | 3 (30%) | 4 | 3 (30%) | 3 | 1 (10%) | 1 | 10 (100%) | 66 | 0 | 0 | 1 (10%) | 1 | 0 | 0 | 10 (100%) | 83
▬ | 3 (4.3%) | 3 | 10 (14.3%) | 10 | 9 (12.9%) | 11 | 10 (14.3%) | 10 | 0 | 0 | 68 (97.1%) | 243 | 0 | 0 | 2 (2.9%) | 2 | 0 | 0 | 69 (98.6%) | 279
▬ | 0 | 0 | 3 (23.1%) | 3 | 1 (7.7%) | 1 | 0 | 0 | 0 | 0 | 13 (100%) | 120 | 1 (7.7%) | 1 | 0 | 0 | 0 | 0 | 13 (100%) | 125
▬ | 24 (8.8%) | 27 | 31 (11.4%) | 33 | 59 (21.6%) | 81 | 43 (15.8%) | 45 | 8 (2.9%) | 8 | 264 (96.7%) | 1531 | 4 (1.5%) | 4 | 9 (3.3%) | 9 | 21 (7.7%) | 32 | 270 (98.9%) | 1770

Table 14.1.3.1 Baseline Demographics and Physical Characteristics by Age Stratuma and Treatment Group ITT population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=72) | Lorazepam (N=62) | Diazepam (N=55) | Lorazepam (N=60) | Diazepam (N=13) | Lorazepam (N=11) | Diazepam (N=140) | Lorazepam (N=133)
Age at Baseline (years)
N | 72 | 62 | 55 | 60 | 13 | 11 | 140 | 133
Mean (SD) | 1.4 (0.6) | 1.4 (0.8) | 6.1 (2.6) | 6.2 (2.5) | 16.6 (4.1) | 16.1 (1.3) | 4.7 (4.9) | 4.8 (4.5)
Median (Min-Max) | 1.3 (0.3 – 2.9) | 1.3 (0.3 – 2.9) | 5.2 (3.0 – 11.7) | 5.8 (3.0 – 12.0) | 15.5 (13.1 – 28.0) | 16.1 (13.2 – 17.8) | 2.8 (0.3 – 28.0) | 3.3 (0.3 – 17.8)
Height at Baseline (cm)
N | 68 | 60 | 47 | 54 | 12 | 9 | 127 | 123
Mean (SD) | 78.0 (9.9) | 78.6 (10.4) | 109.2 (19.7) | 113.9 (19.0) | 157.7 (12.4) | 158.9 (13.5) | 97.1 (28.4) | 100.0 (28.1)
Median (Min-Max) | 78.0 (41.0 – 103.0) | 78.3 (54.0 – 101.0) | 104.0 (79.0 – 174.0) | 115.0 (72.0 – 157.5) | 158.0 (134.0 – 179.0) | 159.0 (139.7 – 179.0) | 89.0 (41.0 – 179.0) | 92.0 (54.0 – 179.0)
Height Percentile at Baseline
N | 68 | 60 | 47 | 54 | 12 | 9 | 127 | 123
Mean (SD) | 43.8 (33.8) | 41.9 (36.5) | 33.2 (37.5) | 41.6 (33.9) | 28.7 (34.1) | 30.3 (35.3) | 38.4 (35.5) | 40.9 (35.2)
Median (Min-Max) | 39.8 (0.0 – 100.0) | 33.4 (0.0 – 100.0) | 12.0 (0.0 – 100.0) | 33.8 (0.0 – 99.9) | 3.1 (0.1 – 81.2) | 19.1 (0.0 – 98.1) | 31.9 (0.0 – 100.0) | 32.9 (0.0 – 100.0)
Weight at Baseline (kg)
N | 58 | 54 | 48 | 52 | 11 | 5 | 117 | 111
Mean (SD) | 10.3 (2.4) | 10.3 (2.9) | 24.4 (14.8) | 22.6 (10.7) | 49.5 (15.4) | 46.1 (7.1) | 19.8 (15.8) | 17.7 (11.6)
Median (Min-Max) | 10.0 (5.7 – 16.0) | 10.0 (5.2 – 19.7) | 18.4 (10.0 – 88.9) | 20.0 (7.2 – 55.0) | 50.0 (28.0 – 76.9) | 45.4 (39.0 – 56.0) | 13.2 (5.7 – 88.9) | 13.0 (5.2 – 56.0)
Weight Percentile at Baseline
N | 58 | 54 | 48 | 52 | 11 | 5 | 117 | 111
Mean (SD) | 35.9 (31.9) | 35.1 (29.8) | 50.2 (35.2) | 46.9 (35.2) | 34.4 (36.9) | 12.3 (13.3) | 41.6 (34.2) | 39.6 (32.8)
Median (Min-Max) | 30.5 (0.0 – 99.9) | 30.8 (0.0 – 100.0) | 52.5 (0.0 – 99.8) | 48.0 (0.0 – 99.9) | 15.1 (0.0 – 92.7) | 11.3 (0.0 – 32.2) | 36.5 (0.0 – 99.9) | 34.1 (0.0 – 100.0)
BMI at Baseline (kg/m^2^)
N | 10 | 13 | 42 | 48 | 11 | 3 | 63 | 64
Mean (SD) | 15.9 (1.9) | 15.9 (2.2) | 17.7 (4.6) | 16.9 (3.5) | 19.8 (4.2) | 15.4 (1.3) | 17.8 (4.3) | 16.7 (3.2)
Median (Min-Max) | 15.7 (12.9 – 18.5) | 16.1 (12.8 – 19.3) | 16.6 (10.7 – 33.9) | 16.1 (9.8 – 30.3) | 20.7 (13.8 – 25.4) | 14.7 (14.7 – 16.9) | 16.8 (10.7 – 33.9) | 16.1 (9.8 – 30.3)
BMI Percentile at Baseline
N | 10 | 13 | 42 | 48 | 11 | 3 | 63 | 64
Mean (SD) | 42.7 (38.2) | 46.7 (42.3) | 62.5 (34.7) | 55.9 (35.1) | 47.3 (38.9) | 0.5 (0.8) | 56.7 (36.4) | 51.4 (37.4)
Median (Min-Max) | 33.8 (0.1 – 96.1) | 52.6 (0.0 – 97.2) | 71.9 (0.0 – 100.0) | 66.3 (0.0 – 99.8) | 64.7 (0.0 – 93.3) | 0.1 (0.0 – 1.5) | 64.7 (0.0 – 100.0) | 52.4 (0.0 – 99.8)
BMI Category at Baseline ^1^
Missing | 3 (4.2%) | 2 (3.2%) | 13 (23.6%) | 12 (20.0%) | 2 (15.4%) | 8 (72.7%) | 18 (12.9%) | 22 (16.5%)
Infant | 59 (81.9%) | 47 (75.8%) | 0 | 0 | 0 | 0 | 59 (42.1%) | 47 (35.3%)
Underweight | 1 (1.4%) | 4 (6.5%) | 5 (9.1%) | 8 (13.3%) | 4 (30.8%) | 3 (27.3%) | 10 (7.1%) | 15 (11.3%)
Healthy Weight | 7 (9.7%) | 4 (6.5%) | 18 (32.7%) | 26 (43.3%) | 5 (38.5%) | 0 | 30 (21.4%) | 30 (22.6%)
Overweight | 1 (1.4%) | 3 (4.8%) | 11 (20.0%) | 8 (13.3%) | 2 (15.4%) | 0 | 14 (10.0%) | 11 (8.3%)
Obese | 1 (1.4%) | 2 (3.2%) | 8 (14.5%) | 6 (10.0%) | 0 | 0 | 9 (6.4%) | 8 (6.0%)
Gender
Male | 39 (54.2%) | 30 (48.4%) | 27 (49.1%) | 29 (48.3%) | 9 (69.2%) | 4 (36.4%) | 75 (53.6%) | 63 (47.4%)
Female | 33 (45.8%) | 32 (51.6%) | 28 (50.9%) | 31 (51.7%) | 4 (30.8%) | 7 (63.6%) | 65 (46.4%) | 70 (52.6%)
Ethnicity
Hispanic or Latino | 26 (36.1%) | 17 (27.4%) | 17 (30.9%) | 19 (31.7%) | 2 (15.4%) | 2 (18.2%) | 45 (32.1%) | 38 (28.6%)
Not Hispanic or Latino | 44 (61.1%) | 44 (71.0%) | 37 (67.3%) | 40 (66.7%) | 9 (69.2%) | 8 (72.7%) | 90 (64.3%) | 92 (69.2%)
Not reported | 2 (2.8%) | 1 (1.6%) | 1 (1.8%) | 1 (1.7%) | 2 (15.4%) | 1 (9.1%) | 5 (3.6%) | 3 (2.3%)
Race
American Indian or Alaska Native | 0 | 0 | 0 | 1 (1.7%) | 1 (7.7%) | 0 | 1 (0.7%) | 1 (0.8%)
Asian | 3 (4.2%) | 1 (1.6%) | 1 (1.8%) | 2 (3.3%) | 0 | 0 | 4 (2.9%) | 3 (2.3%)
Black or African American | 25 (34.7%) | 23 (37.1%) | 18 (32.7%) | 23 (38.3%) | 4 (30.8%) | 6 (54.5%) | 47 (33.6%) | 52 (39.1%)
Native Hawaiian or Pacific Islander | 1 (1.4%) | 0 | 1 (1.8%) | 0 | 0 | 0 | 2 (1.4%) | 0
White or Caucasian | 34 (47.2%) | 26 (41.9%) | 29 (52.7%) | 31 (51.7%) | 7 (53.8%) | 4 (36.4%) | 70 (50.0%) | 61 (45.9%)
More Than 1 Race | 5 (6.9%) | 8 (12.9%) | 3 (5.5%) | 2 (3.3%) | 0 | 0 | 8 (5.7%) | 10 (7.5%)
Other | 4 (5.6%) | 2 (3.2%) | 2 (3.6%) | 1 (1.7%) | 1 (7.7%) | 0 | 7 (5.0%) | 3 (2.3%)
Not reported | 0 | 2 (3.2%) | 1 (1.8%) | 0 | 0 | 1 (9.1%) | 1 (0.7%) | 3 (2.3%)

Note: BMI categories- underweight is <5th percentile, healthy weight is between 5th and 85th percentile, overweight is between 85th and 95th percentile and obese is >95th percentile.

BMI is not evaluated in children <2 years of age.

Table 14.1.3.2 Baseline Demographics and Physical Characteristics by Age Stratuma and Treatment Group MITT population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=68) | Lorazepam (N=60) | Diazepam (N=51) | Lorazepam (N=57) | Diazepam (N=12) | Lorazepam (N=10) | Diazepam (N=131) | Lorazepam (N=127)
Age at Baseline (years)
N | 68 | 60 | 51 | 57 | 12 | 10 | 131 | 127
Mean (SD) | 1.4 (0.6) | 1.4 (0.7) | 6.1 (2.6) | 6.3 (2.6) | 15.6 (2.3) | 16.1 (1.4) | 4.5 (4.5) | 4.8 (4.5)
Median (Min-Max) | 1.3 (0.3 – 2.9) | 1.3 (0.3 – 2.9) | 5.0 (3.0 – 11.7) | 5.8 (3.0 – 12.0) | 15.2 (13.1 – 20.1) | 16.2 (13.2 – 17.8) | 2.8 (0.3 – 20.1) | 3.3 (0.3 – 17.8)
Height at Baseline (cm)
N | 66 | 58 | 44 | 52 | 12 | 9 | 122 | 119
Mean (SD) | 77.9 (10.0) | 78.6 (10.6) | 108.8 (20.2) | 114.4 (19.2) | 157.7 (12.4) | 158.9 (13.5) | 96.9 (28.8) | 100.3 (28.4)
Median (Min-Max) | 77.6 (41.0 – 103.0) | 78.3 (54.0 – 101.0) | 102.5 (79.0 – 174.0) | 115.3 (72.0 – 157.5) | 158.0 (134.0 – 179.0) | 159.0 (139.7 – 179.0) | 88.5 (41.0 – 179.0) | 92.0 (54.0 – 179.0)
Height Percentile at Baseline
N | 66 | 58 | 44 | 52 | 12 | 9 | 122 | 119
Mean (SD) | 43.3 (33.5) | 41.8 (36.2) | 31.8 (36.8) | 41.2 (34.0) | 28.7 (34.1) | 30.3 (35.3) | 37.7 (35.1) | 40.6 (35.0)
Median (Min-Max) | 39.8 (0.0 – 99.8) | 33.4 (0.0 – 100.0) | 11.2 (0.0 – 100.0) | 33.8 (0.0 – 99.9) | 3.1 (0.1 – 81.2) | 19.1 (0.0 – 98.1) | 31.9 (0.0 – 100.0) | 32.9 (0.0 – 100.0)
Weight at Baseline (kg)
N | 54 | 52 | 45 | 49 | 11 | 4 | 110 | 105
Mean (SD) | 10.2 (2.3) | 10.3 (3.0) | 24.0 (14.8) | 22.7 (10.9) | 49.5 (15.4) | 45.1 (7.8) | 19.8 (16.0) | 17.4 (11.4)
Median (Min-Max) | 10.0 (5.7 – 16.0) | 10.0 (5.2 – 19.7) | 18.0 (10.0 – 88.9) | 20.0 (7.2 – 55.0) | 50.0 (28.0 – 76.9) | 42.7 (39.0 – 56.0) | 13.1 (5.7 – 88.9) | 13.0 (5.2 – 56.0)
Weight Percentile at Baseline
N | 54 | 52 | 45 | 49 | 11 | 4 | 110 | 105
Mean (SD) | 32.8 (30.3) | 34.6 (29.7) | 49.1 (34.4) | 46.4 (35.2) | 34.4 (36.9) | 7.4 (8.5) | 39.6 (33.3) | 39.1 (32.8)
Median (Min-Max) | 21.7 (0.0 – 99.9) | 30.8 (0.0 – 100.0) | 49.1 (0.0 – 99.8) | 46.4 (0.0 – 99.9) | 15.1 (0.0 – 92.7) | 6.0 (0.0 – 17.5) | 34.1 (0.0 – 99.9) | 34.1 (0.0 – 100.0)
BMI at Baseline (kg/m^2^)
N | 10 | 12 | 40 | 46 | 11 | 3 | 61 | 61
Mean (SD) | 15.9 (1.9) | 15.7 (2.1) | 17.8 (4.7) | 16.8 (3.5) | 19.8 (4.2) | 15.4 (1.3) | 17.8 (4.4) | 16.5 (3.2)
Median (Min-Max) | 15.7 (12.9 – 18.5) | 15.6 (12.8 – 19.3) | 16.9 (10.7 – 33.9) | 16.1 (9.8 – 30.3) | 20.7 (13.8 – 25.4) | 14.7 (14.7 – 16.9) | 17.0 (10.7 – 33.9) | 16.1 (9.8 – 30.3)
BMI Percentile at Baseline
N | 10 | 12 | 40 | 46 | 11 | 3 | 61 | 61
Mean (SD) | 42.7 (38.2) | 42.6 (41.4) | 63.4 (34.8) | 54.6 (35.1) | 47.3 (38.9) | 0.5 (0.8) | 57.1 (36.6) | 49.6 (37.3)
Median (Min-Max) | 33.8 (0.1 – 96.1) | 32.9 (0.0 – 97.2) | 72.0 (0.0 – 100.0) | 58.4 (0.0 – 99.8) | 64.7 (0.0 – 93.3) | 0.1 (0.0 – 1.5) | 64.7 (0.0 – 100.0) | 52.0 (0.0 – 99.8)
BMI Category at Baseline ^1^
Missing | 3 (4.4%) | 2 (3.3%) | 11 (21.6%) | 11 (19.3%) | 1 (8.3%) | 7 (70.0%) | 15 (11.5%) | 20 (15.7%)
Infant | 55 (80.9%) | 46 (76.7%) | 0 | 0 | 0 | 0 | 55 (42.0%) | 46 (36.2%)
Underweight | 1 (1.5%) | 4 (6.7%) | 5 (9.8%) | 8 (14.0%) | 4 (33.3%) | 3 (30.0%) | 10 (7.6%) | 15 (11.8%)
Healthy Weight | 7 (10.3%) | 4 (6.7%) | 16 (31.4%) | 25 (43.9%) | 5 (41.7%) | 0 | 28 (21.4%) | 29 (22.8%)
Overweight | 1 (1.5%) | 3 (5.0%) | 11 (21.6%) | 8 (14.0%) | 2 (16.7%) | 0 | 14 (10.7%) | 11 (8.7%)
Obese | 1 (1.5%) | 1 (1.7%) | 8 (15.7%) | 5 (8.8%) | 0 | 0 | 9 (6.9%) | 6 (4.7%)
Gender
Male | 36 (52.9%) | 28 (46.7%) | 23 (45.1%) | 28 (49.1%) | 8 (66.7%) | 4 (40.0%) | 67 (51.1%) | 60 (47.2%)
Female | 32 (47.1%) | 32 (53.3%) | 28 (54.9%) | 29 (50.9%) | 4 (33.3%) | 6 (60.0%) | 64 (48.9%) | 67 (52.8%)
Ethnicity
Hispanic or Latino | 25 (36.8%) | 16 (26.7%) | 16 (31.4%) | 18 (31.6%) | 2 (16.7%) | 2 (20.0%) | 43 (32.8%) | 36 (28.3%)
Not Hispanic or Latino | 42 (61.8%) | 44 (73.3%) | 35 (68.6%) | 38 (66.7%) | 9 (75.0%) | 8 (80.0%) | 86 (65.6%) | 90 (70.9%)
Not reported | 1 (1.5%) | 0 | 0 | 1 (1.8%) | 1 (8.3%) | 0 | 2 (1.5%) | 1 (0.8%)
Race
American Indian or Alaska Native | 0 | 0 | 0 | 1 (1.8%) | 1 (8.3%) | 0 | 1 (0.8%) | 1 (0.8%)
Asian | 3 (4.4%) | 1 (1.7%) | 1 (2.0%) | 2 (3.5%) | 0 | 0 | 4 (3.1%) | 3 (2.4%)
Black or African American | 22 (32.4%) | 22 (36.7%) | 17 (33.3%) | 22 (38.6%) | 3 (25.0%) | 5 (50.0%) | 42 (32.1%) | 49 (38.6%)
Native Hawaiian or Pacific Islander | 1 (1.5%) | 0 | 1 (2.0%) | 0 | 0 | 0 | 2 (1.5%) | 0
White or Caucasian | 34 (50.0%) | 26 (43.3%) | 29 (56.9%) | 30 (52.6%) | 7 (58.3%) | 4 (40.0%) | 70 (53.4%) | 60 (47.2%)
More Than 1 Race | 5 (7.4%) | 8 (13.3%) | 2 (3.9%) | 1 (1.8%) | 0 | 0 | 7 (5.3%) | 9 (7.1%)
Other | 3 (4.4%) | 1 (1.7%) | 1 (2.0%) | 1 (1.8%) | 1 (8.3%) | 0 | 5 (3.8%) | 2 (1.6%)
Not reported | 0 | 2 (3.3%) | 0 | 0 | 0 | 1 (10.0%) | 0 | 3 (2.4%)

Note: BMI categories- underweight is <5th percentile, healthy weight is between 5th and 85th percentile, overweight is between 85th and 95th percentile and obese is >95th percentile.

BMI is not evaluated in children <2 years of age.

Table 14.1.4 Summary of Diseases by Age Stratum and Treatment Group ITT population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=72) | Lorazepam (N=62) | Diazepam (N=55) | Lorazepam (N=60) | Diazepam (N=13) | Lorazepam (N=11) | Diazepam (N=140) | Lorazepam (N=133)
Duration of Seizures <1 minute Prior to Treatment
Yes | 15 (20.8%) | 7 (11.3%) | 14 (25.5%) | 5 (8.3%) | 1 (7.7%) | 4 (36.4%) | 30 (21.4%) | 16 (12.0%)
No | 57 (79.2%) | 54 (87.1%) | 41 (74.5%) | 54 (90.0%) | 11 (84.6%) | 7 (63.6%) | 109 (77.9%) | 115 (86.5%)
N/A | 0 | 1 (1.6%) | 0 | 1 (1.7%) | 1 (7.7%) | 0 | 1 (0.7%) | 2 (1.5%)
Primary Seizures Etiology
Febrile | 36 (50.0%) | 32 (51.6%) | 13 (23.6%) | 8 (13.3%) | 0 | 0 | 49 (35.0%) | 40 (30.1%)
Remote Symptomatic | 5 (6.9%) | 6 (9.7%) | 7 (12.7%) | 6 (10.0%) | 1 (7.7%) | 2 (18.2%) | 13 (9.3%) | 14 (10.5%)
Acute Symptomatic | 13 (18.1%) | 7 (11.3%) | 8 (14.5%) | 8 (13.3%) | 2 (15.4%) | 0 | 23 (16.4%) | 15 (11.3%)
Idiopathic | 14 (19.4%) | 13 (21.0%) | 15 (27.3%) | 24 (40.0%) | 8 (61.5%) | 7 (63.6%) | 37 (26.4%) | 44 (33.1%)
Low Levels of Anti-Epileptic Drug | 2 (2.8%) | 4 (6.5%) | 8 (14.5%) | 9 (15.0%) | 2 (15.4%) | 0 | 12 (8.6%) | 13 (9.8%)
Other | 2 (2.8%) | 0 | 4 (7.3%) | 5 (8.3%) | 0 | 2 (18.2%) | 6 (4.3%) | 7 (5.3%)

Table 14.1.5 Summary of Medical History by System Organ Class, Preferred Term, Age Stratum and Treatment Group ITT population

| Age Strata | | | | | | | | | | | | Total
| 3 mo – <3 yrs Diazepam (N=72) | | 3 mo – <3 yrs Lorazepam (N=62) | | 3 yrs – <13 yrs Diazepam (N=55) | | 3 yrs – <13 yrs Lorazepam (N=60) | | ≥13 yrs Diazepam (N=13) | | ≥13 yrs Lorazepam (N=11) | | Diazepam (N=140) | | Lorazepam (N=133)
System Organ Class | Pts With MH | Total MH | Pts With MH | Total MH | Pts With MH | Total MH | Pts With MH | Total MH | Pts With MH | Total MH | Pts With MH | Total MH | Pts With MH | Total MH | Pts With MH | Total MH
Preferred Term | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N
Blood and lymphatic system disorders | 4 (5.6%) | 6 | 3 (4.8%) | 3 | 1 (1.8%) | 1 | 3 (5%) | 3 | 3 (23.1%) | 3 | 0 | 0 | 8 (5.7%) | 10 | 6 (4.5%) | 6
Anaemia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Anaemia neonatal | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Blood disorder | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Coagulopathy | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Eosinophilia | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Haemoglobinaemia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Iron deficiency anaemia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Leukocytosis | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Placental transfusion syndrome | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Polycythaemia | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Thrombocytopenia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (15.4%) | 2 | 0 | 0 | 3 (2.1%) | 3 | 0 | 0
Cardiac disorders | 14 (19.4%) | 15 | 5 (8.1%) | 6 | 7 (12.7%) | 8 | 5 (8.3%) | 5 | 5 (38.5%) | 5 | 2 (18.2%) | 2 | 26 (18.6%) | 28 | 12 (9%) | 13
Bradycardia | 2 (2.8%) | 2 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 0 | 0
Cardiac arrest | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Cardiac disorder | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Cardiac failure chronic | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cyanosis | 0 | 0 | 1 (1.6%) | 1 | 3 (5.5%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 1 (0.8%) | 1
Dyspnoea | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Foetal heart rate deceleration | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Long QT syndrome | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Sinus tachycardia | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Tachycardia | 11 (15.3%) | 11 | 5 (8.1%) | 5 | 4 (7.3%) | 4 | 1 (1.7%) | 1 | 3 (23.1%) | 3 | 1 (9.1%) | 1 | 18 (12.9%) | 18 | 7 (5.3%) | 7
Tricuspid valve disease | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Congenital, familial and genetic disorders | 18 (25%) | 30 | 15 (24.2%) | 29 | 23 (41.8%) | 36 | 23 (38.3%) | 36 | 2 (15.4%) | 4 | 2 (18.2%) | 2 | 43 (30.7%) | 70 | 40 (30.1%) | 67
Anterior chamber cleavage syndrome | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Arnold-Chiari malformation | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
Arteriovenous malformation | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Atrial septal defect | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Atrioventricular septal defect | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Biotinidase deficiency | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Brain malformation | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cerebellar hypoplasia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cerebral dysgenesis | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.3%) | 3
Cerebral palsy | 3 (4.2%) | 3 | 4 (6.5%) | 4 | 10 (18.2%) | 10 | 9 (15%) | 9 | 0 | 0 | 1 (9.1%) | 1 | 13 (9.3%) | 13 | 14 (10.5%) | 14
Choanal atresia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cleft lip and palate | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Congenital HIV infection | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Congenital anomaly | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Congenital central nervous system anomaly | 2 (2.8%) | 2 | 0 | 0 | 0 | 0 | 3 (5%) | 3 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 3 (2.3%) | 3
Congenital cystic kidney disease | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Congenital hydrocephalus | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Congenital multiplex arthrogryposis | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Congenital naevus | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Congenital neurological disorder | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 2 (1.5%) | 2
Congenital oculomotor apraxia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cortical dysplasia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Cryptorchism | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Cytogenetic abnormality | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Dysmorphism | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Ear malformation | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Factor V Leiden mutation | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Heart disease congenital | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Heterotaxia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
High arched palate | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Hip dysplasia | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Hydrocele | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypoplastic left heart syndrome | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypospadias | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Laryngomalacia | 1 (1.4%) | 1 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 4 (3%) | 4
Macrocephaly | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Meningomyelocele | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 3
Microcephaly | 3 (4.2%) | 3 | 3 (4.8%) | 3 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 1 (9.1%) | 1 | 4 (2.9%) | 4 | 6 (4.5%) | 6
Microencephaly | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Microgenia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Micrognathia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Micropenis | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Naevus flammeus | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Niemann-Pick disease | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Nonketotic hyperglycinaemia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Optic nerve hypoplasia | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Patent ductus arteriosus | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Periventricular nodular heterotopia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Pierre Robin syndrome | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Plagiocephaly | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Progressive cerebellar degeneration | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Septo-optic dysplasia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Septum pellucidum agenesis | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Sickle cell trait | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Spina bifida | 2 (2.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 3 | 0 | 0
Sturge-Weber syndrome | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Talipes | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Tibial torsion | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Trisomy 22 | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Ventricular septal defect | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Wolf-Hirschhorn syndrome | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Ear and labyrinth disorders | 5 (6.9%) | 5 | 1 (1.6%) | 1 | 2 (3.6%) | 2 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 7 (5%) | 7 | 3 (2.3%) | 3
Deafness | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Deafness bilateral | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Ear pain | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypoacusis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Middle ear effusion | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Tympanic membrane disorder | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Tympanic membrane hyperaemia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Tympanic membrane perforation | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Endocrine disorders | 2 (2.8%) | 5 | 0 | 0 | 1 (1.8%) | 2 | 1 (1.7%) | 2 | 0 | 0 | 0 | 0 | 3 (2.1%) | 7 | 1 (0.8%) | 2
Adrenal insufficiency | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Diabetes insipidus | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Growth hormone deficiency | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypopituitarism | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypothyroidism | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Precocious puberty | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Eye disorders | 8 (11.1%) | 10 | 8 (12.9%) | 10 | 13 (23.6%) | 16 | 14 (23.3%) | 16 | 1 (7.7%) | 1 | 2 (18.2%) | 2 | 22 (15.7%) | 27 | 24 (18%) | 28
Blindness | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 3 (5%) | 3 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 4 (3%) | 4
Blindness cortical | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 3 | 1 (0.8%) | 1
Conjunctivitis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 2 (1.5%) | 2
Ectropion | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Eye disorder | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Eye movement disorder | 1 (1.4%) | 1 | 2 (3.2%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Gaze palsy | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Glaucoma | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Heterophoria | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Miosis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Myopia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Retinopathy of prematurity | 2 (2.8%) | 2 | 1 (1.6%) | 1 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 4 (2.9%) | 4 | 2 (1.5%) | 2
Scleral discolouration | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Strabismus | 2 (2.8%) | 2 | 2 (3.2%) | 2 | 6 (10.9%) | 7 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 8 (5.7%) | 9 | 3 (2.3%) | 3
Vision blurred | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Visual acuity reduced | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Visual impairment | 2 (2.8%) | 2 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 2 (1.5%) | 2
Gastrointestinal disorders | 27 (37.5%) | 41 | 31 (50%) | 47 | 20 (36.4%) | 30 | 22 (36.7%) | 38 | 8 (61.5%) | 9 | 5 (45.5%) | 6 | 55 (39.3%) | 80 | 58 (43.6%) | 91
Abdominal discomfort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Abdominal distension | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Abdominal hernia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Abdominal pain | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 1 (9.1%) | 1 | 1 (0.7%) | 1 | 3 (2.3%) | 3
Congenital large intestinal atresia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Constipation | 0 | 0 | 3 (4.8%) | 3 | 4 (7.3%) | 4 | 6 (10%) | 6 | 1 (7.7%) | 1 | 0 | 0 | 5 (3.6%) | 5 | 9 (6.8%) | 9
Cyclic vomiting syndrome | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Dental caries | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Diarrhoea | 10 (13.9%) | 10 | 9 (14.5%) | 9 | 2 (3.6%) | 2 | 2 (3.3%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 13 (9.3%) | 13 | 11 (8.3%) | 11
Dysphagia | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 3 (2.3%) | 3
Faecal incontinence | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Gastric ulcer | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Gastrooesophageal reflux disease | 5 (6.9%) | 5 | 5 (8.1%) | 5 | 6 (10.9%) | 6 | 4 (6.7%) | 4 | 2 (15.4%) | 2 | 0 | 0 | 13 (9.3%) | 13 | 9 (6.8%) | 9
Haematemesis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Haematochezia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Hiatus hernia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Inguinal hernia | 2 (2.8%) | 2 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 1 (0.8%) | 1
Intestinal obstruction | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Intussusception | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Malabsorption | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Nausea | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 2 (18.2%) | 2 | 2 (1.4%) | 2 | 3 (2.3%) | 3
Necrotising colitis | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 1 (9.1%) | 1 | 2 (1.4%) | 2 | 2 (1.5%) | 2
Necrotising enterocolitis neonatal | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Poor dental condition | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Reflux gastritis | 3 (4.2%) | 3 | 3 (4.8%) | 3 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 4 (2.9%) | 4 | 4 (3%) | 4
Retching | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Short-bowel syndrome | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Teething | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Toothache | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Umbilical hernia | 0 | 0 | 3 (4.8%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.3%) | 3
Vomiting | 15 (20.8%) | 15 | 19 (30.6%) | 19 | 10 (18.2%) | 10 | 11 (18.3%) | 11 | 1 (7.7%) | 1 | 2 (18.2%) | 2 | 26 (18.6%) | 26 | 32 (24.1%) | 32
General disorders and administration site conditions | 36 (50%) | 40 | 33 (53.2%) | 42 | 40 (72.7%) | 54 | 34 (56.7%) | 44 | 7 (53.8%) | 10 | 5 (45.5%) | 7 | 83 (59.3%) | 104 | 72 (54.1%) | 93
Adhesion | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Adverse drug reaction | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Atrophy | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Chest pain | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Denervation atrophy | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Developmental delay | 15 (20.8%) | 15 | 17 (27.4%) | 17 | 28 (50.9%) | 29 | 22 (36.7%) | 22 | 5 (38.5%) | 5 | 5 (45.5%) | 5 | 48 (34.3%) | 49 | 44 (33.1%) | 44
Device malfunction | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Discomfort | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Excessive granulation tissue | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Fatigue | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Granuloma | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Hernia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hyperplasia | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypothermia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Irritability | 0 | 0 | 4 (6.5%) | 4 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 5 (3.8%) | 5
Pain | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Pseudocyst | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Pyrexia | 23 (31.9%) | 23 | 21 (33.9%) | 21 | 14 (25.5%) | 16 | 14 (23.3%) | 15 | 2 (15.4%) | 2 | 1 (9.1%) | 1 | 39 (27.9%) | 41 | 36 (27.1%) | 37
Temperature regulation disorder | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Hepatobiliary disorders | 2 (2.8%) | 2 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
Hyperbilirubinaemia | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Jaundice | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Immune system disorders | 2 (2.8%) | 2 | 1 (1.6%) | 2 | 6 (10.9%) | 6 | 2 (3.3%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 9 (6.4%) | 9 | 3 (2.3%) | 4
Drug hypersensitivity | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Food allergy | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Hypersensitivity | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Milk allergy | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Rubber sensitivity | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 3 | 1 (0.8%) | 1
Seasonal allergy | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Infections and infestations | 33 (45.8%) | 45 | 24 (38.7%) | 39 | 23 (41.8%) | 50 | 20 (33.3%) | 31 | 4 (30.8%) | 5 | 3 (27.3%) | 4 | 60 (42.9%) | 100 | 47 (35.3%) | 74
Adenovirus infection | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Brain abscess | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Bronchiolitis | 3 (4.2%) | 3 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 4 (2.9%) | 4 | 1 (0.8%) | 1
Bronchitis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Chronic sinusitis | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Conjunctivitis bacterial | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Conjunctivitis infective | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Croup infectious | 1 (1.4%) | 1 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 0 | 0
Cytomegalovirus infection | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Ear infection | 1 (1.4%) | 1 | 3 (4.8%) | 3 | 0 | 0 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 4 (3%) | 4
Encephalitis herpes | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Extradural abscess | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Gastroenteritis | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 2 | 2 (3.3%) | 2 | 0 | 0 | 1 (9.1%) | 1 | 2 (1.4%) | 3 | 3 (2.3%) | 3
Gastroenteritis viral | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Gastrointestinal infection | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
H1N1 influenza | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Herpes virus infection | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Herpes zoster | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Infection | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Influenza | 1 (1.4%) | 2 | 2 (3.2%) | 2 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 4 | 3 (2.3%) | 3
Meningitis | 1 (1.4%) | 2 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 3 | 1 (0.8%) | 1
Meningitis neonatal | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Minor cognitive motor disorder | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Nasopharyngitis | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Osteomyelitis | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Otitis media | 5 (6.9%) | 5 | 4 (6.5%) | 4 | 5 (9.1%) | 5 | 6 (10%) | 7 | 0 | 0 | 0 | 0 | 10 (7.1%) | 10 | 10 (7.5%) | 11
Otitis media acute | 3 (4.2%) | 3 | 2 (3.2%) | 2 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 5 (3.6%) | 5 | 2 (1.5%) | 2
Otitis media chronic | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Pharyngitis | 0 | 0 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Pharyngitis streptococcal | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Pneumococcal sepsis | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Pneumonia | 4 (5.6%) | 4 | 3 (4.8%) | 3 | 7 (12.7%) | 9 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 11 (7.9%) | 13 | 5 (3.8%) | 5
Pyelonephritis | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Pyelonephritis acute | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Respiratory syncytial virus infection | 0 | 0 | 3 (4.8%) | 3 | 3 (5.5%) | 3 | 2 (3.3%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 4 (2.9%) | 4 | 5 (3.8%) | 5
Rhinitis | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Rhinovirus infection | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Roseola | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Rotavirus infection | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Sepsis | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Sinusitis | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 2 (1.5%) | 2
Staphylococcal infection | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Tinea capitis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Tinea infection | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Tracheobronchitis | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Upper respiratory tract infection | 6 (8.3%) | 7 | 3 (4.8%) | 3 | 4 (7.3%) | 6 | 1 (1.7%) | 1 | 0 | 0 | 1 (9.1%) | 1 | 10 (7.1%) | 13 | 5 (3.8%) | 5
Urinary tract infection | 5 (6.9%) | 5 | 2 (3.2%) | 2 | 2 (3.6%) | 2 | 2 (3.3%) | 3 | 2 (15.4%) | 2 | 0 | 0 | 9 (6.4%) | 9 | 4 (3%) | 5
Viral infection | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Viral upper respiratory tract infection | 2 (2.8%) | 2 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 0 | 0
Injury, poisoning and procedural complications | 7 (9.7%) | 8 | 5 (8.1%) | 6 | 5 (9.1%) | 6 | 6 (10%) | 8 | 3 (23.1%) | 5 | 1 (9.1%) | 1 | 15 (10.7%) | 19 | 12 (9%) | 15
Arthropod bite | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Child maltreatment syndrome | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Craniocerebral injury | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
Excoriation | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Exposure to chemical pollution | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Fall | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Fracture | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Head injury | 2 (2.8%) | 2 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
Humerus fracture | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Joint dislocation | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Lower limb fracture | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Maternal exposure during pregnancy | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Multiple fractures | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Optic nerve injury | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Retinal injury | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Rib fracture | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Shunt malfunction | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Skeletal injury | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Skull fracture | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Subdural haemorrhage | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Tendon injury | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Wrist fracture | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Investigations | 15 (20.8%) | 26 | 7 (11.3%) | 9 | 11 (20%) | 29 | 8 (13.3%) | 11 | 3 (23.1%) | 3 | 1 (9.1%) | 2 | 29 (20.7%) | 58 | 16 (12%) | 22
Analgesic drug level | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Biopsy | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Blood calcium decreased | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Blood chloride increased | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Blood creatinine increased | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Blood gases abnormal | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Blood glucose abnormal | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Blood glucose increased | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Blood lactic acid increased | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Blood potassium increased | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Blood sodium abnormal | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Blood sodium increased | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Blood urea increased | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Brain stem auditory evoked response | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Bronchoalveolar lavage | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Bronchoscopy | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 5 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 5 | 1 (0.8%) | 1
Carbon dioxide decreased | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Carbon dioxide increased | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Cardiac murmur | 4 (5.6%) | 4 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 5 (3.6%) | 5 | 2 (1.5%) | 2
Chromosome analysis abnormal | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Computerised tomogram abnormal | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Electrocardiogram QT prolonged | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Electroencephalogram abnormal | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Endoscopy | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Endoscopy upper gastrointestinal tract | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Gamma-glutamyltransferase increased | 2 (2.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Investigation abnormal | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Laryngoscopy | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 5 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 6 | 1 (0.8%) | 1
Liver function test abnormal | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Lymphocyte count decreased | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Neutrophil count abnormal | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Neutrophil count increased | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Nuclear magnetic resonance imaging abnormal | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Oesophagogastroduodenoscopy | 0 | 0 | 0 | 0 | 2 (3.6%) | 3 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 4 | 1 (0.8%) | 1
Oxygen saturation decreased | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
PCO2 increased | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
QRS axis abnormal | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Red blood cells urine | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Transaminases increased | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Weight decreased | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
White blood cell count | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
White blood cell count abnormal | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
White blood cell count increased | 2 (2.8%) | 2 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 2 (1.5%) | 2
Wound healing normal | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Metabolism and nutrition disorders | 11 (15.3%) | 15 | 8 (12.9%) | 8 | 8 (14.5%) | 8 | 8 (13.3%) | 10 | 3 (23.1%) | 4 | 2 (18.2%) | 4 | 22 (15.7%) | 27 | 18 (13.5%) | 22
Acidosis | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Decreased appetite | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (18.2%) | 2 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Dehydration | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Failure to thrive | 4 (5.6%) | 4 | 3 (4.8%) | 3 | 3 (5.5%) | 3 | 3 (5%) | 3 | 1 (7.7%) | 1 | 0 | 0 | 8 (5.7%) | 8 | 6 (4.5%) | 6
Feeding disorder | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Hypercholesterolaemia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Hyperglycaemia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hyperkalaemia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypoglycaemia | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Hypoglycaemia neonatal | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Hypokalaemia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Hyponatraemia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 2 (15.4%) | 2 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Hypophagia | 1 (1.4%) | 2 | 2 (3.2%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 2 | 2 (1.5%) | 2
Hypovolaemia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Lactose intolerance | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Malnutrition | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 2 (1.5%) | 2
Metabolic acidosis | 3 (4.2%) | 3 | 0 | 0 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 5 (3.6%) | 5 | 1 (0.8%) | 1
Overweight | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Weight gain poor | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Musculoskeletal and connective tissue disorders | 4 (5.6%) | 5 | 1 (1.6%) | 2 | 4 (7.3%) | 4 | 7 (11.7%) | 11 | 2 (15.4%) | 2 | 2 (18.2%) | 2 | 10 (7.1%) | 11 | 10 (7.5%) | 15
Congenital hip deformity | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Finger deformity | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Foot deformity | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Growth retardation | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Joint range of motion decreased | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Muscle contracture | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Muscle hypertrophy | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Muscle spasms | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 2 (1.5%) | 2
Muscle twitching | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Muscular weakness | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
Neck deformity | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Neck pain | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Osteopenia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Pelvic deformity | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Rhabdomyolysis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Rickets | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Scoliosis | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Shoulder deformity | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Systemic lupus erythematosus | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | 3 (4.2%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 4 (2.9%) | 4 | 0 | 0
Choroid plexus carcinoma | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Haemangioma | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Lipoma | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Medulloblastoma | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Nervous system disorders | 69 (95.8%) | 118 | 60 (96.8%) | 85 | 54 (98.2%) | 133 | 60 (100%) | 116 | 13 (100%) | 33 | 10 (90.9%) | 22 | 136 (97.1%) | 284 | 130 (97.7%) | 223
Altered visual depth perception | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Aphasia | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Arachnoid cyst | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Areflexia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Ataxia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Autism | 0 | 0 | 0 | 0 | 6 (10.9%) | 6 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 7 (5%) | 7 | 1 (0.8%) | 1
Brain injury | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
CNS ventriculitis | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cataplexy | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Cauda equina syndrome | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Cerebral atrophy | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cerebral calcification | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cerebral cyst | 1 (1.4%) | 2 | 1 (1.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 2 | 1 (0.8%) | 2
Cerebral haematoma | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cerebral haemorrhage | 0 | 0 | 1 (1.6%) | 1 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Cerebral ventricle dilatation | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Cerebrovascular accident | 0 | 0 | 0 | 0 | 4 (7.3%) | 4 | 3 (5%) | 3 | 3 (23.1%) | 3 | 0 | 0 | 7 (5%) | 7 | 3 (2.3%) | 3
Choreoathetosis | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cognitive disorder | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Complex partial seizures | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Convulsion | 51 (70.8%) | 54 | 38 (61.3%) | 39 | 32 (58.2%) | 33 | 40 (66.7%) | 40 | 10 (76.9%) | 10 | 7 (63.6%) | 7 | 93 (66.4%) | 97 | 85 (63.9%) | 86
Demyelination | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 2
Dizziness | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Drooling | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Dystonia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Encephalitis | 0 | 0 | 0 | 0 | 3 (5.5%) | 4 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 4 | 1 (0.8%) | 1
Encephalomalacia | 1 (1.4%) | 1 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 3 (2.3%) | 3
Encephalomyelitis | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Encephalopathy | 0 | 0 | 0 | 0 | 5 (9.1%) | 5 | 3 (5%) | 3 | 1 (7.7%) | 1 | 2 (18.2%) | 2 | 6 (4.3%) | 6 | 5 (3.8%) | 5
Epilepsy | 6 (8.3%) | 6 | 9 (14.5%) | 9 | 14 (25.5%) | 14 | 16 (26.7%) | 17 | 1 (7.7%) | 1 | 3 (27.3%) | 4 | 21 (15%) | 21 | 28 (21.1%) | 30
Febrile convulsion | 10 (13.9%) | 12 | 6 (9.7%) | 6 | 5 (9.1%) | 5 | 4 (6.7%) | 4 | 0 | 0 | 0 | 0 | 15 (10.7%) | 17 | 10 (7.5%) | 10
Grand mal convulsion | 4 (5.6%) | 4 | 2 (3.2%) | 2 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 6 (4.3%) | 6 | 2 (1.5%) | 2
Haemorrhage intracranial | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Headache | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 3 (23.1%) | 3 | 3 (27.3%) | 3 | 5 (3.6%) | 5 | 5 (3.8%) | 5
Hemiparesis | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 3 | 0 | 0
Hemiplegia | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 3 | 2 (1.5%) | 2
Hydrocephalus | 5 (6.9%) | 5 | 5 (8.1%) | 5 | 8 (14.5%) | 8 | 5 (8.3%) | 5 | 1 (7.7%) | 1 | 0 | 0 | 14 (10%) | 14 | 10 (7.5%) | 10
Hyperreflexia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Hypertonia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 2
Hyporeflexia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypotonia | 2 (2.8%) | 2 | 2 (3.2%) | 2 | 5 (9.1%) | 5 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 7 (5%) | 7 | 4 (3%) | 4
Hypoxic-ischaemic encephalopathy | 1 (1.4%) | 1 | 0 | 0 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 1 (0.8%) | 1
IIIrd nerve disorder | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Infantile spasms | 2 (2.8%) | 2 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 2 (1.5%) | 2
Intraventricular haemorrhage | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Lethargy | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Masked facies | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Mental retardation | 0 | 0 | 0 | 0 | 4 (7.3%) | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 4 (2.9%) | 4 | 0 | 0
Migraine | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Motor developmental delay | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Motor dysfunction | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Movement disorder | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Muscle spasticity | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Myoclonus | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Nervous system disorder | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Nystagmus | 0 | 0 | 0 | 0 | 3 (5.5%) | 4 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 3 (2.1%) | 4 | 2 (1.5%) | 2
Paralysis | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Paraplegia | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Partial seizures | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Periventricular leukomalacia | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Petit mal epilepsy | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Post-traumatic epilepsy | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Postictal paralysis | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 3 | 0 | 0
Quadriparesis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Quadriplegia | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Sensory disturbance | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Somnolence | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Spastic diplegia | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 2 (3.3%) | 2 | 2 (15.4%) | 2 | 0 | 0 | 3 (2.1%) | 3 | 3 (2.3%) | 3
Speech disorder | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 3 (5%) | 3 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 3 (2.1%) | 3 | 5 (3.8%) | 5
Speech disorder developmental | 4 (5.6%) | 4 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 4 (2.9%) | 4 | 2 (1.5%) | 2
Status epilepticus | 4 (5.6%) | 4 | 3 (4.8%) | 3 | 4 (7.3%) | 4 | 1 (1.7%) | 1 | 2 (15.4%) | 2 | 1 (9.1%) | 1 | 10 (7.1%) | 10 | 5 (3.8%) | 5
Syncope | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Tardive dyskinesia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Tonic clonic movements | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Tremor | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Visual field defect | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Vocal cord paralysis | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Pregnancy, puerperium and perinatal conditions | 8 (11.1%) | 8 | 3 (4.8%) | 3 | 7 (12.7%) | 7 | 5 (8.3%) | 5 | 1 (7.7%) | 1 | 1 (9.1%) | 2 | 16 (11.4%) | 16 | 9 (6.8%) | 10
Abortion spontaneous | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Delivery | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Foetal growth restriction | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Placental disorder | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Pregnancy | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Premature baby | 4 (5.6%) | 4 | 3 (4.8%) | 3 | 7 (12.7%) | 7 | 5 (8.3%) | 5 | 0 | 0 | 0 | 0 | 11 (7.9%) | 11 | 8 (6%) | 8
Twin pregnancy | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Umbilical cord abnormality | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Psychiatric disorders | 7 (9.7%) | 8 | 3 (4.8%) | 3 | 5 (9.1%) | 7 | 11 (18.3%) | 18 | 3 (23.1%) | 6 | 5 (45.5%) | 6 | 15 (10.7%) | 21 | 19 (14.3%) | 27
Abnormal behaviour | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 2 (3.3%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 3 | 2 (1.5%) | 2
Agitation | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Anxiety | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Attention deficit/hyperactivity disorder | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 5 (8.3%) | 7 | 1 (7.7%) | 1 | 2 (18.2%) | 2 | 3 (2.1%) | 3 | 7 (5.3%) | 9
Autism spectrum disorder | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 1 (9.1%) | 1 | 1 (0.7%) | 1 | 4 (3%) | 4
Aversion | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Body dysmorphic disorder | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Breath holding | 2 (2.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Catatonia | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Confusional state | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Conversion disorder | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Decreased eye contact | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Depression | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Drug abuse | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Dysphoria | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Expressive language disorder | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Insomnia | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Intentional self-injury | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Learning disorder | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Mental status changes | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Staring | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Stress | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Renal and urinary disorders | 2 (2.8%) | 4 | 3 (4.8%) | 4 | 1 (1.8%) | 1 | 5 (8.3%) | 5 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 4 (2.9%) | 6 | 9 (6.8%) | 10
Enuresis | 0 | 0 | 0 | 0 | 0 | 0 | 3 (5%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.3%) | 3
Hydronephrosis | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Incontinence | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Lupus nephritis | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Neurogenic bladder | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Renal disorder | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Renal failure | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Renal failure acute | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Renal failure chronic | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Urinary incontinence | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Vesicoureteric reflux | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Reproductive system and breast disorders | 2 (2.8%) | 2 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Genital labial adhesions | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Mammary duct ectasia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Testicular disorder | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Respiratory, thoracic and mediastinal disorders | 34 (47.2%) | 68 | 33 (53.2%) | 70 | 27 (49.1%) | 59 | 29 (48.3%) | 50 | 9 (69.2%) | 13 | 5 (45.5%) | 6 | 70 (50%) | 140 | 67 (50.4%) | 126
Adenoidal hypertrophy | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Apnoea | 4 (5.6%) | 4 | 0 | 0 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 6 (4.3%) | 6 | 1 (0.8%) | 1
Apnoeic attack | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Apparent life threatening event | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Aspiration | 3 (4.2%) | 3 | 2 (3.2%) | 2 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 5 (3.6%) | 5 | 2 (1.5%) | 2
Asthma | 0 | 0 | 2 (3.2%) | 2 | 9 (16.4%) | 9 | 14 (23.3%) | 14 | 3 (23.1%) | 3 | 3 (27.3%) | 3 | 12 (8.6%) | 12 | 19 (14.3%) | 19
Atelectasis | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Bronchial hyperreactivity | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Bronchomalacia | 0 | 0 | 1 (1.6%) | 1 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Bronchopulmonary disease | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Bronchopulmonary dysplasia | 3 (4.2%) | 3 | 0 | 0 | 5 (9.1%) | 6 | 0 | 0 | 0 | 0 | 0 | 0 | 8 (5.7%) | 9 | 0 | 0
Choking | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Chronic respiratory disease | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
Cough | 11 (15.3%) | 12 | 17 (27.4%) | 17 | 4 (7.3%) | 4 | 9 (15%) | 9 | 2 (15.4%) | 2 | 0 | 0 | 17 (12.1%) | 18 | 26 (19.5%) | 26
Dependence on respirator | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Dry throat | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Dyspnoea | 2 (2.8%) | 2 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 3 (2.3%) | 3
Epiglottic mass | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypercapnia | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hyperventilation | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Hypopnoea | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypoventilation | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypoxia | 3 (4.2%) | 3 | 4 (6.5%) | 4 | 4 (7.3%) | 4 | 0 | 0 | 2 (15.4%) | 2 | 2 (18.2%) | 2 | 9 (6.4%) | 9 | 6 (4.5%) | 6
Increased upper airway secretion | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Infantile apnoeic attack | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Laryngeal stenosis | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Lung disorder | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Lung infiltration | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Nasal congestion | 9 (12.5%) | 9 | 9 (14.5%) | 9 | 2 (3.6%) | 2 | 3 (5%) | 3 | 1 (7.7%) | 1 | 0 | 0 | 12 (8.6%) | 12 | 12 (9%) | 12
Neonatal aspiration | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Neonatal respiratory distress syndrome | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Pneumonia aspiration | 1 (1.4%) | 1 | 2 (3.2%) | 2 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 2 (1.5%) | 2
Pulmonary arterial hypertension | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Pulmonary congestion | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Pulmonary haemorrhage | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Pulmonary hypertension | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Pulmonary interstitial emphysema syndrome | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Respiration abnormal | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Respiratory acidosis | 2 (2.8%) | 2 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Respiratory depression | 0 | 0 | 3 (4.8%) | 3 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 4 (3%) | 4
Respiratory disorder | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Respiratory distress | 2 (2.8%) | 2 | 3 (4.8%) | 3 | 2 (3.6%) | 2 | 3 (5%) | 3 | 1 (7.7%) | 1 | 0 | 0 | 5 (3.6%) | 5 | 6 (4.5%) | 6
Respiratory failure | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Rhinitis allergic | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Rhinorrhoea | 11 (15.3%) | 11 | 7 (11.3%) | 7 | 1 (1.8%) | 1 | 6 (10%) | 6 | 0 | 0 | 0 | 0 | 12 (8.6%) | 12 | 13 (9.8%) | 13
Rhonchi | 0 | 0 | 2 (3.2%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Sleep apnoea syndrome | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 3 | 0 | 0
Sneezing | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Snoring | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Stridor | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Tachypnoea | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Tonsillar hypertrophy | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Tracheomalacia | 2 (2.8%) | 2 | 0 | 0 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 4 (2.9%) | 4 | 1 (0.8%) | 1
Upper respiratory tract congestion | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Vocal cord disorder | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Wheezing | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Skin and subcutaneous tissue disorders | 7 (9.7%) | 12 | 11 (17.7%) | 15 | 7 (12.7%) | 8 | 4 (6.7%) | 4 | 2 (15.4%) | 3 | 2 (18.2%) | 3 | 16 (11.4%) | 23 | 17 (12.8%) | 22
Acne | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Cafe au lait spots | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Dermatitis allergic | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Dermatitis atopic | 0 | 0 | 2 (3.2%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
Dermatitis diaper | 1 (1.4%) | 1 | 2 (3.2%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
Drug rash with eosinophilia and systemic symptoms | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Dry skin | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Eczema | 3 (4.2%) | 3 | 3 (4.8%) | 3 | 2 (3.6%) | 2 | 2 (3.3%) | 2 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 6 (4.3%) | 6 | 6 (4.5%) | 6
Erythema | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Hyperhidrosis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Keratosis pilaris | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Pigmentation disorder | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Psoriasis | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Rash | 1 (1.4%) | 1 | 3 (4.8%) | 3 | 1 (1.8%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 3 (2.1%) | 3 | 4 (3%) | 4
Seborrhoeic dermatitis | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Skin irritation | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Skin ulcer | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Stevens-Johnson syndrome | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Sunburn | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Urticaria | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Social circumstances | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Hearing aid user | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Maternal use of illicit drugs | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Surgical and medical procedures | 13 (18.1%) | 55 | 15 (24.2%) | 29 | 25 (45.5%) | 77 | 25 (41.7%) | 68 | 6 (46.2%) | 30 | 3 (27.3%) | 3 | 44 (31.4%) | 162 | 43 (32.3%) | 100
Adenoidectomy | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 3 (5.5%) | 3 | 2 (3.3%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 5 (3.6%) | 5 | 3 (2.3%) | 3
Adenotonsillectomy | 0 | 0 | 1 (1.6%) | 1 | 3 (5.5%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 1 (0.8%) | 1
Anaesthetic premedication | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Antibiotic therapy | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Aorta coarctation repair | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Appendicectomy | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
CSF shunt operation | 0 | 0 | 1 (1.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 2
Caesarean section | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Catheter placement | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Catheter removal | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Central venous catheterisation | 2 (2.8%) | 3 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 4 | 1 (0.8%) | 1
Chest tube removal | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Circumcision | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Cochlea implant | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Corneal transplant | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Craniectomy | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cranioplasty | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Cystostomy | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Dental operation | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Drug therapy | 2 (2.8%) | 3 | 2 (3.2%) | 2 | 0 | 0 | 2 (3.3%) | 2 | 1 (7.7%) | 2 | 0 | 0 | 3 (2.1%) | 5 | 4 (3%) | 4
Ear tube insertion | 1 (1.4%) | 1 | 2 (3.2%) | 2 | 4 (7.3%) | 6 | 7 (11.7%) | 7 | 2 (15.4%) | 2 | 0 | 0 | 7 (5%) | 9 | 9 (6.8%) | 9
Endotracheal intubation | 2 (2.8%) | 2 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 0 | 0
Enteral nutrition | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Eye laser surgery | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
Eye operation | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Fistula repair | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Gastroenterostomy | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Gastrointestinal tube insertion | 5 (6.9%) | 7 | 4 (6.5%) | 4 | 7 (12.7%) | 7 | 5 (8.3%) | 5 | 2 (15.4%) | 2 | 1 (9.1%) | 1 | 14 (10%) | 16 | 10 (7.5%) | 10
Gastrointestinal tube removal | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Gastrostomy | 0 | 0 | 2 (3.2%) | 2 | 3 (5.5%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 2 (1.5%) | 2
Gastrostomy tube insertion | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 2 (3.6%) | 3 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 3 (2.1%) | 4 | 3 (2.3%) | 3
Haemodialysis | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Heart valve replacement | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Hernia repair | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hip surgery | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 2 | 0 | 0 | 1 (0.7%) | 2 | 0 | 0
Hospitalisation | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Immunisation | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Incisional drainage | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Inguinal hernia repair | 0 | 0 | 0 | 0 | 3 (5.5%) | 3 | 1 (1.7%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 4 (2.9%) | 4 | 1 (0.8%) | 2
Injection | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Intensive care | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Intestinal resection | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Intrathecal pump insertion | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Jaw operation | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Laparotomy | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Laryngeal operation | 0 | 0 | 0 | 0 | 1 (1.8%) | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 4 | 0 | 0
Mastoidectomy | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Mechanical ventilation | 2 (2.8%) | 3 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 4 (2.9%) | 5 | 0 | 0
Muscle operation | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Myringotomy | 0 | 0 | 0 | 0 | 4 (7.3%) | 5 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 4 (2.9%) | 5 | 1 (0.8%) | 1
Oesophagogastric fundoplasty | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 4 (6.7%) | 4 | 2 (15.4%) | 2 | 0 | 0 | 4 (2.9%) | 4 | 4 (3%) | 4
Orchidopexy | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Oxygen supplementation | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Packed red blood cell transfusion | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Pain management | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Parenteral nutrition | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Patent ductus arteriosus repair | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 1 (0.8%) | 1
Pericardial drainage | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Platelet transfusion | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Prosthesis implantation | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Pulmonary artery therapeutic procedure | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Salivary gland operation | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Skin cosmetic procedure | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
Small intestinal resection | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Spinal decompression | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Spinal laminectomy | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Strabismus correction | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
Surgery | 3 (4.2%) | 4 | 2 (3.2%) | 2 | 0 | 0 | 5 (8.3%) | 7 | 2 (15.4%) | 2 | 0 | 0 | 5 (3.6%) | 6 | 7 (5.3%) | 9
Tendon operation | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Tonsillectomy | 0 | 0 | 0 | 0 | 3 (5.5%) | 3 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 4 (2.9%) | 4 | 1 (0.8%) | 1
Tracheal lesion excision | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Tracheostomy | 2 (2.8%) | 3 | 1 (1.6%) | 1 | 4 (7.3%) | 6 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 6 (4.3%) | 9 | 3 (2.3%) | 3
Tracheostomy tube removal | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Umbilical hernia repair | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Vagal nerve stimulator implantation | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
Ventricular septal defect repair | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
Ventriculo-peritoneal shunt | 6 (8.3%) | 7 | 4 (6.5%) | 5 | 8 (14.5%) | 9 | 7 (11.7%) | 8 | 2 (15.4%) | 5 | 0 | 0 | 16 (11.4%) | 21 | 11 (8.3%) | 13
Vascular disorders | 2 (2.8%) | 2 | 2 (3.2%) | 2 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 4 (30.8%) | 4 | 0 | 0 | 8 (5.7%) | 8 | 3 (2.3%) | 3
Haemorrhage | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
Hypertension | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (23.1%) | 3 | 0 | 0 | 4 (2.9%) | 4 | 0 | 0
Hypotension | 1 (1.4%) | 1 | 2 (3.2%) | 2 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 2 (1.5%) | 2
Kawasaki’s disease | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1

Note: The percentages are based on the total number of IIT Participants in each treatment group or total.

Table 14.1.6.1 Summary of Prior Anti-Epileptic Medications by Age Stratum and Treatment Group ITT population

| Age Strata | | | | | | Total
| 3 mo – <3 yrs | 3 mo – <3 yrs | 3 yrs – <13 yrs | 3 yrs – <13 yrs | ≥13 yrs | ≥13 yrs
Medication Name | Diazepam (N=72) | Lorazepam (N=62) | Diazepam (N=55) | Lorazepam (N=60) | Diazepam (N=13) | Lorazepam (N=11) | Diazepam (N=140) | Lorazepam (N=133)
AMITRIPTYLINE | 0 | 0 | 1 (2.2%) | 0 | 0 | 0 | 1 (1.1%) | 0
CARBEMAZEPINE | 1 (4.0%) | 0 | 3 (6.5%) | 4 (6.1%) | 0 | 0 | 4 (4.5%) | 4 (3.8%)
CLONAZEPAM | 0 | 1 (3.3%) | 1 (2.2%) | 1 (1.5%) | 0 | 0 | 1 (1.1%) | 2 (1.9%)
DIAZEPAM | 0 | 0 | 0 | 4 (6.1%) | 0 | 0 | 0 | 4 (3.8%)
FELBAMATE | 0 | 0 | 0 | 0 | 1 (5.6%) | 0 | 1 (1.1%) | 0
FOSPHENYTOIN | 0 | 0 | 1 (2.2%) | 2 (3.0%) | 0 | 0 | 1 (1.1%) | 2 (1.9%)
LACOSAMIDE | 1 (4.0%) | 0 | 0 | 0 | 0 | 0 | 1 (1.1%) | 0
LAMOTRIGINE | 0 | 0 | 1 (2.2%) | 2 (3.0%) | 0 | 2 (20.0%) | 1 (1.1%) | 4 (3.8%)
LEVETIRACETAM | 9 (36.0%) | 9 (30.0%) | 14 (30.4%) | 17 (25.8%) | 5 (27.8%) | 4 (40.0%) | 28 (31.5%) | 30 (28.3%)
LORAZEPAM | 0 | 0 | 0 | 3 (4.5%) | 0 | 0 | 0 | 3 (2.8%)
OXCARBAZEPINE | 6 (24.0%) | 2 (6.7%) | 7 (15.2%) | 9 (13.6%) | 4 (22.2%) | 2 (20.0%) | 17 (19.1%) | 13 (12.3%)
PHENOBARBITAL | 2 (8.0%) | 10 (33.3%) | 2 (4.3%) | 3 (4.5%) | 1 (5.6%) | 0 | 5 (5.6%) | 13 (12.3%)
PHENYTOIN | 0 | 0 | 1 (2.2%) | 1 (1.5%) | 0 | 0 | 1 (1.1%) | 1 (0.9%)
RUFINAMIDE | 0 | 0 | 0 | 0 | 0 | 1 (10.0%) | 0 | 1 (0.9%)
SABRIL | 0 | 1 (3.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.9%)
TOPIRAMATE | 2 (8.0%) | 5 (16.7%) | 4 (8.7%) | 10 (15.2%) | 0 | 1 (10.0%) | 6 (6.7%) | 16 (15.1%)
VALPROATE SODIUM/ACID/DIVALPROEX SODIUM | 1 (4.0%) | 1 (3.3%) | 8 (17.4%) | 7 (10.6%) | 7 (38.9%) | 0 | 16 (18.0%) | 8 (7.5%)
VIGABATRIN | 3 (12.0%) | 1 (3.3%) | 0 | 0 | 0 | 0 | 3 (3.4%) | 1 (0.9%)
ZONISAMIDE | 0 | 0 | 3 (6.5%) | 3 (4.5%) | 0 | 0 | 3 (3.4%) | 3 (2.8%)

Note: The percentages are based on the total number of enrolled ITT participants in each treatment group or total.

Table 14.1.6.2 Summary of Concomitant Anti-Epileptic Medications by Age Stratum and Treatment Group ITT population

| Age Strata | | | | | | Total
| 3 mo – <3 yrs | 3 mo – <3 yrs | 3 yrs – <13 yrs | 3 yrs – <13 yrs | ≥13 yrs | ≥13 yrs
Medication Name | Diazepam (N=72) | Lorazepam (N=62) | Diazepam (N=55) | Lorazepam (N=60) | Diazepam (N=13) | Lorazepam (N=11) | Diazepam (N=140) | Lorazepam (N=133)
CARBEMAZEPINE | 2 (1.3%) | 0 | 1 (0.7%) | 2 (1.4%) | 0 | 0 | 3 (0.9%) | 2 (0.6%)
CLONAZEPAM | 2 (1.3%) | 0 | 4 (2.7%) | 0 | 0 | 0 | 6 (1.7%) | 0
DIAZEPAM | 1 (0.6%) | 0 | 0 | 1 (0.7%) | 0 | 0 | 1 (0.3%) | 1 (0.3%)
DIPHENHYDRAMINE | 1 (0.6%) | 0 | 0 | 0 | 0 | 0 | 1 (0.3%) | 0
ETOMIDATE | 0 | 0 | 0 | 1 (0.7%) | 0 | 0 | 0 | 1 (0.3%)
FOSPHENYTOIN | 32 (20.5%) | 35 (19.8%) | 28 (19.0%) | 29 (20.6%) | 4 (9.8%) | 4 (20.0%) | 64 (18.6%) | 68 (20.1%)
LACOSAMIDE | 1 (0.6%) | 0 | 0 | 0 | 0 | 0 | 1 (0.3%) | 0
LAMOTRIGINE | 0 | 0 | 0 | 2 (1.4%) | 0 | 0 | 0 | 2 (0.6%)
LEVETIRACETAM | 25 (16.0%) | 33 (18.6%) | 32 (21.8%) | 27 (19.1%) | 12 (29.3%) | 8 (40.0%) | 69 (20.1%) | 68 (20.1%)
LORAZEPAM | 32 (20.5%) | 25 (14.1%) | 28 (19.0%) | 8 (5.7%) | 4 (9.8%) | 3 (15.0%) | 64 (18.6%) | 36 (10.7%)
MIDAZOLAM | 16 (10.3%) | 40 (22.6%) | 19 (12.9%) | 25 (17.7%) | 4 (9.8%) | 0 | 39 (11.3%) | 65 (19.2%)
OXCARBAZEPINE | 6 (3.8%) | 8 (4.5%) | 10 (6.8%) | 10 (7.1%) | 2 (4.9%) | 4 (20.0%) | 18 (5.2%) | 22 (6.5%)
PENTOBARBITAL | 5 (3.2%) | 0 | 1 (0.7%) | 1 (0.7%) | 0 | 0 | 6 (1.7%) | 1 (0.3%)
PHENOBARBITAL | 22 (14.1%) | 19 (10.7%) | 4 (2.7%) | 7 (5.0%) | 5 (12.2%) | 0 | 31 (9.0%) | 26 (7.7%)
PHENYTOIN | 7 (4.5%) | 10 (5.6%) | 10 (6.8%) | 7 (5.0%) | 0 | 0 | 17 (4.9%) | 17 (5.0%)
PROPOFOL | 0 | 1 (0.6%) | 0 | 5 (3.5%) | 0 | 0 | 0 | 6 (1.8%)
TOPIRAMATE | 3 (1.9%) | 4 (2.3%) | 2 (1.4%) | 6 (4.3%) | 0 | 1 (5.0%) | 5 (1.5%) | 11 (3.3%)
VALPROATE SODIUM/ACID/DIVALPROEX SODIUM | 0 | 0 | 7 (4.8%) | 9 (6.4%) | 10 (24.4%) | 0 | 17 (4.9%) | 9 (2.7%)
VIGABATRIN | 1 (0.6%) | 2 (1.1%) | 0 | 0 | 0 | 0 | 1 (0.3%) | 2 (0.6%)
ZONISAMIDE | 0 | 0 | 1 (0.7%) | 1 (0.7%) | 0 | 0 | 1 (0.3%) | 1 (0.3%)

Note: The percentages are based on the total number of enrolled ITT participants in each treatment group or total.

Table 14.1.7.1 Concomitant Medications Before Start of Study Dose by Age Stratum and Treatment Group ITT population

| Age Strata | | | | | | | | | | | | Total
| 3 mo - <3 yrs Diazepam (N=72) | | 3 mo - <3 yrs Lorazepam (N=62) | | 3 yrs - <13 yrs Diazepam (N=55) | | 3 yrs - <13 yrs Lorazepam (N=60) | | ≥13 yrs Diazepam (N=13) | | ≥13 yrs Lorazepam (N=11) | | Diazepam (N=140) | | Lorazepam (N=133)
WHO Class | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns
Medication Name | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N
ALIMENTARY TRACT AND METABOLISM | 8 (11.1%) | 16 | 4 (6.5%) | 8 | 10 (18.2%) | 24 | 11 (18.3%) | 17 | 5 (38.5%) | 9 | 3 (27.3%) | 13 | 23 (16.4%) | 49 | 18 (13.5%) | 38
ASCORBIC ACID | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
BENZOCAINE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
BIOTIN | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
CALCIUM CARBONATE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
CARNITINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
COENZYME COMPLEX | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
COLECALCIFEROL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 1 (0.7%) | 1 | 1 (0.8%) | 1
COPPER | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
CYPROHEPTADINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
DOCUSATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 1 (0.7%) | 1 | 1 (0.8%) | 1
DURAPATITE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
ENZYMES | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
FIBRE, DIETARY | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
FLEET ENEMA /00129701/ | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
GLYCOPYRROLATE /00196202/ | 0 | 0 | 0 | 0 | 3 (5.5%) | 3 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 1 (0.8%) | 1
GLYCOPYRRONIUM BROMIDE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
L-GLUTAMINE /00900601/ | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
LACTULOSE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
LANSOPRAZOLE | 6 (8.3%) | 6 | 3 (4.8%) | 3 | 3 (5.5%) | 3 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 9 (6.4%) | 9 | 5 (3.8%) | 5
LEVOCARNITINE | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
MAALOX /00091001/ | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
MACROGOL | 1 (1.4%) | 1 | 0 | 0 | 6 (10.9%) | 6 | 4 (6.7%) | 4 | 2 (15.4%) | 2 | 0 | 0 | 9 (6.4%) | 9 | 4 (3%) | 4
METOCLOPRAMIDE | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
MIGLUSTAT | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
MISOPROSTOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
MULTIVITAMINS | 3 (4.2%) | 3 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 1 (9.1%) | 1 | 4 (2.9%) | 4 | 4 (3%) | 4
NEPHROCAPS /01801401/ | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
NICOTINIC ACID | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
OMEPRAZOLE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
ONDANSETRON | 2 (2.8%) | 2 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 3 (2.1%) | 3 | 1 (0.8%) | 1
PYRIDOXINE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
RANITIDINE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 2 (15.4%) | 2 | 0 | 0 | 3 (2.1%) | 3 | 2 (1.5%) | 2
SELENIUM | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
SENNOSIDE A+B | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
SODIUM BICARBONATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
SODIUM PHOSPHATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
THIAMINE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
TOCOPHEROL | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
VARIOUS ALIMENTARY TRACT AND METABOLISM PRODUCTS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
ANTIINFECTIVES FOR SYSTEMIC USE | 8 (11.1%) | 8 | 4 (6.5%) | 4 | 7 (12.7%) | 7 | 5 (8.3%) | 8 | 1 (7.7%) | 1 | 1 (9.1%) | 4 | 16 (11.4%) | 16 | 10 (7.5%) | 16
AMOXICILLIN | 5 (6.9%) | 5 | 2 (3.2%) | 2 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 7 (5%) | 7 | 3 (2.3%) | 3
AMPICILLIN | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 2 | 0 | 0 | 1 (0.8%) | 2
CEFDINIR | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
CEFOTAXIME | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
CEFTRIAXONE | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
CIPROFLOXACIN | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 3 | 0 | 0
ERYTHROMYCIN | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 1 (9.1%) | 1 | 1 (0.7%) | 1 | 2 (1.5%) | 2
GENTAMICIN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 2 (1.5%) | 2
IMMUNOGLOBULINS | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
NAFCILLIN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 2
NITROFURANTOIN | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
OSELTAMIVIR | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
TOBRAMYCIN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
ANTINEOPLASTIC AND IMMUNOMODULATING AGENTS | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
LEUPRORELIN ACETATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
ANTIPARASITIC PRODUCTS, INSECTICIDES AND REPELLENTS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
HYDROXYCHLOROQUINE PHOSPHATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
BLOOD AND BLOOD FORMING ORGANS | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 2 (15.4%) | 2 | 1 (9.1%) | 1 | 3 (2.1%) | 3 | 3 (2.3%) | 3
ACETYLSALICYLIC ACID | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
FERROUS SULFATE | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
FOLIC ACID | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
CARDIOVASCULAR SYSTEM | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 4 (30.8%) | 7 | 1 (9.1%) | 2 | 4 (2.9%) | 7 | 2 (1.5%) | 3
ADENOSINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 2 | 0 | 0 | 1 (0.8%) | 2
AMLODIPINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
CARVEDILOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
CLONIDINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (15.4%) | 2 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
COLESTYRAMINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
ENALAPRIL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
NADOLOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
NIFEDIPINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
DERMATOLOGICALS | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 5 (9.1%) | 6 | 2 (3.3%) | 3 | 0 | 0 | 0 | 0 | 6 (4.3%) | 7 | 3 (2.3%) | 4
CLOTRIMAZOLE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
HYDROCORTISONE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
LIDOCAINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
LIDOCAINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
MUPIROCIN | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
NYSTATIN | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
SALICYLIC ACID | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
TRIAMCINOLONE ACETONIDE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
GENITO URINARY SYSTEM AND SEX HORMONES | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (15.4%) | 2 | 1 (9.1%) | 2 | 3 (2.1%) | 3 | 1 (0.8%) | 2
CARBOPROST | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
METHYLERGOMETRINE MALEATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
OXYBUTYNIN | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
TAMSULOSIN | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
MUSCULO-SKELETAL SYSTEM | 12 (16.7%) | 13 | 7 (11.3%) | 8 | 8 (14.5%) | 9 | 11 (18.3%) | 14 | 2 (15.4%) | 2 | 2 (18.2%) | 2 | 22 (15.7%) | 24 | 20 (15%) | 24
BACLOFEN | 1 (1.4%) | 1 | 0 | 0 | 2 (3.6%) | 2 | 5 (8.3%) | 6 | 1 (7.7%) | 1 | 0 | 0 | 4 (2.9%) | 4 | 5 (3.8%) | 6
IBUPROFEN | 9 (12.5%) | 10 | 7 (11.3%) | 8 | 6 (10.9%) | 7 | 7 (11.7%) | 8 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 16 (11.4%) | 18 | 15 (11.3%) | 17
KETOROLAC | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
ROCURONIUM | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
TIZANIDINE HYDROCHLORIDE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
NERVOUS SYSTEM | 22 (30.6%) | 26 | 18 (29%) | 20 | 12 (21.8%) | 15 | 10 (16.7%) | 18 | 6 (46.2%) | 8 | 2 (18.2%) | 7 | 40 (28.6%) | 49 | 30 (22.6%) | 45
ARIPIPRAZOLE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
BUPIVACAINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
BUTORPHANOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
BUTORPHANOL TARTRATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
DEXAMFETAMINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
FELBAMATE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
FENTANYL | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 3 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 3 (2.3%) | 5
GUANFACINE HYDROCHLORIDE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 2
HYDROCODONE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
INSULIN | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
LIDOCAINE | 0 | 0 | 1 (1.6%) | 1 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
LIDOCAINE | 0 | 0 | 1 (1.6%) | 1 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
MELATONIN | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
METHYLPHENIDATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
MIDAZOLAM | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
NYQUIL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
OTHER NERVOUS SYSTEM DRUGS | 1 (1.4%) | 2 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 3 | 0 | 0
OXYCODONE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
PARACETAMOL | 19 (26.4%) | 22 | 15 (24.2%) | 16 | 8 (14.5%) | 8 | 5 (8.3%) | 7 | 3 (23.1%) | 3 | 2 (18.2%) | 3 | 30 (21.4%) | 33 | 22 (16.5%) | 26
PSYCHOSTIMULANTS, AGENTS USED FOR ADHD AND NO | 0 | 0 | 0 | 0 | 1 (1.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 2 | 0 | 0
QUETIAPINE FUMARATE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
SERTRALINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
TRAZODONE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
ZONISAMIDE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
RESPIRATORY SYSTEM | 7 (9.7%) | 13 | 4 (6.5%) | 6 | 11 (20%) | 22 | 14 (23.3%) | 25 | 2 (15.4%) | 2 | 1 (9.1%) | 1 | 20 (14.3%) | 37 | 19 (14.3%) | 32
ANTIBIOTICS | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
BENADRYL /01563701/ | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
BENYLIN DM-D FOR CHILDREN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
BUDESONIDE | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 4 (7.3%) | 4 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 5 (3.6%) | 5 | 2 (1.5%) | 2
CETIRIZINE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
DIMETAPP /00127601/ | 1 (1.4%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 3 | 0 | 0
DORNASE ALFA | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
FEXOFENADINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
FLUTICASONE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 3 (5%) | 3 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 3 (2.3%) | 3
FLUTICASONE PROPIONATE | 2 (2.8%) | 2 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
GUAIFENESIN | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
IPRATROPIUM | 1 (1.4%) | 1 | 0 | 0 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 1 (0.8%) | 1
IPRATROPIUM BROMIDE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
LEVOSALBUTAMOL | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
LEVOSALBUTAMOL HYDROCHLORIDE | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
LORATADINE | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
MOMETASONE | 0 | 0 | 0 | 0 | 0 | 0 | 4 (6.7%) | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 4 (3%) | 4
MONTELUKAST | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
MONTELUKAST SODIUM | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
NITRIC OXIDE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
OXYMETAZOLINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
PEDIACARE COUGH-COLD | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
SALBUTAMOL | 5 (6.9%) | 5 | 2 (3.2%) | 2 | 5 (9.1%) | 5 | 5 (8.3%) | 5 | 1 (7.7%) | 1 | 0 | 0 | 11 (7.9%) | 11 | 7 (5.3%) | 7
SERETIDE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
SENSORY ORGANS | 0 | 0 | 1 (1.6%) | 2 | 3 (5.5%) | 4 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 4 (2.9%) | 5 | 2 (1.5%) | 3
DORZOLAMIDE W/TIMOLOL | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
LATANOPROST | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
MOXIFLOXACIN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
OFLOXACIN | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
OLOPATADINE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
PREDNISOLONE ACETATE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
TIMOLOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
SYSTEMIC HORMONAL PREPARATIONS, EXCL. SEX HORMONES AND INSULINS | 3 (4.2%) | 4 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 3 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 5 (3.6%) | 6 | 3 (2.3%) | 4
DESMOPRESSIN | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
DEXAMETHASONE | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
LEVOTHYROXINE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
OXYTOCIN | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
PREDNISONE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
SOMATROPIN | 2 (2.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
VARIOUS | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 1 (9.1%) | 2 | 0 | 0 | 2 (1.5%) | 3
AMINO ACIDS NOS W/CAPSICUM FRUTESCENS FRUIT P | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
CYAMOPSIS TETRAGONOLOBA GUM | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
FISH OIL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1

Note: The percentages are based on the total number of enrolled participants in each treatment group or total.

Participants are counted once for each medication before study dose and once for each medication after study dose.

Table 14.1.7.2 Concomitant Medications After Start of Study Dose by Age Stratum and Treatment Group ITT population

| Age Strata | | | | | | | | | | | | Total
| 3 mo - <3 yrs Diazepam (N=72) | | 3 mo - <3 yrs Lorazepam (N=62) | | 3 yrs - <13 yrs Diazepam (N=55) | | 3 yrs - <13 yrs Lorazepam (N=60) | | ≥13 yrs Diazepam (N=13) | | ≥13 yrs Lorazepam (N=11) | | Diazepam (N=140) | | Lorazepam (N=133)
WHO Class | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns | Pts With Medn | Total Medns
Medication Name | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N | N (%) | N
ALIMENTARY TRACT AND METABOLISM | 17 (23.6%) | 34 | 19 (30.6%) | 29 | 16 (29.1%) | 23 | 14 (23.3%) | 23 | 4 (30.8%) | 5 | 1 (9.1%) | 1 | 37 (26.4%) | 62 | 34 (25.6%) | 53
ATROPINE | 5 (6.9%) | 5 | 5 (8.1%) | 5 | 3 (5.5%) | 3 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 8 (5.7%) | 8 | 7 (5.3%) | 7
ATROPINE | 5 (6.9%) | 5 | 5 (8.1%) | 5 | 3 (5.5%) | 3 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 3 (2.3%) | 3
CALCIUM GLUCONATE | 2 (2.8%) | 2 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 1 (0.8%) | 1
COLECALCIFEROL | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
CYPROHEPTADINE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
ERGOCALCIFEROL | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
ESOMEPRAZOLE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
FAMOTIDINE | 2 (2.8%) | 2 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
GLYCERIN /01736901/ | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
GLYCOPYRROLATE /00196202/ | 1 (1.4%) | 1 | 1 (1.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 2
INSULIN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 3
LACTULOSE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
LANSOPRAZOLE | 3 (4.2%) | 3 | 2 (3.2%) | 3 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 4 (2.9%) | 4 | 3 (2.3%) | 4
MACROGOL | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
MAGNESIUM SULFATE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
MULTIVITAMINS | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
ONDANSETRON | 5 (6.9%) | 6 | 2 (3.2%) | 2 | 6 (10.9%) | 6 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 12 (8.6%) | 13 | 4 (3%) | 4
PANTOPRAZOLE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
PANTOPRAZOLE SODIUM SESQUIHYDRATE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
POTASSIUM CHLORIDE | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
POTASSIUM PHOSPHATE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
PYRIDOXINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
RANITIDINE | 7 (9.7%) | 9 | 10 (16.1%) | 12 | 5 (9.1%) | 6 | 5 (8.3%) | 6 | 2 (15.4%) | 3 | 0 | 0 | 14 (10%) | 18 | 15 (11.3%) | 18
SENNOSIDE A+B | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
SODIUM BICARBONATE | 1 (1.4%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 4 | 0 | 0
SODIUM BICARBONATE | 1 (1.4%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 2
ANTIINFECTIVES FOR SYSTEMIC USE | 35 (48.6%) | 87 | 39 (62.9%) | 99 | 17 (30.9%) | 51 | 11 (18.3%) | 39 | 4 (30.8%) | 9 | 0 | 0 | 56 (40%) | 147 | 50 (37.6%) | 138
ACICLOVIR | 12 (16.7%) | 16 | 11 (17.7%) | 17 | 2 (3.6%) | 3 | 2 (3.3%) | 4 | 0 | 0 | 0 | 0 | 14 (10%) | 19 | 13 (9.8%) | 21
AMOXICILLIN | 0 | 0 | 3 (4.8%) | 3 | 2 (3.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 3 (2.3%) | 3
AMPICILLIN | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
AZITHROMYCIN | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2
BACTRIM | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
CEFAZOLIN | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
CEFAZOLIN SODIUM | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
CEFEPIME | 1 (1.4%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 3 | 0 | 0
CEFOTAXIME | 10 (13.9%) | 13 | 13 (21%) | 22 | 4 (7.3%) | 7 | 4 (6.7%) | 7 | 2 (15.4%) | 2 | 0 | 0 | 16 (11.4%) | 22 | 17 (12.8%) | 29
CEFTAZIDIME | 0 | 0 | 0 | 0 | 2 (3.6%) | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 4 | 0 | 0
CEFTRIAXONE | 24 (33.3%) | 29 | 20 (32.3%) | 26 | 6 (10.9%) | 7 | 6 (10%) | 8 | 0 | 0 | 0 | 0 | 30 (21.4%) | 36 | 26 (19.5%) | 34
CEFTRIAXONE SODIUM | 2 (2.8%) | 2 | 3 (4.8%) | 3 | 0 | 0 | 3 (5%) | 3 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 3 | 6 (4.5%) | 6
CEFUROXIME | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
CIPROFLOXACIN | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
CLINDAMYCIN | 1 (1.4%) | 2 | 1 (1.6%) | 4 | 4 (7.3%) | 4 | 2 (3.3%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 6 (4.3%) | 7 | 3 (2.3%) | 6
GENTAMICIN | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
LAMIVUDINE | 0 | 0 | 0 | 0 | 1 (1.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 2 | 0 | 0
LOPINAVIR W/RITONAVIR | 0 | 0 | 0 | 0 | 1 (1.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 2 | 0 | 0
NAFCILLIN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
OSELTAMIVIR | 1 (1.4%) | 1 | 1 (1.6%) | 2 | 2 (3.6%) | 2 | 3 (5%) | 3 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 4 (3%) | 5
TOBRAMYCIN | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
VANCOMYCIN | 12 (16.7%) | 17 | 13 (21%) | 20 | 7 (12.7%) | 13 | 4 (6.7%) | 9 | 3 (23.1%) | 4 | 0 | 0 | 22 (15.7%) | 34 | 17 (12.8%) | 29
ZIDOVUDINE | 0 | 0 | 0 | 0 | 1 (1.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 2 | 0 | 0
ANTIPARASITIC PRODUCTS, INSECTICIDES AND REPELLENTS | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
PERMETHRIN | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
BLOOD AND BLOOD FORMING ORGANS | 7 (9.7%) | 13 | 4 (6.5%) | 7 | 3 (5.5%) | 3 | 5 (8.3%) | 7 | 2 (15.4%) | 3 | 0 | 0 | 12 (8.6%) | 19 | 9 (6.8%) | 14
CALCIUM CHLORIDE | 1 (1.4%) | 2 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 3 (2.1%) | 4 | 0 | 0
CRYOPRECIPITATE | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
FERROUS SULFATE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
HEPARIN | 5 (6.9%) | 6 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 3 (5%) | 3 | 1 (7.7%) | 1 | 0 | 0 | 7 (5%) | 8 | 5 (3.8%) | 5
MANNITOL | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
NORMOSOL | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
PHYTOMENADIONE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
PLASMA | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
PLATELETS | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
RED BLOOD CELLS | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
SODIUM BICARBONATE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 4 | 0 | 0
SODIUM BICARBONATE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 2 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 2
SODIUM CHLORIDE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
THROMBIN | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
CARDIOVASCULAR SYSTEM | 4 (5.6%) | 43 | 3 (4.8%) | 3 | 2 (3.6%) | 2 | 5 (8.3%) | 15 | 4 (30.8%) | 9 | 0 | 0 | 10 (7.1%) | 54 | 8 (6%) | 18
AMLODIPINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
ATROPINE | 2 (2.8%) | 2 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 8 (5.7%) | 8 | 7 (5.3%) | 7
ATROPINE | 2 (2.8%) | 2 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 3 (2.3%) | 3
CLONIDINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (15.4%) | 3 | 0 | 0 | 2 (1.4%) | 3 | 0 | 0
DOPAMINE | 3 (4.2%) | 12 | 0 | 0 | 0 | 0 | 3 (5%) | 9 | 1 (7.7%) | 1 | 0 | 0 | 4 (2.9%) | 13 | 3 (2.3%) | 9
EPINEPHRINE | 2 (2.8%) | 20 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 2 (3.3%) | 4 | 0 | 0 | 0 | 0 | 3 (2.1%) | 21 | 3 (2.3%) | 5
EPINEPHRINE | 2 (2.8%) | 20 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 2 (3.3%) | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
FUROSEMIDE | 1 (1.4%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 3 | 0 | 0
GUANFACINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
GUANFACINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
HYDRALAZINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 2 | 0 | 0 | 1 (0.7%) | 2 | 0 | 0
LABETALOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
MILRINONE | 2 (2.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
NICARDIPINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
NOREPINEPHRIN | 2 (2.8%) | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 4 | 0 | 0
DERMATOLOGICALS | 13 (18.1%) | 17 | 13 (21%) | 15 | 4 (7.3%) | 5 | 2 (3.3%) | 5 | 1 (7.7%) | 1 | 2 (18.2%) | 2 | 18 (12.9%) | 23 | 17 (12.8%) | 22
BACITRACIN | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 2 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 2 (1.4%) | 3 | 1 (0.8%) | 1
DOCOSANOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
EMOLLIENTS AND PROTECTIVES | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 2
HYDROCORTISONE | 3 (4.2%) | 4 | 0 | 0 | 0 | 0 | 2 (3.3%) | 3 | 0 | 0 | 0 | 0 | 3 (2.1%) | 4 | 2 (1.5%) | 3
IODINE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
KETOCONAZOLE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
LIDOCAINE | 9 (12.5%) | 9 | 8 (12.9%) | 8 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 10 (7.1%) | 10 | 9 (6.8%) | 9
LIDOCAINE | 9 (12.5%) | 9 | 8 (12.9%) | 8 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 17 (12.1%) | 21 | 25 (18.8%) | 28
NYSTATIN | 1 (1.4%) | 1 | 2 (3.2%) | 2 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 2 (1.5%) | 2
POVIDONE-IODINE | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
PROCTOFOAM /00646301/ | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
ZINC OXIDE | 1 (1.4%) | 1 | 1 (1.6%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 2
GENITO URINARY SYSTEM AND SEX HORMONES | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
OXYBUTYNIN | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
MUSCULO-SKELETAL SYSTEM | 30 (41.7%) | 53 | 25 (40.3%) | 40 | 17 (30.9%) | 42 | 16 (26.7%) | 24 | 3 (23.1%) | 4 | 0 | 0 | 50 (35.7%) | 99 | 41 (30.8%) | 64
BACLOFEN | 0 | 0 | 1 (1.6%) | 1 | 2 (3.6%) | 3 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 2 (1.4%) | 3 | 3 (2.3%) | 3
CISATRACURIUM | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
IBUPROFEN | 20 (27.8%) | 28 | 12 (19.4%) | 14 | 4 (7.3%) | 5 | 5 (8.3%) | 5 | 1 (7.7%) | 1 | 0 | 0 | 25 (17.9%) | 34 | 17 (12.8%) | 19
KETOROLAC | 1 (1.4%) | 1 | 0 | 0 | 2 (3.6%) | 2 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 4 (2.9%) | 4 | 0 | 0
ROCURONIUM | 6 (8.3%) | 13 | 11 (17.7%) | 13 | 7 (12.7%) | 7 | 7 (11.7%) | 7 | 1 (7.7%) | 2 | 0 | 0 | 14 (10%) | 22 | 18 (13.5%) | 20
SUXAMETHONIUM CHLORIDE | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 2 (3.6%) | 3 | 2 (3.3%) | 2 | 0 | 0 | 0 | 0 | 3 (2.1%) | 4 | 3 (2.3%) | 3
TIZANIDINE HYDROCHLORIDE | 1 (1.4%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 2 | 0 | 0
VECURONIUM | 6 (8.3%) | 8 | 5 (8.1%) | 10 | 5 (9.1%) | 22 | 3 (5%) | 8 | 0 | 0 | 0 | 0 | 11 (7.9%) | 30 | 8 (6%) | 18
NERVOUS SYSTEM | 50 (69.4%) | 168 | 48 (77.4%) | 176 | 24 (43.6%) | 108 | 28 (46.7%) | 76 | 3 (23.1%) | 6 | 4 (36.4%) | 8 | 77 (55%) | 282 | 80 (60.2%) | 260
BUPIVACAINE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
CITALOPRAM | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
DESFLURANE | 1 (1.4%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 3 | 0 | 0
DEXMEDETOMIDINE | 0 | 0 | 2 (3.2%) | 5 | 0 | 0 | 2 (3.3%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 4 (3%) | 8
DEXMEDETOMIDINE HYDROCHLORIDE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
DEXMETHYLPHENIDATE HYDROCHLORIDE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
EMLA /00675501/ | 2 (2.8%) | 2 | 2 (3.2%) | 2 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 3 (2.3%) | 3
ETOMIDATE | 5 (6.9%) | 5 | 6 (9.7%) | 8 | 5 (9.1%) | 5 | 4 (6.7%) | 4 | 0 | 0 | 0 | 0 | 10 (7.1%) | 10 | 10 (7.5%) | 12
FENTANYL | 7 (9.7%) | 25 | 13 (21%) | 42 | 5 (9.1%) | 17 | 7 (11.7%) | 13 | 2 (15.4%) | 3 | 0 | 0 | 14 (10%) | 45 | 20 (15%) | 55
GUANFACINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
GUANFACINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
ISOFLURANE | 1 (1.4%) | 4 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 4 | 1 (0.8%) | 1
KETAMINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (0.8%) | 1
LEVETIRACETAM | 1 (1.4%) | 1 | 1 (1.6%) | 2 | 0 | 0 | 1 (1.7%) | 2 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 4
LIDOCAINE | 9 (12.5%) | 10 | 14 (22.6%) | 16 | 7 (12.7%) | 10 | 10 (16.7%) | 11 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 10 (7.1%) | 10 | 9 (6.8%) | 9
LIDOCAINE | 9 (12.5%) | 10 | 14 (22.6%) | 16 | 7 (12.7%) | 10 | 10 (16.7%) | 11 | 1 (7.7%) | 1 | 1 (9.1%) | 1 | 17 (12.1%) | 21 | 25 (18.8%) | 28
LORAZEPAM | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 2 | 1 (0.8%) | 1
MELATONIN | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
METHOHEXITAL SODIUM | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
MIDAZOLAM | 4 (5.6%) | 18 | 5 (8.1%) | 13 | 5 (9.1%) | 12 | 2 (3.3%) | 5 | 0 | 0 | 0 | 0 | 9 (6.4%) | 30 | 7 (5.3%) | 18
MORPHINE | 3 (4.2%) | 17 | 1 (1.6%) | 2 | 2 (3.6%) | 21 | 6 (10%) | 12 | 0 | 0 | 1 (9.1%) | 1 | 5 (3.6%) | 38 | 8 (6%) | 15
NEOSTIGMINE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
NITROUS OXIDE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
PARACETAMOL | 39 (54.2%) | 70 | 45 (72.6%) | 79 | 20 (36.4%) | 33 | 16 (26.7%) | 20 | 1 (7.7%) | 2 | 2 (18.2%) | 2 | 60 (42.9%) | 105 | 63 (47.4%) | 101
PENTOBARBITAL | 1 (1.4%) | 1 | 1 (1.6%) | 2 | 1 (1.8%) | 2 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 2 (1.4%) | 3 | 2 (1.5%) | 3
PENTOBARBITAL SODIUM | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
PROPOFOL | 4 (5.6%) | 5 | 0 | 0 | 1 (1.8%) | 5 | 2 (3.3%) | 3 | 0 | 0 | 0 | 0 | 5 (3.6%) | 10 | 2 (1.5%) | 3
THIOPENTAL | 0 | 0 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
VALPROIC ACID | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
ZONISAMIDE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
RESPIRATORY SYSTEM | 8 (11.1%) | 14 | 9 (14.5%) | 10 | 8 (14.5%) | 13 | 8 (13.3%) | 18 | 0 | 0 | 0 | 0 | 16 (11.4%) | 27 | 17 (12.8%) | 28
BENADRYL /01563701/ | 3 (4.2%) | 3 | 2 (3.2%) | 3 | 1 (1.8%) | 1 | 2 (3.3%) | 3 | 0 | 0 | 0 | 0 | 4 (2.9%) | 4 | 4 (3%) | 6
BUDESONIDE | 1 (1.4%) | 1 | 1 (1.6%) | 1 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 1 (0.8%) | 1
CETIRIZINE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 1 (0.8%) | 1
COMBIVENT | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
EPINEPHRINE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (2.1%) | 21 | 3 (2.3%) | 5
EPINEPHRINE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
FLUTICASONE | 0 | 0 | 0 | 0 | 2 (3.6%) | 2 | 5 (8.3%) | 6 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 5 (3.8%) | 6
IPRATROPIUM | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
IPRATROPIUM BROMIDE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
LEVOSALBUTAMOL HYDROCHLORIDE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
LORATADINE | 1 (1.4%) | 1 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.4%) | 2 | 0 | 0
MOMETASONE | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
MONTELUKAST | 0 | 0 | 0 | 0 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
MONTELUKAST SODIUM | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
NITRIC OXIDE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
RACEPINEFRINE | 0 | 0 | 4 (6.5%) | 4 | 1 (1.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 4 (3%) | 4
SALBUTAMOL | 5 (6.9%) | 8 | 1 (1.6%) | 1 | 3 (5.5%) | 3 | 1 (1.7%) | 2 | 0 | 0 | 0 | 0 | 8 (5.7%) | 11 | 2 (1.5%) | 3
SALMETEROL | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
SERETIDE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
SENSORY ORGANS | 1 (1.4%) | 2 | 3 (4.8%) | 3 | 1 (1.8%) | 1 | 2 (3.3%) | 2 | 3 (23.1%) | 3 | 0 | 0 | 5 (3.6%) | 6 | 5 (3.8%) | 5
ERYTHROMYCIN | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
LACRI-LUBE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
OCULAR LUBRICANT /01768801/ | 0 | 0 | 3 (4.8%) | 3 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 2 (15.4%) | 2 | 0 | 0 | 3 (2.1%) | 3 | 4 (3%) | 4
POLYMYXIN B W/TRIMETHOPRIM | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
TIMOLOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
SYSTEMIC HORMONAL PREPARATIONS, EXCL. SEX HORMONES AND INSULINS | 3 (4.2%) | 3 | 5 (8.1%) | 7 | 1 (1.8%) | 1 | 3 (5%) | 6 | 1 (7.7%) | 1 | 0 | 0 | 5 (3.6%) | 5 | 8 (6%) | 13
DEXAMETHASONE | 2 (2.8%) | 2 | 4 (6.5%) | 6 | 1 (1.8%) | 1 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 3 (2.1%) | 3 | 5 (3.8%) | 7
METHYLPREDNISOLONE | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 1 (1.7%) | 1 | 1 (7.7%) | 1 | 0 | 0 | 1 (0.7%) | 1 | 2 (1.5%) | 2
PREDNISONE | 1 (1.4%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 1 | 0 | 0
VASOPRESSIN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 4
VARIOUS | 1 (1.4%) | 3 | 3 (4.8%) | 3 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 1 (0.7%) | 3 | 4 (3%) | 4
BARIUM SULFATE | 1 (1.4%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.7%) | 3 | 0 | 0
GADOTERIDOL | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.7%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
IOPAMIDOL | 0 | 0 | 1 (1.6%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.8%) | 1
MEGLUMINE GADOPENTETATE | 0 | 0 | 2 (3.2%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (1.5%) | 2

Note: The percentages are based on the total number of enrolled participants in each treatment group or total.

Participants are counted once for each medication before study dose and once for each medication after study dose.

Table 14.1.8 Summary of Doses by Age Stratum and Treatment Group ITT population

| 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=72) | Lorazepam (N=62) | Diazepam (N=55) | Lorazepam (N=60) | Diazepam (N=13) | Lorazepam (N=11) | Diazepam (N=140) | Lorazepam (N=133)
First Dose
N | 71 | 62 | 55 | 60 | 13 | 11 | 139 | 133
Mean (SD) | 0.4 (0.1) | 0.5 (0.2) | 0.9 (0.4) | 0.9 (0.4) | 1.5 (0.1) | 1.6 (0.1) | 0.7 (0.4) | 0.7 (0.4)
Median (Min-Max) | 0.4 (0.2 – 0.9) | 0.4 (0.2 – 2.0) | 0.8 (0.4 – 1.6) | 0.8 (0.4 – 1.6) | 1.6 (1.1 – 1.6) | 1.6 (1.4 – 1.6) | 0.5 (0.2 – 1.6) | 0.5 (0.2 – 2.0)
Second Dose
N | 18 | 17 | 7 | 11 | 0 | 1 | 25 | 29
Mean (SD) | 0.2 (0.1) | 0.2 (0.1) | 0.5 (0.2) | 0.6 (0.2) | | 0.8 | 0.3 (0.2) | 0.4 (0.2)
Median (Min-Max) | 0.2 (0.2 – 0.5) | 0.2 (0.1 – 0.4) | 0.4 (0.3 – 0.7) | 0.6 (0.2 – 0.8) | | 0.8 | 0.3 (0.2 – 0.7) | 0.3 (0.1 – 0.8)
Third Dose
N | 4 | 7 | 0 | 2 | 0 | 0 | 4 | 9
Mean (SD) | 176.3 (123.5) | 235.7 (43.9) | | 560.0 (84.9) | | | 176.3 (123.5) | 307.8 (151.0)
Median (Min-Max) | 200.0 (5.0 – 300.0) | 240.0 (150.0 – 300.0) | | 560.0 (500.0 – 620.0) | | | 200.0 (5.0 – 300.0) | 240.0 (150.0 – 620.0)
2nd Line Medications
Fos-phenytoin | 17 (23.6%) | 16 (25.8%) | 7 (12.7%) | 4 (6.7%) | 1 (7.7%) | 0 | 25 (17.9%) | 20 (15.0%)
Phenytoin | 1 (1.4%) | 3 (4.8%) | 1 (1.8%) | 1 (1.7%) | 0 | 0 | 2 (1.4%) | 4 (3.0%)
Phenobarbital | 1 (1.4%) | 4 (6.5%) | 1 (1.8%) | 3 (5.0%) | 0 | 0 | 2 (1.4%) | 7 (5.3%)

Note: N= Number of ITT populations.

Table 14.2.1.1 Summary of Primary Efficacy Endpoint by Treatment Group MITT population

| Diazepam (N=131) | Lorazepam (N=127) | Total (N=258) | P value^2^
Primary Efficacy Endpoint^1^ | 93 ( 71.0%) | 94 ( 74.0%) | 187 ( 72.5%) | 0.6924

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and without ▬ randomization errors.

1 Proportion of participants who have both (1) a cessation of convulsions within 10 minutes of the initial administration of the study drug and (2) a sustained absence of convulsions for 30 minutes from the initial administration of the study drug.

2 p-value is obtained from logistic legression model by treatment groups and age groups as independent factors.

Table 14.2.1.1.S Summary of Primary Efficacy Endpoint by Treatment Group Sensitivity Analysis

| Diazepam (N=140) | Lorazepam (N=133) | Total (N=273) | P value^2^
Primary Efficacy Endpoint^1^ | 101 ( 72.1%) | 97 ( 72.9%) | 198 ( 72.5%) | 0.9953

Note: Sensitivity population (ITT) includes all MITT population (258 participants) and qualified ▬ randomization errors (15 participants meeting the MITT criteria).

1 Proportion of participants who have both (1) a cessation of convulsions within 10 minutes of the initial administration of the study drug and (2) a sustained absence of convulsions for 30 minutes from the initial administration of the study drug.

2 p-value is obtained from logistic legression model by treatment groups and age groups as independent factors.

Table 14.2.1.2 Summary of Primary Efficacy Endpoint by Treatment Group Per Protocol population

| Diazepam (N=102) | Lorazepam (N=107) | Total (N=209) | P value^2^
Primary Efficacy Endpoint^1^ | 78 ( 76.5%) | 85 ( 79.4%) | 163 ( 78.0%) | 0.6609

Note: Per Protocol (PP) population includes all randomized participants with confirmed Status Epilepticus and exclude subjects with Protocol deviation.

1 Proportion of participants who have both (1) a cessation of convulsions within 10 minutes of the initial administration of the study drug and (2) a sustained absence of convulsions for 30 minutes from the initial administration of the study drug.

2 p-value is obtained from logistic legression model by treatment groups and age groups as independent factors.

Table 14.2.1.2.S Summary of Primary Efficacy Endpoint by Treatment Group Per Protocol population Sensitivity Analysis

| Diazepam (N=111) | Lorazepam (N=111) | Total (N=222) | P value^2^
Primary Efficacy Endpoint^1^ | 86 ( 77.5%) | 87 ( 78.4%) | 173 ( 77.9%) | 0.9212

Note: Sensitivity analysis on Per Protocol (PP) population includes all randomized ITT population (273 participants) and excludes participants who had any major protocol deviations.

1 Proportion of participants who have both (1) a cessation of convulsions within 10 minutes of the initial administration of the study drug and (2) a sustained absence of convulsions for 30 minutes from the initial administration of the study drug.

2 p-value is obtained from logistic legression model by treatment groups and age groups as independent factors.

Table 14.2.2.1 Summary of Secondary Efficacy Endpoints by Treatment Group MITT Population

| Diazepam (N=131) | Lorazepam (N=127) | Total (N=258) | P value^5^
Sustained absence of convulsions for 30 minutes^1^ | 86 (65.6%) | 86 (67.7%) | 172 (66.7%) | 0.6959
Sustained absence of convulsions for 60 minutes^2^ | 83 (63.4%) | 86 (67.7%) | 169 (65.5%) | 0.2054
Partcipants requiring a second dose of study medication^3^ | 41 (31.3%) | 41 (32.3%) | 82 (31.8%) | 0.8057
Partcipants who require only a single dose of study drug and have no recurring seizures within 30 minutes^4^ | 81 (61.8%) | 79 (62.2%) | 160 (62.0%) | 0.7399

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and without ▬ randomization errors.

1 Proportion of partcipants with a sustained absence of convulsions for 30 minutes.

2 Proportion of partcipants with a sustained absence of convulsions for 60 minutes.

3 Proportion of partcipants requiring a second dose of study medication.

4 Proportion of partcipants who require only a single dose of study drug and have no recurring seizures within 30 minutes.

5 p-values are obtained from Cochran-Mental-Haenzel Test.

Table 14.2.2.1.S Summary of Secondary Efficacy Endpoints by Treatment Group Senstivity Analysis

| Diazepam (N=140) | Lorazepam (N=133) | Total (N=273) | P value^5^
Sustained absence of convulsions for 30 minutes^1^ | 93 (66.4%) | 87 (65.4%) | 180 (65.9%) | 0.7885
Sustained absence of convulsions for 60 minutes^2^ | 90 (64.3%) | 87 (65.4%) | 177 (64.8%) | 0.2610
Partcipants requiring a second dose of study medication^3^ | 42 (30.0%) | 44 (33.1%) | 86 (31.5%) | 0.5527
Partcipants who require only a single dose of study drug and have no recurring seizures within 30 minutes^4^ | 87 (62.1%) | 80 (60.2%) | 167 (61.2%) | 0.6528

Note: Sensitivity population (ITT) includes all MITT population (258 participants) and qualified ▬ randomization errors (15 participants meeting the MITT criteria).

1 Proportion of partcipants with a sustained absence of convulsions for 30 minutes.

2 Proportion of partcipants with a sustained absence of convulsions for 60 minutes.

3 Proportion of partcipants requiring a second dose of study medication.

4 Proportion of partcipants who require only a single dose of study drug and have no recurring seizures within 30 minutes.

5 p-values are obtained from Cochran-Mental-Haenzel Test.

Table 14.2.2.2.A Summary of Secondary Efficacy Endpoint (Time to Cessation of Initial Convulsion) by Treatment Group MITT population

| Diazepam (N=131) | Lorazepam (N=127)
Number of Participants
Num of Censored Participants | 16 (12.2%) | 17 (13.4%)
Num of Non Censored Participants | 115 (87.8%) | 110 (86.6%)
Time to Cessation of Initial Convulsion in mins
Median (95% CI) | 1.0 (1.00, 2.00) | 2.0 (1.00, 2.00)
25% Percentile (95% CI) | 0.0 (0.00, 1.00) | 1.0 (0.00, 1.00)
75% Percentile (95% CI) | 5.0 (3.00, 10.00) | 7.0 (4.00, 12.00)
Range | 0, 1285 | 0, 366
Cox Proportional Hazards Regression Stratified Analysis Stratified by Age Group
Hazard Ratio (Relative to lorazepam) | | 1.13
(95% CI) | | (0.86, 1.47)
p value (Log Rank) | | 0.3867

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and without ▬ randomization errors.

1 Number of minutes from the end of the first administration of the study drug to the cessation of the initial convulsion.

Table 14.2.2.2.A.S Summary of Secondary Efficacy Endpoint (Time to Cessation of Initial Convulsion) by Treatment Group Senstivity Analysis

| Diazepam (N=140) | Lorazepam (N=133)
Number of Participants
Num of Censored Participants | 16 (11.4%) | 19 (14.3%)
Num of Non Censored Participants | 124 (88.6%) | 114 (85.7%)
Time to Cessation of Initial Convulsion in mins
Median (95% CI) | 1.0 (1.00, 2.00) | 2.0 (1.00, 2.00)
25% Percentile (95% CI) | 0.5 (0.00, 1.00) | 1.0 (0.00, 1.00)
75% Percentile (95% CI) | 5.0 (3.00, 10.00) | 8.0 (4.00, 13.00)
Range | 0, 1285 | 0, 366
Cox Proportional Hazards Regression Stratified Analysis Stratified by Age Group
Hazard Ratio (Relative to lorazepam) | | 1.17
(95% CI) | | (0.90, 1.52)
p value (Log Rank) | | 0.2374

Note: Sensitivity population (ITT) includes all MITT population (258 participants) and qualified ▬ randomization errors (15 participants meeting the MITT criteria).

1 Number of minutes from the end of the first administration of the study drug to the cessation of the initial convulsion.

Table 14.2.2.2.B Summary of Secondary Efficacy Endpoint (Time to New Seizure Activity) by Treatment Group MITT population

| Diazepam (N=131) | Lorazepam (N=127)
Number of Participants
Num of Censored Participants | 95 (72.5%) | 102 (80.3%)
Num of Participants with New Seizure Activity | 36 (27.5%) | 25 (19.7%)
Time to New Seizure Activity in mins
Median (95% CI) | . | .
25% Percentile (95% CI) | 127.0 (32.00, .) | . (89.00, .)
75% Percentile (95% CI) | . | .
Range | 1,1440 | 3, 1440
Cox Proportional Hazards Regression
Hazard Ratio (Relative to Treatment Lorazepam) | | 1.51
(95% CI) | | (0.90, 2.53)
p value (Log Rank) | | 0.1190

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and without ▬ randomization errors.

1 Number of minutes from study drug administration until new seizure activity is observed(within 24Hrs).

Table 14.2.2.2.B.S Summary of Secondary Efficacy Endpoint (Time to New Seizure Activity) by Treatment Group Senstivity Analysis

| Diazepam (N=140) | Lorazepam (N=133)
Number of Participants | . | .
Num of Censored Participants | 101 (72.1%) | 106 (79.7%)
Num of Participants with New Seizure Activity | 39 (27.9%) | 27 (20.3%)
Time to New Seizure Activity in mins
Median (95% CI) | . | .
25% Percentile (95% CI) | 124.0 (32.00, .) | . (29.00, .)
75% Percentile (95% CI)
Range | 1,1440 | 2, 1440
Cox Proportional Hazards Regression
Hazard Ratio (Relative to lorazepam) (95% CI) | | 1.45 (0.88, 2.38)
p value (Log Rank) | | 0.1458

Note: Sensitivity population (ITT) includes all MITT population (258 participants) and qualified ▬ randomization errors (15 participants meeting the MITT criteria).

Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and with ▬ randomization errors.

1 Number of minutes from study drug administration until new seizure activity is observed(within 24Hrs).

Table 14.2.2.2.C Summary of Secondary Efficacy Endpoint (Time to Return to Baseline Function) by Treatment Group MITT Population

| Diazepam (N=131) | Lorazepam (N=127)
Number of Participants
Num of censored Participants | 59 (45.0%) | 82 (64.6%)
Num of Participants Returned to Baseline | 72 (55.0%) | 45 (35.4%)
Time to return to baseline function in mins
Median (95% CI) | 120.0 (119.0, 125.0) | 239.0 (180.0, .)
25% Percentile (95% CI) | 66.0 (60.0, 108.0) | 121.0 (63.0, 173.0)
75% Percentile (95% CI) | 183.0 (163.0, 240.0) | .
Range | 0, 240 | 0, 240
Cox Proportional Hazards Regression
Hazard Ratio (Relative to Treatment Lorazepam) (95% CI) | | 2.18 (1.48, 3.20)
p value (Log Rank) | | <.0001

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and with ▬ randomization errors.

1 Time from completion of the initial dose of study medication administration to return to baseline functionality/mental status.

Table 14.2.2.2.C.S Summary of Secondary Efficacy Endpoint (Time to Return to Baseline function) by Treatment Group Senstivity Analysis

| Diazepam (N=140) | Lorazepam (N=133)
Number of Participants
Num of censored Participants | 62 (44.3%) | 86 (64.7%)
Num of Participants Returned to Baseline | 78 (55.7%) | 47 (35.3%)
Time to return to baseline function in mins
Median (95% CI) | 120.0 (118.0, 125.0) | 238.0 (180.0, 240.0)
25% Percentile (95% CI) | 60.0 (60.0, 77.0) | 120.0 (63.0, 165.0)
75% Percentile (95% CI) | 183.0 (168.0, 240.0)
Range | 0, 240 | 0, 240
Cox Proportional Hazards Regression
Hazard Ratio (Relative to lorazepam) (95% CI) | | 2.00 (1.38, 2.92)
p value (Log Rank) | | 0.0003

Note: Sensitivity population (ITT) includes all MITT population (258 participants) and qualified ▬ randomization errors (15 participants meeting the MITT criteria).

1 Time from completion of the initial dose of study medication administration to return to baseline functionality/mental status.

Table 14.2.2.3 Summary of Status Epilepticus Refractory to Benzodiazepines by Treatment Group MITT population

| Diazepam (N=131) | Lorazepam (N=127) | Total (N=258) | P value
Status Epilepticus refractory to benzodiazepines^1^ | 20 (15.3%) | 19 (15.0%) | 39 (15.1%) | 0.9453
Refractory Status Epilepticus terminated by second-line medication^2^ | 6 (30.0%) | 2 (10.5%) | 8 (20.5%) | 0.1373

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and without ▬ randomization errors.

1 The number and proportion of participants with status epilepticus refractory to benzodiazepines (FOS Phenytoin, Phenytoin & Phenobarbital).

2 The number and proportion of children in whom status epilepticus refractory to benzodiazepines is terminated by second-line medication.

Table 14.2.2.3.S Summary of Status Epilepticus Refractory to Benzodiazepines by Treatment Group Senstivity Analysis

| Diazepam (N=140) | Lorazepam (N=133) | Total (N=273) | P value
Status Epilepticus refractory to benzodiazepines^1^ | 21 (15.0%) | 21 (15.8%) | 42 (15.4%) | 0.8569
Refractory Status Epilepticus terminated by second-line medication^2^ | 6 (28.6%) | 3 (14.3%) | 9 (21.4%) | 0.2650

Note: Sensitivity population (ITT) includes all MITT population (258 participants) and qualified ▬ randomization errors (15 participants meeting the MITT criteria).

1 The number and proportion of participants with status epilepticus refractory to benzodiazepines (FOS Phenytoin, Phenytoin & Phenobarbital).

2 The number and proportion of children in whom status epilepticus refractory to benzodiazepines is terminated by second-line medication.

Table 14.2.2.4.A Summary of Risk Factors for Status Epilepticus Refractory to Benzodiazepines MITT Population

| Without Event (N=219) | With Event (N=39) | p value^1^
Treatment
Diazepam | 111 (50.7%) | 20 (51.3%) | 0.5922
Lorazepam | 108 (49.3%) | 19 (48.7%)
Age
3 mo - <3 yrs | 100 (45.7%) | 28 (71.8%) | 0.2102
3 yrs - <13 yrs | 99 (45.2%) | 9 (23.1%)
>13 yrs | 20 (9.1%) | 2 (5.1%)
Gender
Male | 107 (48.9%) | 20 (51.3%) | 0.5699
Female | 112 (51.1%) | 19 (48.7%)
Race
American Indian or Alaska Native | 2 (0.9%) | 0 | 0.7874
Asian | 5 (2.3%) | 2 (5.1%)
Black or African American | 82 (37.4%) | 9 (23.1%)
Native Hawaiian or Pacific Islander | 2 (0.9%) | 0
White or Caucasian | 109 (49.8%) | 21 (53.8%)
Other | 5 (2.3%) | 2 (5.1%)
Mixed | 12 (5.5%) | 4 (10.3%)
Not reported | 2 (0.9%) | 1 (2.6%)
Primary Etiology
Febrile | 68 (31.1%) | 19 (48.7%) | 0.2956
Low Levels of anti-epileptic drugs | 23 (10.5%) | 2 (5.1%)
Acute symptomatic | 27 (12.3%) | 10 (25.6%)
Remote symptomatic | 23 (10.5%) | 2 (5.1%)
Idiopathic | 65 (29.7%) | 6 (15.4%)
Other | 13 (5.9%) | 0
Length of Qualifying Seizure
N | 210 | 39 | 0.2580
Mean (SD) | 22.1 (32.8) | 30.2 (28.8)
Median (Min-Max) | 11.0 (0.0 – 300.0) | 23.0 (1.0 – 123.0)

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and with ▬ randomization errors.

1 P value is obtained from the multiple logistic regression analysis considering Race, Sex, Age Group, SE Etiology and SE Duration as risk factors for status epilepticus refractory to benzodiazepines endpoint.

Table 14.2.2.4.A.S Summary of Risk Factors for Status Epilepticus Refractory to Benzodiazepines Senstivity Analysis

| Without Event (N=231) | With Event (N=42) | p value^1^
Treatment
Diazepam | 119 (51.5%) | 21 (50.0%) | 0.4420
Lorazepam | 112 (48.5%) | 21 (50.0%)
Age
3 mo - <3 yrs | 104 (45.0%) | 30 (71.4%) | 0.1847
3 yrs - <13 yrs | 105 (45.5%) | 10 (23.8%)
>13 yrs | 22 (9.5%) | 2 (4.8%)
Gender
Male | 115 (49.8%) | 23 (54.8%) | 0.4201
Female | 116 (50.2%) | 19 (45.2%)
Race
American Indian or Alaska Native | 2 (0.9%) | 0 | 0.6516
Asian | 5 (2.2%) | 2 (4.8%)
Black or African American | 89 (38.5%) | 10 (23.8%)
Native Hawaiian or Pacific Islander | 2 (0.9%) | 0
White or Caucasian | 110 (47.6%) | 21 (50.0%)
Other | 7 (3.0%) | 3 (7.1%)
Mixed | 14 (6.1%) | 4 (9.5%)
Not reported | 2 (0.9%) | 2 (4.8%)
Primary Etiology
Febrile | 69 (29.9%) | 20 (47.6%) | 0.1868
Low Levels of anti-epileptic drugs | 23 (10.0%) | 2 (4.8%)
Acute symptomatic | 27 (11.7%) | 11 (26.2%)
Remote symptomatic | 25 (10.8%) | 2 (4.8%)
Idiopathic | 74 (32.0%) | 7 (16.7%)
Other | 13 (5.6%) | 0
Length of Qualifying Seizure
N | 222 | 42 | 0.3803
Mean (SD) | 22.6 (33.5) | 29.5 (28.1)
Median (Min-Max) | 11.0 (0.0 – 300.0) | 22.0 (1.0 – 123.0)

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and with ▬ randomization errors.

1 P value is obtained from the multiple logistic regression analysis considering Race, Sex, Age Group, SE Etiology and SE Duration as risk factors for status epilepticus refractory to benzodiazepines endpoint.

Table 14.2.2.5 Analysis of Dose-response Relationship for Second-line Medication MITT population

FOS Phenytoin | Diazepam (N=131) | Lorazepam (N=127) | Total (N=258)
Dose (mg/kg)
N | 15 | 12 | 27
Mean (SD) | 19.5 (3.9) | 20.8 (4.9) | 20.1 (4.4)
Median (Min-Max) | 20.0 (11.5 – 27.5) | 20.0 (15.0 – 30.0) | 20.0 (11.5 – 30.0)
Cessation of Seizure | 6/15 | 1/12 | 7/27

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and without ▬ randomization errors.

Table 14.2.2.5.S Analysis of Dose-response Relationship for Second-line Medication Senstivity Analysis

FOS Phenytoin | Diazepam (N=140) | Lorazepam (N=133) | Total (N=273)
Dose (mg/kg)
N | 16 | 14 | 30
Mean (SD) | 17.8 (5.6) | 20.3 (4.7) | 19.0 (5.3)
Median (Min-Max) | 20.0 (0.5 – 23.1) | 19.7 (15.0 – 30.0) | 20.0 (0.5 – 30.0)
Cessation of Seizure | 6/16 | 2/14 | 8/30

Note: Sensitivity population (ITT) includes all MITT population (258 participants) and qualified ▬ randomization errors (15 participants meeting the MITT criteria).

Table 14.2.2.6 Association of Adverse Events with second-line medication by usage MITT population

Second-line Medication Adverse event | Fos-Phenytoin | Phenytoin | Phenytoin and Fos-Phenytoin | Phenobarbital
Hypercarbia | 9/93(9.68%) | 4/29(13.8%) | 0/5(0.00%) | 1/31(3.23%)
Bradycardia | 0/93(0.00%) | 0/29(0.00%) | 0/5(0.00%) | 0/31(0.00%)
Hypoxemia | 6/93(6.45%) | 3/29(10.3%) | 1/5(20.0%) | 3/31(9.68%)
Hypotension | 13/93(14.0%) | 4/29(13.8%) | 0/5(0.00%) | 4/31(12.9%)
Respiratory depression | 27/93(29.0%) | 4/29(13.8%) | 2/5(40.0%) | 1/31(3.23%)

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and without ▬ randomization errors.

Table 14.2.2.7 Summary of Medications employed for Coma Induction by Treatment Group MITT population

Anit-Epileptic Medication | Diazepam (N=131) | Lorazepam (N=127) | Total (N=258)
MIDAZOLAM | 0 (0.0%) | 1 (0.8%) | 1 (0.4%)
PENTOBARBITAL | 0 (0.0%) | 1 (0.8%) | 1 (0.4%)

Note: Modified intent-to-treat (MITT) population includes all randomized participants with confirmed Status Epilepticus and without ▬ randomization errors.

Participants may be counted more than once in each Anti-epileptic Medication.

Table 14.3.1.1 Summary of Safety Endpoints by Treatment and Age Group Safety Population

| 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148) | P-value
Number of Randomizations | 77 | 71 | 68 | 63 | 17 | 14 | 162 | 148
Randomizations That Met Primary Safety Endpoint | 11 (14.3%) | 16 (22.5%) | 12 (17.6%) | 10 (15.9%) | 3 (17.6%) | 0 | 26 (16.0%) | 26 (17.6%) | 0.736
Randomizations That Met Secondary Safety Endpoints
Randomizations with at least one SAE | 22 (28.6%) | 27 (38.0%) | 17 (25.0%) | 17 (27.0%) | 4 (23.5%) | 1 (7.1%) | 43 (26.5%) | 45 (30.4%) | 0.466
Randomizations with Adverse Clinical Events | 57 (74.0%) | 58 (81.7%) | 54 (79.4%) | 51 (81.0%) | 11 (64.7%) | 9 (64.3%) | 122 (75.3%) | 118 (79.7%) | 0.369
Randomizations with Critical and Near Critical Adverse Events | 12 (15.6%) | 18 (25.4%) | 14 (20.6%) | 12 (19.0%) | 3 (17.6%) | 0 | 29 (17.9%) | 30 (20.3%) | 0.613
Randomizations with Respiratory Depression | 38 (49.4%) | 32 (45.1%) | 33 (48.5%) | 21 (33.3%) | 3 (17.6%) | 1 (7.1%) | 74 (45.7%) | 54 (36.5%) | 0.084
Randomizations with Sedation | 35 (45.5%) | 44 (62.0%) | 38 (55.9%) | 47 (74.6%) | 8 (47.1%) | 8 (57.1%) | 81 (50.0%) | 99 (66.9%) | 0.003

Note: The percentages are based on the total number of Randomizations in each treatment and age group.

Primary safety endpoint is defined as randomizations that experience severe or life-threatening respiratory depression within four hours of the initial administration of the study drug.

Adverse Clinical Event is defined as randomizations that experience any respiratory depression, bradycardia, hypotension, hypercapnia, hypoxia, aspiration, sedation or agitation.

Critical and Near Critical Adverse Event is defined as randomizations that experience any severe or life threatening respiratory depression, bradycardia or hypotension or experience ventricular dysrhythmia or cardiac arrest.

P-Value is calculated from CMH test, stratified by age group.

N= Number of Randomizations.

Table 14.3.1.2 Summary of Primary Safety Endpoint (Time to Severe or Life-threatening Respiratory Depression) by Treatment Group Safety Population

| Treatment
| Diazepam (N=162) | Lorazepam (N=148) | Total (N=310)
Number of Radomizations
Num of Censored Radomizations | 136 (84.0%) | 122 (82.4%) | 258 (83.2%)
Num of Non Censored Radomizations | 26 (16.0%) | 26 (17.6%) | 52 (16.8%)
Time to Severe or Life-threatening Respiratory Depression in mins
Median (95% CI) | . | .
25% Percentile (95% CI) | . | .
75% Percentile (95% CI) | . | .
Range | 0, 240 | 0, 240 | 0, 240
Stratified Analysis by age group and treatment
Hazard Ratio (Relative to lorazepam) (95% CI) | | 0.91 (0.53, 1.57)
p value (Log Rank) | | 0.7363

Note: The percentages are based on the total number of Randomizations in each treatment group.

Table 14.3.1.3 Summary of Safety Endpoints by Treatment and Age Group Per Protocol Population

| 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=48) | Lorazepam (N=48) | Diazepam (N=43) | Lorazepam (N=50) | Diazepam (N=11) | Lorazepam (N=9) | Diazepam (N=102) | Lorazepam (N=107) | P-value
Number of Randomizations | 48 | 48 | 43 | 50 | 11 | 9 | 102 | 107
Randomizations That Met Primary Safety Endpoint | 2 (4.2%) | 8 (16.7%) | 7 (16.3%) | 7 (14.0%) | 2 (18.2%) | 0 | 11 (10.8%) | 15 (14.0%) | 0.511
Randomizations That Met Secondary Safety Endpoints
Randomizations with at least one SAE | 8 (16.7%) | 15 (31.3%) | 11 (25.6%) | 13 (26.0%) | 3 (27.3%) | 1 (11.1%) | 22 (21.6%) | 29 (27.1%) | 0.370
Randomizations with Adverse Clinical Events | 32 (66.7%) | 40 (83.3%) | 35 (81.4%) | 42 (84.0%) | 8 (72.7%) | 6 (66.7%) | 75 (73.5%) | 88 (82.2%) | 0.151
Randomizations with Critical and Near Critical Adverse Events | 3 (6.3%) | 9 (18.8%) | 9 (20.9%) | 9 (18.0%) | 2 (18.2%) | 0 | 14 (13.7%) | 18 (16.8%) | 0.585
Randomizations with Respiratory Depression | 21 (43.8%) | 19 (39.6%) | 23 (53.5%) | 18 (36.0%) | 2 (18.2%) | 1 (11.1%) | 46 (45.1%) | 38 (35.5%) | 0.124
Randomizations with Sedation | 19 (39.6%) | 32 (66.7%) | 24 (55.8%) | 38 (76.0%) | 7 (63.6%) | 5 (55.6%) | 50 (49.0%) | 75 (70.1%) | 0.002

Note: The percentages are based on the total number of Randomizations in each treatment and age group.

Primary safety endpoint is defined as randomizations that experience severe or life-threatening respiratory depression within four hours of the initial administration of the study drug.

Adverse Clinical Event is defined as randomizations that experience any respiratory depression, bradycardia, hypotension, hypercapnia, hypoxia, aspiration, sedation or agitation.

Critical and Near Critical Adverse Event is defined as randomizations that experience any severe or life threatening respiratory depression, bradycardia or hypotension or experience ventricular dysrhythmia or cardiac arrest.

P-Value is calculated from CMH test, stratified by age group.

N= Number of Randomizations.

Table 14.3.1.4 Summary of Primary Safety Endpoint(Time to Severe or Life-threatening Respiratory Depression) by Treatment Group Per Protocol Population

| Treatment
| Diazepam (N=102) | Lorazepam (N=107) | Total (N=209)
Number of Radomizations
Num of Censored Radomizations | 91 (56.2%) | 92 (62.2%) | 183 (59.0%)
Num of Non Censored Radomizations | 11 (6.8%) | 15 (10.1%) | 26 (8.4%)
Time to Severe or Life-threatening Respiratory Depression in mins
Median (95% CI) | . | .
25% Percentile (95% CI) | . | .
75% Percentile (95% CI) | . | .
Range | 0, 240 | 0, 240 | 0, 240
Stratified Analysis by age group and treatment
Hazard Ratio (Relative to lorazepam) (95% CI) | | 0.78 (0.36, 1.71)
p value (Log Rank) | | 0.5360

Note: The percentages are based on the total number of Randomizations in each treatment group.

Table 14.3.2 Summary of Treatment-Emergent Adverse Events by Age Stratum and Treatment Group Safety Population

| 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Number of Events/Randomizations
Number of Treatment-Emergent Adverse Events | 154 | 175 | 155 | 137 | 38 | 23 | 347 | 335
Randomizations with at least one AE | 67 (87.0%) | 64 (90.1%) | 56 (82.4%) | 55 (87.3%) | 14 (82.4%) | 9 (64.3%) | 137 (84.6%) | 128 (86.5%)
Number of SAEs | 31 | 29 | 20 | 24 | 6 | 2 | 57 | 55
Randomizations with at least one SAE | 22 (28.6%) | 27 (38.0%) | 17 (25.0%) | 17 (27.0%) | 4 (23.5%) | 1 (7.1%) | 43 (26.5%) | 45 (30.4%)
Number of Treatment-Emergent Adverse Clinical Events | 105 | 117 | 129 | 109 | 23 | 13 | 257 | 239
Randomizations with Adverse Clinical Events | 57 (74.0%) | 58 (81.7%) | 54 (79.4%) | 51 (81.0%) | 11 (64.7%) | 9 (64.3%) | 122 (75.3%) | 118 (79.7%)
Number of Critical and Near Critical Adverse Events | 13 | 18 | 15 | 14 | 4 | 0 | 32 | 32
Randomizations with Critical and Near Critical Adverse Events | 12 (15.6%) | 18 (25.4%) | 14 (20.6%) | 12 (19.0%) | 3 (17.6%) | 0 | 29 (17.9%) | 30 (20.3%)
Severity (All AEs)
Mild | 100 | 110 | 100 | 86 | 25 | 18 | 225 | 214
Moderate | 23 | 36 | 33 | 28 | 7 | 5 | 63 | 69
Severe | 13 | 12 | 8 | 7 | 1 | 0 | 22 | 19
Life threatening | 18 | 17 | 14 | 15 | 4 | 0 | 36 | 32
Death | 0 | 0 | 0 | 1 | 1 | 0 | 1 | 1
Highest Severity Per Randomization
Mild | 35 (45.5%) | 25 (35.2%) | 25 (36.8%) | 28 (44.4%) | 9 (52.9%) | 7 (50.0%) | 69 (42.6%) | 60 (40.5%)
Moderate | 12 (15.6%) | 14 (19.7%) | 13 (19.1%) | 11 (17.5%) | 2 (11.8%) | 2 (14.3%) | 27 (16.7%) | 27 (18.2%)
Severe | 7 (9.1%) | 9 (12.7%) | 5 (7.4%) | 5 (7.9%) | 0 | 0 | 12 (7.4%) | 14 (9.5%)
Life threatening | 13 (16.9%) | 16 (22.5%) | 13 (19.1%) | 10 (15.9%) | 2 (11.8%) | 0 | 28 (17.3%) | 26 (17.6%)
Death | 0 | 0 | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 1 (0.6%) | 1 (0.7%)
Relationship (All AEs)
Unrelated | 46 | 52 | 30 | 26 | 12 | 9 | 88 | 87
Possibly related | 97 | 115 | 117 | 103 | 22 | 8 | 236 | 226
Probably related | 11 | 7 | 8 | 7 | 2 | 6 | 21 | 20
Definitely related | 0 | 1 | 0 | 1 | 2 | 0 | 2 | 2
Strongest Relationship Per Randomization
Unrelated | 8 (10.4%) | 5 (7.0%) | 3 (4.4%) | 3 (4.8%) | 3 (17.6%) | 1 (7.1%) | 14 (8.6%) | 9 (6.1%)
Possibly related | 51 (66.2%) | 51 (71.8%) | 46 (67.6%) | 46 (73.0%) | 7 (41.2%) | 3 (21.4%) | 104 (64.2%) | 100 (67.6%)
Probably related | 8 (10.4%) | 7 (9.9%) | 7 (10.3%) | 5 (7.9%) | 2 (11.8%) | 5 (35.7%) | 17 (10.5%) | 17 (11.5%)
Definitely related | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 2 (11.8%) | 0 | 2 (1.2%) | 2 (1.4%)
Severity (All SAEs)
Mild | 1 | 0 | 1 | 3 | 0 | 0 | 2 | 3
Moderate | 5 | 7 | 1 | 3 | 1 | 2 | 7 | 12
Severe | 7 | 5 | 4 | 2 | 0 | 0 | 11 | 7
Life threatening | 18 | 17 | 14 | 15 | 4 | 0 | 36 | 32
Death | 0 | 0 | 0 | 1 | 1 | 0 | 1 | 1
Relationship (All SAEs)
Unrelated | 16 | 9 | 8 | 9 | 2 | 1 | 26 | 19
Possibly related | 13 | 17 | 9 | 14 | 2 | 1 | 24 | 32
Probably related | 2 | 3 | 3 | 1 | 1 | 0 | 6 | 4
Definitely related | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0

Note: Mild events include both transient and mild severity.

N= Number of Randomizations.

Table 14.3.3.1 Treatment-Emergent Adverse Events by MedDRA System Organ Class, Preferred Term, Age Stratum and Treatment Group Safety Population

| 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Blood and lymphatic system disorders | 3 (3.9%) | 0 | 1 (1.5%) | 2 (3.2%) | 0 | 0 | 4 (2.5%) | 2 (1.4%)
Coagulopathy | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Disseminated intravascular coagulation | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Leukocytosis | 2 (2.6%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 0
Cardiac disorders | 1 (1.3%) | 0 | 3 (4.4%) | 0 | 0 | 0 | 4 (2.5%) | 0
Bradycardia | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Cardio-respiratory arrest | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Tachycardia | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Congenital, familial and genetic disorders | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Sturge-Weber syndrome | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Ear and labyrinth disorders | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Tympanic membrane disorder | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Eye disorders | 0 | 0 | 0 | 1 (1.6%) | 0 | 1 (7.1%) | 0 | 2 (1.4%)
Dry eye | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Lagophthalmos | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Gastrointestinal disorders | 4 (5.2%) | 5 (7.0%) | 3 (4.4%) | 3 (4.8%) | 1 (5.9%) | 2 (14.3%) | 8 (4.9%) | 10 (6.8%)
Abdominal distension | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Vomiting | 4 (5.2%) | 5 (7.0%) | 2 (2.9%) | 3 (4.8%) | 1 (5.9%) | 2 (14.3%) | 7 (4.3%) | 10 (6.8%)
General disorders and administration site conditions | 3 (3.9%) | 6 (8.5%) | 3 (4.4%) | 2 (3.2%) | 2 (11.8%) | 1 (7.1%) | 8 (4.9%) | 9 (6.1%)
Asthenia | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Device malfunction | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Gait disturbance | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Irritability | 1 (1.3%) | 2 (2.8%) | 0 | 0 | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)
Pyrexia | 2 (2.6%) | 4 (5.6%) | 3 (4.4%) | 0 | 1 (5.9%) | 0 | 6 (3.7%) | 4 (2.7%)
Infections and infestations | 7 (9.1%) | 4 (5.6%) | 4 (5.9%) | 2 (3.2%) | 1 (5.9%) | 2 (14.3%) | 12 (7.4%) | 8 (5.4%)
Adenovirus infection | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
Bacteraemia | 2 (2.6%) | 0 | 0 | 0 | 0 | 0 | 2 (1.2%) | 0
Encephalitis viral | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Meningitis bacterial | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Oral herpes | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Pneumonia | 0 | 1 (1.4%) | 1 (1.5%) | 2 (3.2%) | 1 (5.9%) | 0 | 2 (1.2%) | 3 (2.0%)
Pyelonephritis | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Sepsis | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Septic shock | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Sinusitis | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Staphylococcal infection | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Upper respiratory tract infection | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Urinary tract infection | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Urinary tract infection pseudomonal | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Injury, poisoning and procedural complications | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Foreign body | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Investigations | 3 (3.9%) | 5 (7.0%) | 5 (7.4%) | 0 | 0 | 0 | 8 (4.9%) | 5 (3.4%)
Aspartate aminotransferase increased | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Blood glucose increased | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Blood pH decreased | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Blood pressure systolic decreased | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Body temperature increased | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Chest X-ray abnormal | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Haematocrit abnormal | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Haematocrit decreased | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Oxygen saturation increased | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Respiratory rate increased | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
White blood cell count increased | 0 | 3 (4.2%) | 0 | 0 | 0 | 0 | 0 | 3 (2.0%)
Metabolism and nutrition disorders | 2 (2.6%) | 2 (2.8%) | 0 | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 3 (2.0%)
Acidosis | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Hypocalcaemia | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Hypokalaemia | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Hypomagnesaemia | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Hyponatraemia | 0 | 2 (2.8%) | 0 | 0 | 0 | 0 | 0 | 2 (1.4%)
Lactic acidosis | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Metabolic acidosis | 2 (2.6%) | 0 | 0 | 0 | 0 | 0 | 2 (1.2%) | 0
Musculoskeletal and connective tissue disorders | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Arthralgia | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Medulloblastoma | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Nervous system disorders | 43 (55.8%) | 48 (67.6%) | 38 (55.9%) | 49 (77.8%) | 10 (58.8%) | 8 (57.1%) | 91 (56.2%) | 105 (70.9%)
Ataxia | 0 | 0 | 0 | 2 (3.2%) | 0 | 0 | 0 | 2 (1.4%)
Brain injury | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Cerebral ventricle dilatation | 1 (1.3%) | 0 | 0 | 0 | 1 (5.9%) | 0 | 2 (1.2%) | 0
Chorea | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Convulsion | 6 (7.8%) | 3 (4.2%) | 1 (1.5%) | 3 (4.8%) | 0 | 0 | 7 (4.3%) | 6 (4.1%)
Dizziness | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Extensor plantar response | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Febrile convulsion | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Headache | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Hemiparesis | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Hyporeflexia | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Infantile spasms | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Nervous system disorder | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Partial seizures | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Porencephaly | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Postictal paralysis | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Postictal state | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Sedation | 35 (45.5%) | 44 (62.0%) | 38 (55.9%) | 47 (74.6%) | 8 (47.1%) | 8 (57.1%) | 81 (50.0%) | 99 (66.9%)
Status epilepticus | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 0
Pregnancy, puerperium and perinatal conditions | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Eclampsia | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Psychiatric disorders | 3 (3.9%) | 3 (4.2%) | 3 (4.4%) | 3 (4.8%) | 0 | 1 (7.1%) | 6 (3.7%) | 7 (4.7%)
Agitation | 2 (2.6%) | 3 (4.2%) | 3 (4.4%) | 3 (4.8%) | 0 | 0 | 5 (3.1%) | 6 (4.1%)
Confusional state | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Mental status changes | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Respiratory, thoracic and mediastinal disorders | 46 (59.7%) | 46 (64.8%) | 40 (58.8%) | 37 (58.7%) | 8 (47.1%) | 3 (21.4%) | 94 (58.0%) | 86 (58.1%)
Apnoea | 2 (2.6%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 1 (0.7%)
Aspiration | 0 | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)
Atelectasis | 0 | 1 (1.4%) | 1 (1.5%) | 2 (3.2%) | 0 | 0 | 1 (0.6%) | 3 (2.0%)
Cough | 1 (1.3%) | 6 (8.5%) | 0 | 1 (1.6%) | 1 (5.9%) | 1 (7.1%) | 2 (1.2%) | 8 (5.4%)
Dyspnoea | 0 | 0 | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 2 (1.2%) | 1 (0.7%)
Hiccups | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Hypercapnia | 8 (10.4%) | 13 (18.3%) | 14 (20.6%) | 12 (19.0%) | 4 (23.5%) | 2 (14.3%) | 26 (16.0%) | 27 (18.2%)
Hypoventilation | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Hypoxia | 7 (9.1%) | 4 (5.6%) | 5 (7.4%) | 10 (15.9%) | 1 (5.9%) | 1 (7.1%) | 13 (8.0%) | 15 (10.1%)
Increased bronchial secretion | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Increased upper airway secretion | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Lung infiltration | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Nasal flaring | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
Pneumonia aspiration | 1 (1.3%) | 2 (2.8%) | 0 | 0 | 0 | 1 (7.1%) | 1 (0.6%) | 3 (2.0%)
Pulmonary oedema | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Respiration abnormal | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Respiratory acidosis | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 0 | 2 (1.4%)
Respiratory depression | 38 (49.4%) | 32 (45.1%) | 33 (48.5%) | 21 (33.3%) | 3 (17.6%) | 1 (7.1%) | 74 (45.7%) | 54 (36.5%)
Respiratory distress | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Stridor | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Use of accessory respiratory muscles | 1 (1.3%) | 3 (4.2%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 3 (2.0%)
Skin and subcutaneous tissue disorders | 2 (2.6%) | 2 (2.8%) | 0 | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 3 (2.0%)
Dermatitis diaper | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Rash | 1 (1.3%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
Vascular disorders | 4 (5.2%) | 7 (9.9%) | 11 (16.2%) | 7 (11.1%) | 6 (35.3%) | 0 | 21 (13.0%) | 14 (9.5%)
Hypertensive emergency | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Hypotension | 4 (5.2%) | 7 (9.9%) | 10 (14.7%) | 7 (11.1%) | 5 (29.4%) | 0 | 19 (11.7%) | 14 (9.5%)
Hypovolaemic shock | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0

Note: The percentages are based on the total number of randomizations in each treatment or total.

Randomizations are counted once at each SOC and PT levels.

N= Number of Randomizations.

Table 14.3.3.2 Treatment-Emergent Adverse Events by MedDRA System Organ Class, Preferred Term, Severity, Age Stratum and Treatment Group Safety Population

| | 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Severity | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Blood and lymphatic system disorders | Mild | 2 (2.6%) | 0 | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 1 (0.7%)
| Moderate | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
| Life threatening | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Coagulopathy | Mild | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Disseminated intravascular coagulation | Moderate | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
| Life threatening | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Leukocytosis | Mild | 2 (2.6%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 0
Cardiac disorders | Mild | 0 | 0 | 3 (4.4%) | 0 | 0 | 0 | 3 (1.9%) | 0
| Life threatening | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Bradycardia | Mild | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Cardio-respiratory arrest | Life threatening | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Tachycardia | Mild | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Congenital, familial and genetic disorders | Severe | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Sturge-Weber syndrome | Severe | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Ear and labyrinth disorders | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Tympanic membrane disorder | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Eye disorders | Mild | 0 | 0 | 0 | 1 (1.6%) | 0 | 1 (7.1%) | 0 | 2 (1.4%)
Dry eye | Mild | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Lagophthalmos | Mild | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Gastrointestinal disorders | Mild | 4 (5.2%) | 5 (7.0%) | 2 (2.9%) | 3 (4.8%) | 1 (5.9%) | 2 (14.3%) | 7 (4.3%) | 10 (6.8%)
| Moderate | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Abdominal distension | Mild | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Vomiting | Mild | 4 (5.2%) | 5 (7.0%) | 1 (1.5%) | 3 (4.8%) | 1 (5.9%) | 2 (14.3%) | 6 (3.7%) | 10 (6.8%)
| Moderate | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
General disorders and administration site conditions | Mild | 2 (2.6%) | 5 (7.0%) | 2 (2.9%) | 1 (1.6%) | 2 (11.8%) | 1 (7.1%) | 6 (3.7%) | 7 (4.7%)
| Moderate | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
| Severe | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Asthenia | Mild | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Device malfunction | Severe | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Gait disturbance | Mild | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Irritability | Mild | 1 (1.3%) | 2 (2.8%) | 0 | 0 | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)
Pyrexia | Mild | 1 (1.3%) | 3 (4.2%) | 2 (2.9%) | 0 | 1 (5.9%) | 0 | 4 (2.5%) | 3 (2.0%)
| Moderate | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
Infections and infestations | Mild | 3 (3.9%) | 1 (1.4%) | 2 (2.9%) | 0 | 0 | 2 (14.3%) | 5 (3.1%) | 3 (2.0%)
| Moderate | 2 (2.6%) | 3 (4.2%) | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 4 (2.5%) | 4 (2.7%)
| Severe | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 0
| Life threatening | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Adenovirus infection | Mild | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
Bacteraemia | Mild | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
| Moderate | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Encephalitis viral | Severe | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Meningitis bacterial | Severe | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Oral herpes | Mild | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Pneumonia | Moderate | 0 | 1 (1.4%) | 1 (1.5%) | 2 (3.2%) | 1 (5.9%) | 0 | 2 (1.2%) | 3 (2.0%)
Pyelonephritis | Moderate | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Sepsis | Life threatening | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Septic shock | Life threatening | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Sinusitis | Mild | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Staphylococcal infection | Mild | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
| Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Upper respiratory tract infection | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Urinary tract infection | Mild | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Urinary tract infection pseudomonal | Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Injury, poisoning and procedural complications | Mild | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Foreign body | Mild | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Investigations | Mild | 3 (3.9%) | 4 (5.6%) | 5 (7.4%) | 0 | 0 | 0 | 8 (4.9%) | 4 (2.7%)
| Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Aspartate aminotransferase increased | Mild | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Blood glucose increased | Mild | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Blood pH decreased | Mild | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Blood pressure systolic decreased | Mild | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Body temperature increased | Mild | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Chest X-ray abnormal | Mild | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Haematocrit abnormal | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Haematocrit decreased | Mild | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Oxygen saturation increased | Mild | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Respiratory rate increased | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
White blood cell count increased | Mild | 0 | 2 (2.8%) | 0 | 0 | 0 | 0 | 0 | 2 (1.4%)
| Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Metabolism and nutrition disorders | Mild | 1 (1.3%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Moderate | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Acidosis | Mild | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Hypocalcaemia | Mild | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Hypokalaemia | Moderate | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Hypomagnesaemia | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Hyponatraemia | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
| Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Lactic acidosis | Moderate | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Metabolic acidosis | Mild | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
| Moderate | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Musculoskeletal and connective tissue disorders | Mild | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Arthralgia | Mild | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | Death | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Medulloblastoma | Death | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Nervous system disorders | Mild | 30 (39.0%) | 28 (39.4%) | 28 (41.2%) | 36 (57.1%) | 9 (52.9%) | 8 (57.1%) | 67 (41.4%) | 72 (48.6%)
| Moderate | 8 (10.4%) | 18 (25.4%) | 9 (13.2%) | 10 (15.9%) | 1 (5.9%) | 0 | 18 (11.1%) | 28 (18.9%)
| Severe | 4 (5.2%) | 2 (2.8%) | 1 (1.5%) | 2 (3.2%) | 0 | 0 | 5 (3.1%) | 4 (2.7%)
| Life threatening | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
| Death | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Ataxia | Mild | 0 | 0 | 0 | 2 (3.2%) | 0 | 0 | 0 | 2 (1.4%)
Brain injury | Life threatening | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Cerebral ventricle dilatation | Mild | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
| Moderate | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Chorea | Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Convulsion | Mild | 2 (2.6%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 2 (1.4%)
| Moderate | 1 (1.3%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Severe | 3 (3.9%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 3 (1.9%) | 1 (0.7%)
| Death | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Dizziness | Mild | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Extensor plantar response | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Febrile convulsion | Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Headache | Mild | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Hemiparesis | Mild | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Hyporeflexia | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Infantile spasms | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Nervous system disorder | Moderate | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Partial seizures | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Porencephaly | Mild | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Postictal paralysis | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Postictal state | Mild | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Sedation | Mild | 29 (37.7%) | 28 (39.4%) | 28 (41.2%) | 35 (55.6%) | 7 (41.2%) | 8 (57.1%) | 64 (39.5%) | 71 (48.0%)
| Moderate | 5 (6.5%) | 15 (21.1%) | 10 (14.7%) | 10 (15.9%) | 1 (5.9%) | 0 | 16 (9.9%) | 25 (16.9%)
| Severe | 1 (1.3%) | 1 (1.4%) | 0 | 2 (3.2%) | 0 | 0 | 1 (0.6%) | 3 (2.0%)
Status epilepticus | Moderate | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
| Severe | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Pregnancy, puerperium and perinatal conditions | Moderate | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Eclampsia | Moderate | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Psychiatric disorders | Mild | 2 (2.6%) | 2 (2.8%) | 2 (2.9%) | 1 (1.6%) | 0 | 1 (7.1%) | 4 (2.5%) | 4 (2.7%)
| Moderate | 1 (1.3%) | 1 (1.4%) | 0 | 2 (3.2%) | 0 | 0 | 1 (0.6%) | 3 (2.0%)
| Severe | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Agitation | Mild | 1 (1.3%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 4 (2.7%)
| Moderate | 1 (1.3%) | 0 | 0 | 2 (3.2%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Severe | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Confusional state | Mild | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Mental status changes | Mild | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
| Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Respiratory, thoracic and mediastinal disorders | Mild | 26 (33.8%) | 20 (28.2%) | 20 (29.4%) | 16 (25.4%) | 4 (23.5%) | 1 (7.1%) | 50 (30.9%) | 37 (25.0%)
| Moderate | 4 (5.2%) | 4 (5.6%) | 6 (8.8%) | 6 (9.5%) | 1 (5.9%) | 2 (14.3%) | 11 (6.8%) | 12 (8.1%)
| Severe | 5 (6.5%) | 6 (8.5%) | 2 (2.9%) | 4 (6.3%) | 0 | 0 | 7 (4.3%) | 10 (6.8%)
| Life threatening | 11 (14.3%) | 16 (22.5%) | 12 (17.6%) | 11 (17.5%) | 3 (17.6%) | 0 | 26 (16.0%) | 27 (18.2%)
Apnoea | Mild | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 0
| Life threatening | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Aspiration | Moderate | 0 | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)
Atelectasis | Mild | 0 | 0 | 0 | 2 (3.2%) | 0 | 0 | 0 | 2 (1.4%)
| Moderate | 0 | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Cough | Mild | 1 (1.3%) | 5 (7.0%) | 0 | 1 (1.6%) | 1 (5.9%) | 1 (7.1%) | 2 (1.2%) | 7 (4.7%)
| Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Dyspnoea | Mild | 0 | 0 | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 2 (1.2%) | 1 (0.7%)
Hiccups | Mild | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Hypercapnia | Mild | 5 (6.5%) | 8 (11.3%) | 8 (11.8%) | 4 (6.3%) | 2 (11.8%) | 1 (7.1%) | 15 (9.3%) | 13 (8.8%)
| Moderate | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 5 (7.9%) | 1 (5.9%) | 1 (7.1%) | 6 (3.7%) | 8 (5.4%)
| Severe | 2 (2.6%) | 3 (4.2%) | 2 (2.9%) | 3 (4.8%) | 1 (5.9%) | 0 | 5 (3.1%) | 6 (4.1%)
Hypoventilation | Life threatening | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Hypoxia | Mild | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 7 (11.1%) | 0 | 0 | 3 (1.9%) | 9 (6.1%)
| Moderate | 2 (2.6%) | 0 | 3 (4.4%) | 2 (3.2%) | 1 (5.9%) | 1 (7.1%) | 6 (3.7%) | 3 (2.0%)
| Severe | 2 (2.6%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
| Life threatening | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 2 (1.4%)
Increased bronchial secretion | Mild | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Increased upper airway secretion | Moderate | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Lung infiltration | Moderate | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Nasal flaring | Mild | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
Pneumonia aspiration | Mild | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
| Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 1 (7.1%) | 0 | 2 (1.4%)
| Life threatening | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Pulmonary oedema | Life threatening | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Respiration abnormal | Mild | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Respiratory acidosis | Moderate | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 0 | 2 (1.4%)
Respiratory depression | Mild | 25 (32.5%) | 15 (21.1%) | 17 (25.0%) | 10 (15.9%) | 0 | 0 | 42 (25.9%) | 25 (16.9%)
| Moderate | 2 (2.6%) | 1 (1.4%) | 3 (4.4%) | 0 | 0 | 1 (7.1%) | 5 (3.1%) | 2 (1.4%)
| Severe | 2 (2.6%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 4 (2.7%)
| Life threatening | 9 (11.7%) | 13 (18.3%) | 11 (16.2%) | 10 (15.9%) | 3 (17.6%) | 0 | 23 (14.2%) | 23 (15.5%)
Respiratory distress | Severe | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Stridor | Moderate | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Use of accessory respiratory muscles | Mild | 1 (1.3%) | 3 (4.2%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 3 (2.0%)
Skin and subcutaneous tissue disorders | Mild | 2 (2.6%) | 2 (2.8%) | 0 | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 3 (2.0%)
Dermatitis diaper | Mild | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Rash | Mild | 1 (1.3%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
Vascular disorders | Mild | 1 (1.3%) | 3 (4.2%) | 4 (5.9%) | 4 (6.3%) | 3 (17.6%) | 0 | 8 (4.9%) | 7 (4.7%)
| Moderate | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 1 (1.6%) | 2 (11.8%) | 0 | 7 (4.3%) | 3 (2.0%)
| Severe | 0 | 2 (2.8%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Life threatening | 2 (2.6%) | 0 | 2 (2.9%) | 2 (3.2%) | 1 (5.9%) | 0 | 5 (3.1%) | 2 (1.4%)
Hypertensive emergency | Moderate | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Hypotension | Mild | 1 (1.3%) | 3 (4.2%) | 4 (5.9%) | 4 (6.3%) | 3 (17.6%) | 0 | 8 (4.9%) | 7 (4.7%)
| Moderate | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 1 (1.6%) | 1 (5.9%) | 0 | 6 (3.7%) | 3 (2.0%)
| Severe | 0 | 2 (2.8%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Life threatening | 2 (2.6%) | 0 | 1 (1.5%) | 2 (3.2%) | 1 (5.9%) | 0 | 4 (2.5%) | 2 (1.4%)
Hypovolaemic shock | Life threatening | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0

Note: The percentages are based on the total number of randomizations in each treatment or total.

Randomizations are counted once at each SOC and PT levels.

Randomizations are only counted once using the most severe intensity.

Mild events include both transient and mild severity.

N= Number of Randomizations.

Table 14.3.3.3 Treatment-Emergent Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Stratum and Treatment Group Safety Population

| | 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Relationship | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Blood and lymphatic system disorders | Unrelated | 3 (3.9%) | 0 | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 1 (0.7%)
| Possibly related | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Coagulopathy | Possibly related | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Disseminated intravascular coagulation | Unrelated | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Leukocytosis | Unrelated | 2 (2.6%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 0
Cardiac disorders | Unrelated | 1 (1.3%) | 0 | 2 (2.9%) | 0 | 0 | 0 | 3 (1.9%) | 0
| Possibly related | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Bradycardia | Unrelated | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Cardio-respiratory arrest | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Tachycardia | Possibly related | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Congenital, familial and genetic disorders | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Sturge-Weber syndrome | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Ear and labyrinth disorders | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Tympanic membrane disorder | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Eye disorders | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 1 (7.1%) | 0 | 2 (1.4%)
Dry eye | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Lagophthalmos | Unrelated | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Gastrointestinal disorders | Unrelated | 1 (1.3%) | 4 (5.6%) | 2 (2.9%) | 3 (4.8%) | 0 | 1 (7.1%) | 3 (1.9%) | 8 (5.4%)
| Possibly related | 2 (2.6%) | 1 (1.4%) | 1 (1.5%) | 0 | 1 (5.9%) | 1 (7.1%) | 4 (2.5%) | 2 (1.4%)
| Probably related | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abdominal distension | Unrelated | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Vomiting | Unrelated | 1 (1.3%) | 4 (5.6%) | 1 (1.5%) | 3 (4.8%) | 0 | 1 (7.1%) | 2 (1.2%) | 8 (5.4%)
| Possibly related | 2 (2.6%) | 1 (1.4%) | 1 (1.5%) | 0 | 1 (5.9%) | 1 (7.1%) | 4 (2.5%) | 2 (1.4%)
| Probably related | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
General disorders and administration site conditions | Unrelated | 3 (3.9%) | 6 (8.5%) | 3 (4.4%) | 1 (1.6%) | 1 (5.9%) | 1 (7.1%) | 7 (4.3%) | 8 (5.4%)
| Possibly related | 0 | 0 | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 1 (0.6%) | 1 (0.7%)
Asthenia | Unrelated | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Device malfunction | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Gait disturbance | Possibly related | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Irritability | Unrelated | 1 (1.3%) | 2 (2.8%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Possibly related | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Pyrexia | Unrelated | 2 (2.6%) | 4 (5.6%) | 3 (4.4%) | 0 | 1 (5.9%) | 0 | 6 (3.7%) | 4 (2.7%)
Infections and infestations | Unrelated | 7 (9.1%) | 3 (4.2%) | 3 (4.4%) | 2 (3.2%) | 1 (5.9%) | 2 (14.3%) | 11 (6.8%) | 7 (4.7%)
| Possibly related | 0 | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Adenovirus infection | Unrelated | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
Bacteraemia | Unrelated | 2 (2.6%) | 0 | 0 | 0 | 0 | 0 | 2 (1.2%) | 0
Encephalitis viral | Unrelated | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Meningitis bacterial | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Oral herpes | Unrelated | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Pneumonia | Unrelated | 0 | 0 | 0 | 2 (3.2%) | 1 (5.9%) | 0 | 1 (0.6%) | 2 (1.4%)
| Possibly related | 0 | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Pyelonephritis | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Sepsis | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Septic shock | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Sinusitis | Unrelated | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Staphylococcal infection | Unrelated | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Upper respiratory tract infection | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Urinary tract infection | Unrelated | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Urinary tract infection pseudomonal | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Injury, poisoning and procedural complications | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Foreign body | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Investigations | Unrelated | 2 (2.6%) | 4 (5.6%) | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 4 (2.7%)
| Possibly related | 1 (1.3%) | 1 (1.4%) | 4 (5.9%) | 0 | 0 | 0 | 5 (3.1%) | 1 (0.7%)
Aspartate aminotransferase increased | Possibly related | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Blood glucose increased | Unrelated | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Blood pH decreased | Possibly related | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Blood pressure systolic decreased | Possibly related | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Body temperature increased | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Chest X-ray abnormal | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Haematocrit abnormal | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Haematocrit decreased | Possibly related | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Oxygen saturation increased | Possibly related | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Respiratory rate increased | Possibly related | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
White blood cell count increased | Unrelated | 0 | 3 (4.2%) | 0 | 0 | 0 | 0 | 0 | 3 (2.0%)
Metabolism and nutrition disorders | Unrelated | 1 (1.3%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Possibly related | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Acidosis | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Hypocalcaemia | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Hypokalaemia | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Hypomagnesaemia | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Hyponatraemia | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
| Possibly related | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Lactic acidosis | Possibly related | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Metabolic acidosis | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
| Possibly related | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Musculoskeletal and connective tissue disorders | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Arthralgia | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | Unrelated | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Medulloblastoma | Unrelated | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Nervous system disorders | Unrelated | 9 (11.7%) | 6 (8.5%) | 1 (1.5%) | 3 (4.8%) | 1 (5.9%) | 1 (7.1%) | 11 (6.8%) | 10 (6.8%)
| Possibly related | 30 (39.0%) | 37 (52.1%) | 33 (48.5%) | 40 (63.5%) | 7 (41.2%) | 3 (21.4%) | 70 (43.2%) | 80 (54.1%)
| Probably related | 4 (5.2%) | 4 (5.6%) | 4 (5.9%) | 5 (7.9%) | 1 (5.9%) | 4 (28.6%) | 9 (5.6%) | 13 (8.8%)
| Definitely related | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 1 (0.6%) | 2 (1.4%)
Ataxia | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
| Possibly related | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Brain injury | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Cerebral ventricle dilatation | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 1 (5.9%) | 0 | 2 (1.2%) | 0
Chorea | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Convulsion | Unrelated | 5 (6.5%) | 3 (4.2%) | 1 (1.5%) | 3 (4.8%) | 0 | 0 | 6 (3.7%) | 6 (4.1%)
| Possibly related | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Dizziness | Unrelated | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Extensor plantar response | Possibly related | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Febrile convulsion | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Headache | Unrelated | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Hemiparesis | Unrelated | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Hyporeflexia | Possibly related | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Infantile spasms | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Nervous system disorder | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Partial seizures | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Porencephaly | Unrelated | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Postictal paralysis | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Postictal state | Possibly related | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Sedation | Unrelated | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 1 (1.6%) | 0 | 1 (7.1%) | 3 (1.9%) | 4 (2.7%)
| Possibly related | 29 (37.7%) | 37 (52.1%) | 33 (48.5%) | 40 (63.5%) | 6 (35.3%) | 3 (21.4%) | 68 (42.0%) | 80 (54.1%)
| Probably related | 4 (5.2%) | 4 (5.6%) | 4 (5.9%) | 5 (7.9%) | 1 (5.9%) | 4 (28.6%) | 9 (5.6%) | 13 (8.8%)
| Definitely related | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 1 (0.6%) | 2 (1.4%)
Status epilepticus | Unrelated | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 0
Pregnancy, puerperium and perinatal conditions | Unrelated | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Eclampsia | Unrelated | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Psychiatric disorders | Unrelated | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 1 (7.1%) | 2 (1.2%) | 3 (2.0%)
| Possibly related | 2 (2.6%) | 2 (2.8%) | 2 (2.9%) | 2 (3.2%) | 0 | 0 | 4 (2.5%) | 4 (2.7%)
Agitation | Unrelated | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 2 (1.4%)
| Possibly related | 1 (1.3%) | 2 (2.8%) | 2 (2.9%) | 2 (3.2%) | 0 | 0 | 3 (1.9%) | 4 (2.7%)
Confusional state | Unrelated | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Mental status changes | Possibly related | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Respiratory, thoracic and mediastinal disorders | Unrelated | 3 (3.9%) | 7 (9.9%) | 2 (2.9%) | 1 (1.6%) | 1 (5.9%) | 1 (7.1%) | 6 (3.7%) | 9 (6.1%)
| Possibly related | 40 (51.9%) | 36 (50.7%) | 34 (50.0%) | 34 (54.0%) | 5 (29.4%) | 1 (7.1%) | 79 (48.8%) | 71 (48.0%)
| Probably related | 3 (3.9%) | 3 (4.2%) | 4 (5.9%) | 2 (3.2%) | 1 (5.9%) | 1 (7.1%) | 8 (4.9%) | 6 (4.1%)
| Definitely related | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Apnoea | Possibly related | 2 (2.6%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 0
| Probably related | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Aspiration | Possibly related | 0 | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)
Atelectasis | Unrelated | 0 | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
| Possibly related | 0 | 0 | 0 | 2 (3.2%) | 0 | 0 | 0 | 2 (1.4%)
Cough | Unrelated | 1 (1.3%) | 3 (4.2%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 3 (2.0%)
| Possibly related | 0 | 3 (4.2%) | 0 | 1 (1.6%) | 1 (5.9%) | 1 (7.1%) | 1 (0.6%) | 5 (3.4%)
Dyspnoea | Unrelated | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
| Possibly related | 0 | 0 | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Hiccups | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Hypercapnia | Unrelated | 3 (3.9%) | 4 (5.6%) | 2 (2.9%) | 1 (1.6%) | 0 | 1 (7.1%) | 5 (3.1%) | 6 (4.1%)
| Possibly related | 4 (5.2%) | 9 (12.7%) | 12 (17.6%) | 10 (15.9%) | 4 (23.5%) | 1 (7.1%) | 20 (12.3%) | 20 (13.5%)
| Probably related | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Hypoventilation | Possibly related | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Hypoxia | Unrelated | 2 (2.6%) | 0 | 0 | 0 | 0 | 0 | 2 (1.2%) | 0
| Possibly related | 4 (5.2%) | 4 (5.6%) | 5 (7.4%) | 10 (15.9%) | 1 (5.9%) | 0 | 10 (6.2%) | 14 (9.5%)
| Probably related | 1 (1.3%) | 0 | 0 | 0 | 0 | 1 (7.1%) | 1 (0.6%) | 1 (0.7%)
Increased bronchial secretion | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Increased upper airway secretion | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Lung infiltration | Possibly related | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Nasal flaring | Unrelated | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
| Possibly related | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Pneumonia aspiration | Possibly related | 1 (1.3%) | 2 (2.8%) | 0 | 0 | 0 | 1 (7.1%) | 1 (0.6%) | 3 (2.0%)
Pulmonary oedema | Unrelated | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Respiration abnormal | Unrelated | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Respiratory acidosis | Possibly related | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 0 | 2 (1.4%)
Respiratory depression | Unrelated | 1 (1.3%) | 4 (5.6%) | 3 (4.4%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 5 (3.4%)
| Possibly related | 35 (45.5%) | 26 (36.6%) | 26 (38.2%) | 19 (30.2%) | 1 (5.9%) | 0 | 62 (38.3%) | 45 (30.4%)
| Probably related | 2 (2.6%) | 2 (2.8%) | 4 (5.9%) | 1 (1.6%) | 1 (5.9%) | 1 (7.1%) | 7 (4.3%) | 4 (2.7%)
| Definitely related | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Respiratory distress | Unrelated | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Stridor | Unrelated | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Use of accessory respiratory muscles | Unrelated | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
| Possibly related | 0 | 2 (2.8%) | 0 | 0 | 0 | 0 | 0 | 2 (1.4%)
Skin and subcutaneous tissue disorders | Unrelated | 2 (2.6%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 2 (1.4%)
| Possibly related | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Dermatitis diaper | Unrelated | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Rash | Unrelated | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
| Possibly related | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Vascular disorders | Unrelated | 1 (1.3%) | 2 (2.8%) | 3 (4.4%) | 1 (1.6%) | 3 (17.6%) | 0 | 7 (4.3%) | 3 (2.0%)
| Possibly related | 3 (3.9%) | 5 (7.0%) | 8 (11.8%) | 6 (9.5%) | 3 (17.6%) | 0 | 14 (8.6%) | 11 (7.4%)
Hypertensive emergency | Unrelated | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Hypotension | Unrelated | 1 (1.3%) | 2 (2.8%) | 2 (2.9%) | 1 (1.6%) | 2 (11.8%) | 0 | 5 (3.1%) | 3 (2.0%)
| Possibly related | 3 (3.9%) | 5 (7.0%) | 8 (11.8%) | 6 (9.5%) | 3 (17.6%) | 0 | 14 (8.6%) | 11 (7.4%)
Hypovolaemic shock | Unrelated | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0

Note: The percentages are based on the total number of randomizations in each treatment or total.

Randomizations are counted once at each SOC and PT levels.

Randomizations are only counted once using the highest relationship.

N= Number of Randomizations.

Table 14.3.3.4 Serious Adverse Events by MedDRA System Organ Class, Preferred Term, Age Stratum and Treatment Group Safety Population

| 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Blood and lymphatic system disorders | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Disseminated intravascular coagulation | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Cardiac disorders | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Cardio-respiratory arrest | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Congenital, familial and genetic disorders | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Sturge-Weber syndrome | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
General disorders and administration site conditions | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Device malfunction | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Pyrexia | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Infections and infestations | 3 (3.9%) | 1 (1.4%) | 2 (2.9%) | 2 (3.2%) | 1 (5.9%) | 0 | 6 (3.7%) | 3 (2.0%)
Adenovirus infection | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Encephalitis viral | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Meningitis bacterial | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Pneumonia | 0 | 0 | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 1 (0.6%) | 1 (0.7%)
Pyelonephritis | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Sepsis | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Septic shock | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Staphylococcal infection | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Medulloblastoma | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Nervous system disorders | 7 (9.1%) | 4 (5.6%) | 1 (1.5%) | 5 (7.9%) | 0 | 0 | 8 (4.9%) | 9 (6.1%)
Ataxia | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Brain injury | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Chorea | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Convulsion | 4 (5.2%) | 2 (2.8%) | 0 | 3 (4.8%) | 0 | 0 | 4 (2.5%) | 5 (3.4%)
Febrile convulsion | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Sedation | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Status epilepticus | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 0
Pregnancy, puerperium and perinatal conditions | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Eclampsia | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Psychiatric disorders | 0 | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Agitation | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Mental status changes | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Respiratory, thoracic and mediastinal disorders | 14 (18.2%) | 21 (29.6%) | 13 (19.1%) | 12 (19.0%) | 3 (17.6%) | 1 (7.1%) | 30 (18.5%) | 34 (23.0%)
Apnoea | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Aspiration | 0 | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Hypoventilation | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Hypoxia | 3 (3.9%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 2 (1.4%)
Pneumonia aspiration | 0 | 2 (2.8%) | 0 | 0 | 0 | 1 (7.1%) | 0 | 3 (2.0%)
Pulmonary oedema | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Respiratory depression | 10 (13.0%) | 15 (21.1%) | 12 (17.6%) | 11 (17.5%) | 3 (17.6%) | 0 | 25 (15.4%) | 26 (17.6%)
Respiratory distress | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Vascular disorders | 2 (2.6%) | 1 (1.4%) | 2 (2.9%) | 3 (4.8%) | 1 (5.9%) | 0 | 5 (3.1%) | 4 (2.7%)
Hypotension | 2 (2.6%) | 1 (1.4%) | 1 (1.5%) | 3 (4.8%) | 1 (5.9%) | 0 | 4 (2.5%) | 4 (2.7%)
Hypovolaemic shock | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0

Note: The percentages are based on the total number of randomizations in each treatment or total.

Randomizations are counted once at each SOC and PT levels.

N= Number of Randomizations.

Table 14.3.3.5 Summary of Adverse Events that Led to Premature Discontinuation of Study Medication by Age Stratum and Treatment Group Safety Population

No participants reported the event.

Table 14.3.4.1 Summary of Treatment-Emergent Adverse Clinical Events by Age Stratum and Treatment Group Safety Population

| 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Number of Events/Randomizations
Number of Treatment-Emergent Adverse Clinical Events | 105 | 117 | 129 | 109 | 23 | 13 | 257 | 239
Randomizations with Adverse Clinical Events | 57 (74.0%) | 58 (81.7%) | 54 (79.4%) | 51 (81.0%) | 11 (64.7%) | 9 (64.3%) | 122 (75.3%) | 118 (79.7%)
Severity (All Adverse Clinical Events)
Mild | 74 | 72 | 81 | 67 | 13 | 10 | 168 | 149
Moderate | 12 | 21 | 29 | 22 | 5 | 3 | 46 | 46
Severe | 7 | 10 | 6 | 6 | 1 | 0 | 14 | 16
Life threatening | 12 | 14 | 13 | 14 | 4 | 0 | 29 | 28
Death | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Highest Severity Per Randomization
Mild | 34 (44.2%) | 27 (38.0%) | 25 (36.8%) | 27 (42.9%) | 7 (41.2%) | 7 (50.0%) | 66 (40.7%) | 61 (41.2%)
Moderate | 9 (11.7%) | 9 (12.7%) | 13 (19.1%) | 9 (14.3%) | 1 (5.9%) | 2 (14.3%) | 23 (14.2%) | 20 (13.5%)
Severe | 3 (3.9%) | 8 (11.3%) | 4 (5.9%) | 4 (6.3%) | 0 | 0 | 7 (4.3%) | 12 (8.1%)
Life threatening | 11 (14.3%) | 14 (19.7%) | 12 (17.6%) | 11 (17.5%) | 3 (17.6%) | 0 | 26 (16.0%) | 25 (16.9%)
Death | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Relationship (All Adverse Clinical Events)
Unrelated | 10 | 13 | 14 | 6 | 2 | 2 | 26 | 21
Possibly related | 85 | 97 | 107 | 95 | 17 | 5 | 209 | 197
Probably related | 10 | 6 | 8 | 7 | 2 | 6 | 20 | 19
Definitely related | 0 | 1 | 0 | 1 | 2 | 0 | 2 | 2
Strongest Relationship Per Randomization
Unrelated | 2 (2.6%) | 3 (4.2%) | 2 (2.9%) | 0 | 1 (5.9%) | 1 (7.1%) | 5 (3.1%) | 4 (2.7%)
Possibly related | 48 (62.3%) | 48 (67.6%) | 45 (66.2%) | 45 (71.4%) | 6 (35.3%) | 3 (21.4%) | 99 (61.1%) | 96 (64.9%)
Probably related | 7 (9.1%) | 6 (8.5%) | 7 (10.3%) | 5 (7.9%) | 2 (11.8%) | 5 (35.7%) | 16 (9.9%) | 16 (10.8%)
Definitely related | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 2 (11.8%) | 0 | 2 (1.2%) | 2 (1.4%)

Note: Mild events include both transient and mild severity.

N= Number of Randomizations.

Table 14.3.4.2 Treatment-Emergent Adverse Clinical Events by MedDRA System Organ Class, Preferred Term, Age Stratum and Treatment Group Safety Population

| 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Cardiac disorders | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Bradycardia | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Nervous system disorders | 35 (45.5%) | 44 (62.0%) | 38 (55.9%) | 47 (74.6%) | 8 (47.1%) | 8 (57.1%) | 81 (50.0%) | 99 (66.9%)
Sedation | 35 (45.5%) | 44 (62.0%) | 38 (55.9%) | 47 (74.6%) | 8 (47.1%) | 8 (57.1%) | 81 (50.0%) | 99 (66.9%)
Psychiatric disorders | 2 (2.6%) | 3 (4.2%) | 3 (4.4%) | 3 (4.8%) | 0 | 0 | 5 (3.1%) | 6 (4.1%)
Agitation | 2 (2.6%) | 3 (4.2%) | 3 (4.4%) | 3 (4.8%) | 0 | 0 | 5 (3.1%) | 6 (4.1%)
Respiratory, thoracic and mediastinal disorders | 43 (55.8%) | 40 (56.3%) | 38 (55.9%) | 35 (55.6%) | 6 (35.3%) | 3 (21.4%) | 87 (53.7%) | 78 (52.7%)
Aspiration | 0 | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)
Hypercapnia | 8 (10.4%) | 13 (18.3%) | 14 (20.6%) | 12 (19.0%) | 4 (23.5%) | 2 (14.3%) | 26 (16.0%) | 27 (18.2%)
Hypoxia | 7 (9.1%) | 4 (5.6%) | 5 (7.4%) | 10 (15.9%) | 1 (5.9%) | 1 (7.1%) | 13 (8.0%) | 15 (10.1%)
Respiratory depression | 38 (49.4%) | 32 (45.1%) | 33 (48.5%) | 21 (33.3%) | 3 (17.6%) | 1 (7.1%) | 74 (45.7%) | 54 (36.5%)
Vascular disorders | 4 (5.2%) | 7 (9.9%) | 10 (14.7%) | 7 (11.1%) | 5 (29.4%) | 0 | 19 (11.7%) | 14 (9.5%)
Hypotension | 4 (5.2%) | 7 (9.9%) | 10 (14.7%) | 7 (11.1%) | 5 (29.4%) | 0 | 19 (11.7%) | 14 (9.5%)

Note: The percentages are based on the total number of randomizations in each treatment or total. Randomizations are counted once at each SOC and PT levels.

N= Number of Randomizations.

Table 14.3.4.3 Treatment-Emergent Adverse Clinical Events by MedDRA System Organ Class, Preferred Term, Severity, Age Stratum and Treatment Group Safety Population

| | 3 mo - <3 yrs | | 3 yrs - <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Severity | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Cardiac disorders | Mild | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Bradycardia | Mild | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Nervous system disorders | Mild | 29 (37.7%) | 28 (39.4%) | 28 (41.2%) | 35 (55.6%) | 7 (41.2%) | 8 (57.1%) | 64 (39.5%) | 71 (48.0%)
| Moderate | 5 (6.5%) | 15 (21.1%) | 10 (14.7%) | 10 (15.9%) | 1 (5.9%) | 0 | 16 (9.9%) | 25 (16.9%)
| Severe | 1 (1.3%) | 1 (1.4%) | 0 | 2 (3.2%) | 0 | 0 | 1 (0.6%) | 3 (2.0%)
Sedation | Mild | 29 (37.7%) | 28 (39.4%) | 28 (41.2%) | 35 (55.6%) | 7 (41.2%) | 8 (57.1%) | 64 (39.5%) | 71 (48.0%)
| Moderate | 5 (6.5%) | 15 (21.1%) | 10 (14.7%) | 10 (15.9%) | 1 (5.9%) | 0 | 16 (9.9%) | 25 (16.9%)
| Severe | 1 (1.3%) | 1 (1.4%) | 0 | 2 (3.2%) | 0 | 0 | 1 (0.6%) | 3 (2.0%)
Psychiatric disorders | Mild | 1 (1.3%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 4 (2.7%)
| Moderate | 1 (1.3%) | 0 | 0 | 2 (3.2%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Severe | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Agitation | Mild | 1 (1.3%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 4 (2.7%)
| Moderate | 1 (1.3%) | 0 | 0 | 2 (3.2%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Severe | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Respiratory, thoracic and mediastinal disorders | Mild | 26 (33.8%) | 17 (23.9%) | 18 (26.5%) | 14 (22.2%) | 2 (11.8%) | 1 (7.1%) | 46 (28.4%) | 32 (21.6%)
| Moderate | 4 (5.2%) | 3 (4.2%) | 6 (8.8%) | 6 (9.5%) | 1 (5.9%) | 2 (14.3%) | 11 (6.8%) | 11 (7.4%)
| Severe | 4 (5.2%) | 6 (8.5%) | 2 (2.9%) | 4 (6.3%) | 0 | 0 | 6 (3.7%) | 10 (6.8%)
| Life threatening | 9 (11.7%) | 14 (19.7%) | 12 (17.6%) | 11 (17.5%) | 3 (17.6%) | 0 | 24 (14.8%) | 25 (16.9%)
Aspiration | Moderate | 0 | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)
Hypercapnia | Mild | 5 (6.5%) | 8 (11.3%) | 8 (11.8%) | 4 (6.3%) | 2 (11.8%) | 1 (7.1%) | 15 (9.3%) | 13 (8.8%)
| Moderate | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 5 (7.9%) | 1 (5.9%) | 1 (7.1%) | 6 (3.7%) | 8 (5.4%)
| Severe | 2 (2.6%) | 3 (4.2%) | 2 (2.9%) | 3 (4.8%) | 1 (5.9%) | 0 | 5 (3.1%) | 6 (4.1%)
Hypoxia | Mild | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 7 (11.1%) | 0 | 0 | 3 (1.9%) | 9 (6.1%)
| Moderate | 2 (2.6%) | 0 | 3 (4.4%) | 2 (3.2%) | 1 (5.9%) | 1 (7.1%) | 6 (3.7%) | 3 (2.0%)
| Severe | 2 (2.6%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
| Life threatening | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 2 (1.4%)
Respiratory depression | Mild | 25 (32.5%) | 15 (21.1%) | 17 (25.0%) | 10 (15.9%) | 0 | 0 | 42 (25.9%) | 25 (16.9%)
| Moderate | 2 (2.6%) | 1 (1.4%) | 3 (4.4%) | 0 | 0 | 1 (7.1%) | 5 (3.1%) | 2 (1.4%)
| Severe | 2 (2.6%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 4 (2.7%)
| Life threatening | 9 (11.7%) | 13 (18.3%) | 11 (16.2%) | 10 (15.9%) | 3 (17.6%) | 0 | 23 (14.2%) | 23 (15.5%)
Vascular disorders | Mild | 1 (1.3%) | 3 (4.2%) | 4 (5.9%) | 4 (6.3%) | 3 (17.6%) | 0 | 8 (4.9%) | 7 (4.7%)
| Moderate | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 1 (1.6%) | 1 (5.9%) | 0 | 6 (3.7%) | 3 (2.0%)
| Severe | 0 | 2 (2.8%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Life threatening | 2 (2.6%) | 0 | 1 (1.5%) | 2 (3.2%) | 1 (5.9%) | 0 | 4 (2.5%) | 2 (1.4%)
Hypotension | Mild | 1 (1.3%) | 3 (4.2%) | 4 (5.9%) | 4 (6.3%) | 3 (17.6%) | 0 | 8 (4.9%) | 7 (4.7%)
| Moderate | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 1 (1.6%) | 1 (5.9%) | 0 | 6 (3.7%) | 3 (2.0%)
| Severe | 0 | 2 (2.8%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Life threatening | 2 (2.6%) | 0 | 1 (1.5%) | 2 (3.2%) | 1 (5.9%) | 0 | 4 (2.5%) | 2 (1.4%)

Note: The percentages are based on the total number of randomizations in each treatment or total.

Randomizations are counted once at each SOC and PT levels.

Randomizations are only counted once using the most severe intensity.

N= Number of Randomizations.

Table 14.3.4.4 Treatment-Emergent Adverse Clinical Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Stratum and Treatment Group Safety Population

| | 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Relationship | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Cardiac disorders | Unrelated | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Bradycardia | Unrelated | 0 | 0 | 2 (2.9%) | 0 | 0 | 0 | 2 (1.2%) | 0
Nervous system disorders | Unrelated | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 1 (1.6%) | 0 | 1 (7.1%) | 3 (1.9%) | 4 (2.7%)
| Possibly related | 29 (37.7%) | 37 (52.1%) | 33 (48.5%) | 40 (63.5%) | 6 (35.3%) | 3 (21.4%) | 68 (42.0%) | 80 (54.1%)
| Probably related | 4 (5.2%) | 4 (5.6%) | 4 (5.9%) | 5 (7.9%) | 1 (5.9%) | 4 (28.6%) | 9 (5.6%) | 13 (8.8%)
| Definitely related | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 1 (0.6%) | 2 (1.4%)
Sedation | Unrelated | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 1 (1.6%) | 0 | 1 (7.1%) | 3 (1.9%) | 4 (2.7%)
| Possibly related | 29 (37.7%) | 37 (52.1%) | 33 (48.5%) | 40 (63.5%) | 6 (35.3%) | 3 (21.4%) | 68 (42.0%) | 80 (54.1%)
| Probably related | 4 (5.2%) | 4 (5.6%) | 4 (5.9%) | 5 (7.9%) | 1 (5.9%) | 4 (28.6%) | 9 (5.6%) | 13 (8.8%)
| Definitely related | 0 | 1 (1.4%) | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 1 (0.6%) | 2 (1.4%)
Psychiatric disorders | Unrelated | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 2 (1.4%)
| Possibly related | 1 (1.3%) | 2 (2.8%) | 2 (2.9%) | 2 (3.2%) | 0 | 0 | 3 (1.9%) | 4 (2.7%)
Agitation | Unrelated | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 2 (1.4%)
| Possibly related | 1 (1.3%) | 2 (2.8%) | 2 (2.9%) | 2 (3.2%) | 0 | 0 | 3 (1.9%) | 4 (2.7%)
Respiratory, thoracic and mediastinal disorders | Unrelated | 3 (3.9%) | 4 (5.6%) | 1 (1.5%) | 1 (1.6%) | 0 | 1 (7.1%) | 4 (2.5%) | 6 (4.1%)
| Possibly related | 37 (48.1%) | 34 (47.9%) | 33 (48.5%) | 32 (50.8%) | 4 (23.5%) | 1 (7.1%) | 74 (45.7%) | 67 (45.3%)
| Probably related | 3 (3.9%) | 2 (2.8%) | 4 (5.9%) | 2 (3.2%) | 1 (5.9%) | 1 (7.1%) | 8 (4.9%) | 5 (3.4%)
| Definitely related | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Aspiration | Possibly related | 0 | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)
Hypercapnia | Unrelated | 3 (3.9%) | 4 (5.6%) | 2 (2.9%) | 1 (1.6%) | 0 | 1 (7.1%) | 5 (3.1%) | 6 (4.1%)
| Possibly related | 4 (5.2%) | 9 (12.7%) | 12 (17.6%) | 10 (15.9%) | 4 (23.5%) | 1 (7.1%) | 20 (12.3%) | 20 (13.5%)
| Probably related | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Hypoxia | Unrelated | 2 (2.6%) | 0 | 0 | 0 | 0 | 0 | 2 (1.2%) | 0
| Possibly related | 4 (5.2%) | 4 (5.6%) | 5 (7.4%) | 10 (15.9%) | 1 (5.9%) | 0 | 10 (6.2%) | 14 (9.5%)
| Probably related | 1 (1.3%) | 0 | 0 | 0 | 0 | 1 (7.1%) | 1 (0.6%) | 1 (0.7%)
Respiratory depression | Unrelated | 1 (1.3%) | 4 (5.6%) | 3 (4.4%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 5 (3.4%)
| Possibly related | 35 (45.5%) | 26 (36.6%) | 26 (38.2%) | 19 (30.2%) | 1 (5.9%) | 0 | 62 (38.3%) | 45 (30.4%)
| Probably related | 2 (2.6%) | 2 (2.8%) | 4 (5.9%) | 1 (1.6%) | 1 (5.9%) | 1 (7.1%) | 7 (4.3%) | 4 (2.7%)
| Definitely related | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Vascular disorders | Unrelated | 1 (1.3%) | 2 (2.8%) | 2 (2.9%) | 1 (1.6%) | 2 (11.8%) | 0 | 5 (3.1%) | 3 (2.0%)
| Possibly related | 3 (3.9%) | 5 (7.0%) | 8 (11.8%) | 6 (9.5%) | 3 (17.6%) | 0 | 14 (8.6%) | 11 (7.4%)
Hypotension | Unrelated | 1 (1.3%) | 2 (2.8%) | 2 (2.9%) | 1 (1.6%) | 2 (11.8%) | 0 | 5 (3.1%) | 3 (2.0%)
| Possibly related | 3 (3.9%) | 5 (7.0%) | 8 (11.8%) | 6 (9.5%) | 3 (17.6%) | 0 | 14 (8.6%) | 11 (7.4%)

Note: The percentages are based on the total number of randomizations in each treatment or total.

Randomizations are counted once at each SOC and PT levels.

Randomizations are only counted once using the highest relationship.

N= Number of Randomizations.

Table 14.3.5.1 Summary of Critical or Near Critical Adverse Events by Age Stratum and Treatment Group Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Number of Events/Randomizations
Number of Critical and Near Critical Adverse Events | 13 | 18 | 15 | 14 | 4 | 0 | 32 | 32
Randomizations with Critical and Near Critical Adverse Events | 12 (15.6%) | 18 (25.4%) | 14 (20.6%) | 12 (19.0%) | 3 (17.6%) | 0 | 29 (17.9%) | 30 (20.3%)
Severity (All Critical and Near Critical AEs)
Mild | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Moderate | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Severe | 2 | 5 | 3 | 1 | 0 | 0 | 5 | 6
Life threatening | 11 | 13 | 12 | 13 | 4 | 0 | 27 | 26
Death | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Highest Severity Per Randomization
Mild | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Moderate | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Severe | 1 (1.3%) | 5 (7.0%) | 3 (4.4%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 6 (4.1%)
Life threatening | 11 (14.3%) | 13 (18.3%) | 11 (16.2%) | 11 (17.5%) | 3 (17.6%) | 0 | 25 (15.4%) | 24 (16.2%)
Death | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Relationship (All Critical and Near Critical AEs)
Unrelated | 1 | 3 | 4 | 3 | 0 | 0 | 5 | 6
Possibly related | 11 | 13 | 7 | 11 | 2 | 0 | 20 | 24
Probably related | 1 | 2 | 4 | 0 | 1 | 0 | 6 | 2
Definitely related | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0
Strongest Relationship Per Randomization
Unrelated | 1 (1.3%) | 3 (4.2%) | 4 (5.9%) | 1 (1.6%) | 0 | 0 | 5 (3.1%) | 4 (2.7%)
Possibly related | 10 (13.0%) | 13 (18.3%) | 6 (8.8%) | 11 (17.5%) | 1 (5.9%) | 0 | 17 (10.5%) | 24 (16.2%)
Probably related | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 0 | 1 (5.9%) | 0 | 6 (3.7%) | 2 (1.4%)
Definitely related | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0

Note: Mild events include both transient and mild severity.

N= Number of Randomizations.

Table 14.3.5.2 Critical or Near Critical Adverse Events by MedDRA System Organ Class, Preferred Term, Age Stratum and Treatment Group Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Respiratory, thoracic and mediastinal disorders | 11 (14.3%) | 16 (22.5%) | 13 (19.1%) | 11 (17.5%) | 3 (17.6%) | 0 | 27 (16.7%) | 27 (18.2%)
Respiratory depression | 11 (14.3%) | 16 (22.5%) | 13 (19.1%) | 11 (17.5%) | 3 (17.6%) | 0 | 27 (16.7%) | 27 (18.2%)
Vascular disorders | 2 (2.6%) | 2 (2.8%) | 2 (2.9%) | 2 (3.2%) | 1 (5.9%) | 0 | 5 (3.1%) | 4 (2.7%)
Hypotension | 2 (2.6%) | 2 (2.8%) | 2 (2.9%) | 2 (3.2%) | 1 (5.9%) | 0 | 5 (3.1%) | 4 (2.7%)

Note: The percentages are based on the total number of randomizations in each treatment or total.

Randomizations are counted once at each SOC and PT levels.

N= Number of Randomizations.

Table 14.3.5.3 Critical or Near Critical Adverse Events by MedDRA System Organ Class, Preferred Term, Severity, Age Stratum and Treatment Group Safety Population

| | 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Severity | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Respiratory, thoracic and mediastinal disorders | Severe | 2 (2.6%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 4 (2.7%)
| Life threatening | 9 (11.7%) | 13 (18.3%) | 11 (16.2%) | 10 (15.9%) | 3 (17.6%) | 0 | 23 (14.2%) | 23 (15.5%)
Respiratory depression | Severe | 2 (2.6%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 4 (2.7%)
| Life threatening | 9 (11.7%) | 13 (18.3%) | 11 (16.2%) | 10 (15.9%) | 3 (17.6%) | 0 | 23 (14.2%) | 23 (15.5%)
Vascular disorders | Severe | 0 | 2 (2.8%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Life threatening | 2 (2.6%) | 0 | 1 (1.5%) | 2 (3.2%) | 1 (5.9%) | 0 | 4 (2.5%) | 2 (1.4%)
Hypotension | Severe | 0 | 2 (2.8%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 2 (1.4%)
| Life threatening | 2 (2.6%) | 0 | 1 (1.5%) | 2 (3.2%) | 1 (5.9%) | 0 | 4 (2.5%) | 2 (1.4%)

Note: The percentages are based on the total number of randomizations in each treatment or total.

Randomizations are counted once at each SOC and PT levels.

Randomizations are only counted once using the most severe intensity.

N= Number of Randomizations.

Table 14.3.5.4 Critical or Near Critical Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Stratum and Treatment Group Safety Population

| | 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
System Organ Class (SOC)/Preferred Term | Relationship | Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Respiratory, thoracic and mediastinal disorders | Unrelated | 0 | 2 (2.8%) | 3 (4.4%) | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 3 (2.0%)
| Possibly related | 10 (13.0%) | 12 (16.9%) | 6 (8.8%) | 10 (15.9%) | 1 (5.9%) | 0 | 17 (10.5%) | 22 (14.9%)
| Probably related | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 0 | 1 (5.9%) | 0 | 6 (3.7%) | 2 (1.4%)
| Definitely related | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Respiratory depression | Unrelated | 0 | 2 (2.8%) | 3 (4.4%) | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 3 (2.0%)
| Possibly related | 10 (13.0%) | 12 (16.9%) | 6 (8.8%) | 10 (15.9%) | 1 (5.9%) | 0 | 17 (10.5%) | 22 (14.9%)
| Probably related | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 0 | 1 (5.9%) | 0 | 6 (3.7%) | 2 (1.4%)
| Definitely related | 0 | 0 | 0 | 0 | 1 (5.9%) | 0 | 1 (0.6%) | 0
Vascular disorders | Unrelated | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 2 (1.4%)
| Possibly related | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 3 (1.9%) | 2 (1.4%)
Hypotension | Unrelated | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 2 (1.4%)
| Possibly related | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 0 | 3 (1.9%) | 2 (1.4%)

Note: The percentages are based on the total number of randomizations in each treatment or total.

Randomizations are counted once at each SOC and PT levels.

Randomizations are only counted once using the highest relationship.

N= Number of Randomizations.

Table 14.3.6.1.1 Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group White Blood Count (×10^3^/cumm) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 63 | 61 | 60 | 51 | 14 | 12 | 137 | 124
Mean (SD) | 15.3 (7.0) | 15.8 (8.4) | 12.9 (6.5) | 13.4 (5.5) | 10.7 (4.9) | 12.0 (4.0) | 13.8 (6.8) | 14.4 (7.1)
95% CI of the Mean | 13.6, 17.1 | 13.6, 17.9 | 11.2, 14.6 | 11.8, 14.9 | 7.9, 13.6 | 9.5, 14.6 | 12.6, 14.9 | 13.2, 15.7
Median (Min-Max) | 14.4 (2.7, 38.2) | 13.9 (2.0, 41.0) | 11.7 (4.6, 46.9) | 12.4 (4.5, 25.0) | 9.5 (5.7, 21.6) | 11.2 (7.7, 20.5) | 12.6 (2.7, 46.9) | 13.2 (2.0, 41.0)
24 Hour Visit
N | 48 | 42 | 44 | 43 | 11 | 9 | 103 | 94
Mean (SD) | 10.8 (6.6) | 11.4 (6.4) | 10.0 (5.4) | 8.7 (3.0) | 8.6 (5.1) | 9.0 (5.9) | 10.2 (5.9) | 9.9 (5.2)
95% CI of the Mean | 8.9, 12.7 | 9.4, 13.4 | 8.3, 11.6 | 7.8, 9.7 | 5.2, 12.1 | 4.4, 13.5 | 9.1, 11.4 | 8.9, 11.0
Median (Min-Max) | 8.9 (3.7, 32.9) | 10.4 (2.6, 35.0) | 9.1 (1.9, 33.7) | 8.5 (2.8, 14.3) | 6.9 (3.8, 22.3) | 7.5 (4.6, 24.0) | 8.9 (1.9, 33.7) | 8.9 (2.6, 35.0)
Change from Baseline to 24 hour Visit
N | 38 | 36 | 40 | 37 | 10 | 8 | 88 | 81
Mean (SD) | −3.9 (6.8) | −4.8 (5.4) | −3.5 (5.3) | −4.7 (4.5) | −2.5 (3.2) | −2.7 (3.5) | −3.6 (5.8) | −4.6 (4.8)
95% CI of the Mean | 0.0, −1.6 | 0.0, −3.0 | 0.0, −1.8 | 0.0, −3.2 | 0.0, −0.2 | 0.0, 0.2 | 0.0, −2.3 | 0.0, −3.5
Median (Min-Max) | −3.9 (−19.9, 17.8) | −3.7 (−21.8, 3.2) | −2.8 (−26.9, 4.7) | −3.5 (−16.2, 4.2) | −1.6 (−8.9, 1.0) | −3.3 (−6.2, 4.7) | −2.9 (−26.9, 17.8) | −3.6 (−21.8, 4.7)

Table 14.3.6.1.2 Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group Red Blood Count (×10^3^/cumm) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 63 | 61 | 60 | 51 | 14 | 12 | 137 | 124
Mean (SD) | 4.4 (0.4) | 4.5 (0.4) | 4.6 (0.4) | 4.6 (0.4) | 4.7 (0.7) | 4.6 (0.5) | 4.5 (0.5) | 4.6 (0.4)
95% CI of the Mean | 4.3, 4.6 | 4.4, 4.6 | 4.5, 4.7 | 4.5, 4.7 | 4.3, 5.0 | 4.3, 4.9 | 4.5, 4.6 | 4.5, 4.6
Median (Min-Max) | 4.5 (3.1, 5.5) | 4.5 (3.3, 5.6) | 4.6 (3.8, 5.8) | 4.5 (3.6, 5.6) | 4.6 (3.4, 5.9) | 4.8 (3.4, 5.3) | 4.5 (3.1, 5.9) | 4.5 (3.3, 5.6)
24 Hour Visit
N | 48 | 42 | 44 | 43 | 11 | 9 | 103 | 94
Mean (SD) | 4.3 (0.5) | 4.2 (0.5) | 4.3 (0.4) | 4.2 (0.4) | 4.3 (0.5) | 4.2 (0.5) | 4.3 (0.5) | 4.2 (0.4)
95% CI of the Mean | 4.1, 4.4 | 4.0, 4.3 | 4.2, 4.4 | 4.1, 4.4 | 3.9, 4.7 | 3.8, 4.6 | 4.2, 4.4 | 4.1, 4.3
Median (Min-Max) | 4.3 (2.7, 5.5) | 4.2 (3.0, 6.0) | 4.3 (3.3, 5.1) | 4.2 (3.5, 5.2) | 4.2 (3.6, 5.2) | 4.1 (3.5, 5.2) | 4.3 (2.7, 5.5) | 4.2 (3.0, 6.0)
Change from Baseline to 24 hour Visit
N | 38 | 36 | 40 | 37 | 10 | 8 | 88 | 81
Mean (SD) | −0.3 (0.5) | −0.3 (0.4) | −0.3 (0.4) | −0.3 (0.3) | −0.3 (0.4) | −0.2 (0.2) | −0.3 (0.4) | −0.3 (0.3)
95% CI of the Mean | 0.0, −0.2 | 0.0, −0.2 | 0.0, −0.2 | 0.0, −0.2 | 0.0, 0.0 | 0.0, 0.0 | 0.0, −0.2 | 0.0, −0.2
Median (Min-Max) | −0.2 (−1.7, 0.2) | −0.2 (−1.5, 0.5) | −0.2 (−1.3, 0.3) | −0.2 (−1.2, 0.3) | −0.3 (−1.0, 0.3) | −0.2 (−0.7, 0.1) | −0.2 (−1.7, 0.3) | −0.2 (−1.5, 0.5)

Table 14.3.6.1.3 Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group Hemaglobin (g/dL) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 63 | 61 | 60 | 52 | 14 | 12 | 137 | 125
Mean (SD) | 11.7 (1.2) | 12.1 (0.9) | 12.8 (1.2) | 12.7 (1.2) | 14.1 (2.0) | 13.1 (2.0) | 12.4 (1.5) | 12.5 (1.2)
95% CI of the Mean | 11.4, 12.0 | 11.8, 12.3 | 12.5, 13.1 | 12.4, 13.1 | 13.0, 15.2 | 11.8, 14.4 | 12.2, 12.7 | 12.2, 12.7
Median (Min-Max) | 11.6 (8.4, 14.7) | 11.9 (9.4, 14.9) | 12.8 (10.5, 16.4) | 12.6 (9.2, 16.3) | 13.3 (11.1, 18.3) | 14.0 (9.0, 14.6) | 12.1 (8.4, 18.3) | 12.3 (9.0, 16.3)
24 Hour Visit
N | 48 | 42 | 44 | 43 | 11 | 9 | 103 | 94
Mean (SD) | 11.0 (1.2) | 11.2 (1.3) | 12.1 (1.3) | 11.9 (1.2) | 13.1 (1.6) | 11.9 (1.9) | 11.7 (1.4) | 11.6 (1.3)
95% CI of the Mean | 10.7, 11.4 | 10.8, 11.6 | 11.7, 12.5 | 11.5, 12.2 | 12.0, 14.1 | 10.4, 13.3 | 11.4, 12.0 | 11.3, 11.8
Median (Min-Max) | 11.2 (7.7, 13.0) | 11.2 (7.8, 16.4) | 12.1 (8.8, 14.2) | 11.7 (8.6, 15.0) | 13.1 (10.8, 16.2) | 12.4 (8.2, 13.8) | 11.7 (7.7, 16.2) | 11.4 (7.8, 16.4)
Change from Baseline to 24 hour Visit
N | 38 | 36 | 40 | 38 | 10 | 8 | 88 | 82
Mean (SD) | −0.9 (1.2) | −0.9 (1.0) | −0.8 (1.1) | −0.8 (0.9) | −0.9 (1.1) | −0.6 (0.8) | −0.9 (1.1) | −0.8 (1.0)
95% CI of the Mean | 0.0, −0.5 | 0.0, −0.6 | 0.0, −0.5 | 0.0, −0.5 | 0.0, −0.2 | 0.0, 0.1 | 0.0, −0.6 | 0.0, −0.6
Median (Min-Max) | −0.7 (−5.0, 0.5) | −0.7 (−4.0, 1.4) | −0.5 (−3.8, 0.6) | −0.6 (−3.3, 0.8) | −1.0 (−3.0, 0.9) | −0.8 (−1.5, 0.7) | −0.7 (−5.0, 0.9) | −0.7 (−4.0, 1.4)

Table 14.3.6.1.4 Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group Hematocrit (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 63 | 61 | 60 | 52 | 14 | 12 | 137 | 125
Mean (SD) | 35.2 (3.5) | 36.2 (2.6) | 37.5 (3.2) | 37.6 (3.1) | 41.9 (5.6) | 39.0 (4.3) | 36.9 (4.1) | 37.0 (3.1)
95% CI of the Mean | 34.3, 36.0 | 35.5, 36.8 | 36.7, 38.4 | 36.8, 38.5 | 38.7, 45.1 | 36.2, 41.7 | 36.2, 37.6 | 36.5, 37.6
Median (Min-Max) | 34.8 (28.3, 44.8) | 35.8 (29.6, 42.4) | 37.3 (32.4, 46.5) | 37.4 (29.6, 46.1) | 39.8 (32.1, 53.6) | 40.8 (29.0, 43.0) | 36.3 (28.3, 53.6) | 36.9 (29.0, 46.1)
24 Hour Visit
N | 48 | 42 | 44 | 43 | 11 | 9 | 103 | 94
Mean (SD) | 33.0 (3.5) | 33.3 (3.5) | 35.3 (3.4) | 34.5 (2.9) | 38.7 (4.3) | 35.4 (4.4) | 34.6 (4.0) | 34.0 (3.4)
95% CI of the Mean | 32.0, 34.0 | 32.2, 34.4 | 34.3, 36.4 | 33.6, 35.3 | 35.8, 41.6 | 32.0, 38.8 | 33.8, 35.4 | 33.4, 34.7
Median (Min-Max) | 33.0 (22.8, 41.6) | 33.4 (24.5, 47.6) | 35.6 (27.3, 42.4) | 34.1 (27.4, 42.2) | 38.3 (32.6, 46.1) | 36.0 (28.2, 41.7) | 34.3 (22.8, 46.1) | 33.7 (24.5, 47.6)
Change from Baseline to 24 hour Visit
N | 38 | 36 | 40 | 38 | 10 | 8 | 88 | 82
Mean (SD) | −3.0 (3.9) | −2.9 (3.2) | −2.6 (2.8) | −2.9 (2.7) | −2.9 (3.2) | −2.0 (1.9) | −2.8 (3.3) | −2.8 (2.8)
95% CI of the Mean | 0.0, −1.7 | 0.0, −1.8 | 0.0, −1.7 | 0.0, −2.0 | 0.0, −0.6 | 0.0, −0.3 | 0.0, −2.1 | 0.0, −2.2
Median (Min-Max) | −2.0 (−14.9, 1.7) | −2.5 (−13.9, 3.4) | −1.9 (−10.5, 1.9) | −2.2 (−9.4, 2.4) | −3.8 (−9.0, 2.4) | −2.1 (−5.4, 0.5) | −2.1 (−14.9, 2.4) | −2.2 (−13.9, 3.4)

Table 14.3.6.1.5 Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group Platelet Count (×10^3^/cumm) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 63 | 61 | 60 | 51 | 14 | 12 | 137 | 124
Mean (SD) | 353.1 (120.6) | 373.0 (143.9) | 333.8 (93.4) | 336.1 (118.0) | 243.2 (50.1) | 224.9 (82.5) | 333.4 (108.0) | 343.5 (134.9)
95% CI of the Mean | 322.7, 383.4 | 336.2, 409.9 | 309.7, 358.0 | 302.9, 369.3 | 214.3, 272.1 | 172.5, 277.3 | 315.2, 351.7 | 319.5, 367.5
Median (Min-Max) | 351.0 (140.0, 687.0) | 356.0 (36.0, 783.0) | 328.5 (100.0, 581.0) | 323.0 (137.0, 696.0) | 231.5 (179.0, 333.0) | 218.0 (100.0, 429.0) | 325.0 (100.0, 687.0) | 325.0 (36.0, 783.0)
24 Hour Visit
N | 47 | 42 | 43 | 43 | 11 | 9 | 101 | 94
Mean (SD) | 277.0 (112.3) | 288.3 (97.3) | 271.4 (76.3) | 283.6 (102.5) | 199.0 (60.2) | 235.6 (78.0) | 266.1 (95.7) | 281.1 (98.3)
95% CI of the Mean | 244.1, 310.0 | 258.0, 318.6 | 248.0, 294.9 | 252.0, 315.1 | 158.6, 239.4 | 175.6, 295.5 | 247.2, 285.0 | 261.0, 301.2
Median (Min-Max) | 290.0 (70.0, 565.0) | 289.5 (134.0, 544.0) | 280.0 (20.0, 402.0) | 271.0 (32.0, 527.0) | 200.0 (90.0, 278.0) | 238.0 (130.0, 406.0) | 268.0 (20.0, 565.0) | 271.0 (32.0, 544.0)
Change from Baseline to 24 hour Visit
N | 37 | 36 | 40 | 37 | 10 | 8 | 87 | 81
Mean (SD) | −63.1 (103.0) | −83.1 (79.5) | −64.4 (84.8) | −60.0 (70.0) | −39.9 (36.1) | −14.5 (16.9) | −61.0 (88.9) | −65.8 (73.5)
95% CI of the Mean | 0.0, −28.8 | 0.0, −56.2 | 0.0, −37.3 | 0.0, −36.7 | 0.0, −14.1 | 0.0, −0.3 | 0.0, −42.1 | 0.0, −49.5
Median (Min-Max) | −60.0 (−400.0, 136.0) | −70.0 (−275.0, 43.0) | −52.0 (−292.0, 216.0) | −61.0 (−231.0, 65.0) | −51.0 (−86.0, 31.0) | −15.5 (−37.0, 14.0) | −54.0 (−400.0, 216.0) | −49.0 (−275.0, 65.0)

Table 14.3.6.1.6 Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group Neutrophils (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | >13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 60 | 53 | 50 | 43 | 11 | 10 | 121 | 106
Mean (SD) | 46.2 (19.9) | 42.3 (18.2) | 51.9 (18.8) | 52.1 (19.3) | 67.0 (16.9) | 64.2 (15.1) | 50.5 (19.9) | 48.3 (19.5)
95% CI of the Mean | 41.1, 51.4 | 37.3, 47.3 | 46.6, 57.3 | 46.1, 58.0 | 55.6, 78.3 | 53.4, 74.9 | 46.9, 54.1 | 44.5, 52.1
Median (Min-Max) | 49.0 (2.2, 86.9) | 44.0 (11.5, 78.0) | 52.0 (10.0, 85.2) | 53.0 (12.0, 91.1) | 73.0 (30.6, 88.0) | 65.9 (35.0, 85.0) | 50.0 (2.2, 88.0) | 50.6 (11.5, 91.1)
24 Hour Visit
N | 42 | 33 | 31 | 33 | 6 | 6 | 79 | 72
Mean (SD) | 43.0 (21.5) | 45.1 (21.5) | 55.8 (22.2) | 54.8 (15.6) | 57.8 (18.2) | 60.7 (8.8) | 49.1 (22.3) | 50.9 (18.8)
95% CI of the Mean | 36.3, 49.7 | 37.5, 52.8 | 47.7, 64.0 | 49.3, 60.3 | 38.7, 76.9 | 51.4, 70.0 | 44.1, 54.1 | 46.4, 55.3
Median (Min-Max) | 43.0 (4.0, 88.3) | 53.0 (1.7, 79.6) | 57.9 (18.2, 89.7) | 53.0 (28.0, 84.8) | 57.2 (34.0, 87.0) | 59.6 (51.9, 75.0) | 51.0 (4.0, 89.7) | 53.6 (1.7, 84.8)
Change from Baseline to 24 hour Visit
N | 34 | 26 | 27 | 27 | 5 | 5 | 66 | 58
Mean (SD) | −7.0 (19.5) | −0.8 (21.4) | 3.3 (24.6) | 1.3 (25.1) | −14.2 (18.2) | −8.1 (16.2) | −3.3 (22.1) | −0.5 (22.7)
95% CI of the Mean | 0.0, −0.2 | 0.0, 7.9 | 0.0, 13.0 | 0.0, 11.2 | 0.0, 8.4 | 0.0, 12.0 | 0.0, 2.1 | 0.0, 5.5
Median (Min-Max) | −1.1 (−63.3, 21.0) | −1.7 (−35.0, 59.5) | 2.0 (−59.3, 65.9) | −6.4 (−32.6, 63.0) | −16.3 (−42.0, 5.0) | −4.5 (−30.0, 12.0) | −1.1 (−63.3, 65.9) | −2.3 (−35.0, 63.0)

Table 14.3.6.1.7 Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group Lymphocytes (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 60 | 53 | 50 | 43 | 11 | 10 | 121 | 106
Mean (SD) | 38.6 (20.8) | 42.1 (18.7) | 36.0 (18.0) | 37.0 (17.6) | 22.2 (13.9) | 25.9 (12.5) | 36.0 (19.6) | 38.5 (18.2)
95% CI of the Mean | 33.2, 44.0 | 37.0, 47.3 | 30.9, 41.1 | 31.6, 42.4 | 12.8, 31.5 | 17.0, 34.9 | 32.5, 39.5 | 35.0, 42.0
Median (Min-Max) | 38.0 (5.0, 83.9) | 40.0 (9.2, 80.4) | 35.3 (1.6, 71.0) | 38.0 (5.9, 71.0) | 17.9 (6.0, 51.7) | 22.6 (9.0, 52.0) | 34.0 (1.6, 83.9) | 37.5 (5.9, 80.4)
24 Hour Visit
N | 42 | 33 | 31 | 33 | 6 | 6 | 79 | 72
Mean (SD) | 42.6 (21.2) | 39.0 (19.2) | 33.6 (19.3) | 35.9 (14.5) | 31.4 (15.2) | 29.3 (7.6) | 38.2 (20.4) | 36.8 (16.5)
95% CI of the Mean | 36.0, 49.2 | 32.2, 45.9 | 26.5, 40.6 | 30.7, 41.1 | 15.4, 47.4 | 21.3, 37.3 | 33.6, 42.8 | 32.9, 40.7
Median (Min-Max) | 37.2 (5.0, 91.0) | 36.0 (3.3, 77.0) | 31.0 (5.0, 71.0) | 39.0 (10.8, 63.2) | 34.9 (4.0, 46.0) | 31.6 (15.0, 36.9) | 35.8 (4.0, 91.0) | 36.0 (3.3, 77.0)
Change from Baseline to 24 hour Visit
N | 34 | 26 | 27 | 27 | 5 | 5 | 66 | 58
Mean (SD) | 6.9 (14.5) | 3.8 (23.1) | −2.8 (22.0) | 0.0 (24.1) | 12.9 (14.9) | 7.5 (11.9) | 3.4 (18.5) | 2.3 (22.7)
95% CI of the Mean | 1.8, 11.9 | 0.0, 13.1 | 0.0, 5.9 | 0.0, 9.6 | 0.0, 31.4 | 0.0, 22.2 | 0.0, 7.9 | 0.0, 8.3
Median (Min-Max) | 3.6 (−17.9, 43.0) | 4.6 (−49.8, 57.7) | 2.0 (−62.8, 33.4) | 5.8 (−60.2, 29.1) | 15.2 (−2.0, 34.0) | 4.5 (−3.2, 24.0) | 3.0 (−62.8, 43.0) | 4.9 (−60.2, 57.7)

Table 14.3.6.1.8 Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group Monocytes (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 60 | 53 | 50 | 43 | 11 | 10 | 121 | 106
Mean (SD) | 8.4 (5.2) | 8.2 (4.4) | 7.5 (3.1) | 6.9 (4.3) | 8.9 (3.1) | 7.6 (3.1) | 8.1 (4.3) | 7.6 (4.3)
95% CI of the Mean | 7.1, 9.8 | 7.0, 9.4 | 6.6, 8.4 | 5.6, 8.2 | 6.8, 11.0 | 5.4, 9.9 | 7.3, 8.9 | 6.8, 8.4
Median (Min-Max) | 7.9 (0.9, 29.0) | 8.0 (0.6, 23.0) | 7.2 (2.5, 16.0) | 6.4 (1.6, 28.0) | 8.3 (5.4, 15.0) | 7.5 (3.3, 11.0) | 7.5 (0.9, 29.0) | 7.1 (0.6, 28.0)
24 Hour Visit
N | 42 | 33 | 31 | 33 | 6 | 6 | 79 | 72
Mean (SD) | 7.9 (3.6) | 7.7 (3.7) | 7.0 (3.5) | 7.0 (2.6) | 9.3 (3.9) | 8.3 (3.0) | 7.7 (3.6) | 7.5 (3.2)
95% CI of the Mean | 6.8, 9.0 | 6.4, 9.0 | 5.7, 8.3 | 6.1, 8.0 | 5.3, 13.3 | 5.1, 11.5 | 6.8, 8.5 | 6.7, 8.2
Median (Min-Max) | 7.8 (0.0, 15.0) | 8.0 (0.9, 15.0) | 6.4 (2.5, 17.0) | 6.5 (3.4, 13.6) | 9.0 (4.2, 16.0) | 8.3 (4.4, 13.4) | 7.3 (0.0, 17.0) | 7.1 (0.9, 15.0)
Change from Baseline to 24 hour Visit
N | 34 | 26 | 27 | 27 | 5 | 5 | 66 | 58
Mean (SD) | 0.0 (5.1) | −0.1 (4.5) | −0.1 (3.3) | 0.5 (3.0) | 0.8 (2.8) | 1.8 (2.4) | 0.0 (4.2) | 0.4 (3.7)
95% CI of the Mean | 0.0, 1.8 | 0.0, 1.8 | 0.0, 1.2 | 0.0, 1.7 | 0.0, 4.3 | 0.0, 4.7 | 0.0, 1.1 | 0.0, 1.3
Median (Min-Max) | 0.0 (−10.9, 8.6) | 0.0 (−10.5, 7.4) | −0.8 (−7.0, 7.6) | 0.1 (−3.5, 10.9) | 1.2 (−2.1, 4.0) | 2.8 (−2.0, 4.0) | 0.0 (−10.9, 8.6) | 0.2 (−10.5, 10.9)

Table 14.3.6.1.9 Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group Eosinophils (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 55 | 45 | 47 | 42 | 11 | 10 | 113 | 97
Mean (SD) | 1.2 (2.0) | 1.6 (2.2) | 1.9 (2.1) | 1.9 (2.3) | 1.6 (2.5) | 1.3 (1.3) | 1.5 (2.1) | 1.7 (2.2)
95% CI of the Mean | 0.7, 1.8 | 1.0, 2.3 | 1.3, 2.5 | 1.1, 2.6 | 0.0, 3.2 | 0.4, 2.3 | 1.1, 1.9 | 1.3, 2.1
Median (Min-Max) | 0.4 (0.0, 11.3) | 1.0 (0.0, 10.0) | 1.0 (0.0, 9.3) | 1.0 (0.0, 10.5) | 0.1 (0.0, 8.1) | 1.2 (0.0, 3.4) | 0.8 (0.0, 11.3) | 1.0 (0.0, 10.5)
24 Hour Visit
N | 37 | 30 | 29 | 33 | 6 | 6 | 72 | 69
Mean (SD) | 0.8 (1.1) | 1.4 (2.3) | 2.0 (3.2) | 1.5 (1.6) | 1.0 (1.2) | 1.2 (0.6) | 1.3 (2.2) | 1.5 (1.9)
95% CI of the Mean | 0.5, 1.2 | 0.6, 2.3 | 0.8, 3.2 | 1.0, 2.1 | 0.0, 2.3 | 0.6, 1.8 | 0.8, 1.8 | 1.0, 1.9
Median (Min-Max) | 0.6 (0.0, 4.6) | 0.7 (0.0, 8.6) | 1.0 (0.0, 16.2) | 1.2 (0.0, 7.0) | 0.5 (0.0, 3.0) | 1.2 (0.5, 2.0) | 0.8 (0.0, 16.2) | 1.0 (0.0, 8.6)
Change from Baseline to 24 hour Visit
N | 30 | 21 | 25 | 26 | 5 | 5 | 60 | 52
Mean (SD) | −0.3 (2.1) | 0.0 (1.9) | −0.1 (1.6) | −0.3 (2.8) | 0.0 (0.6) | −0.1 (1.5) | −0.2 (1.8) | −0.2 (2.3)
95% CI of the Mean | 0.0, 0.5 | 0.0, 0.9 | 0.0, 0.6 | 0.0, 0.8 | 0.0, 0.7 | 0.0, 1.8 | 0.0, 0.3 | 0.0, 0.5
Median (Min-Max) | 0.0 (−10.1, 2.8) | 0.0 (−3.0, 6.1) | 0.0 (−4.0, 3.0) | 0.0 (−10.4, 4.6) | 0.0 (−1.0, 0.7) | −0.2 (−2.0, 2.0) | 0.0 (−10.1, 3.0) | 0.0 (−10.4, 6.1)

Table 14.3.6.1.10 Summary of Clinical Laboratory Hematology Measurement by Visit and Treatment Group Basophils (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 57 | 43 | 43 | 41 | 11 | 9 | 111 | 93
Mean (SD) | 0.4 (0.6) | 0.3 (0.5) | 0.3 (0.4) | 0.4 (0.5) | 0.3 (0.4) | 0.2 (0.3) | 0.4 (0.5) | 0.3 (0.4)
95% CI of the Mean | 0.3, 0.6 | 0.1, 0.4 | 0.2, 0.4 | 0.2, 0.5 | 0.0, 0.6 | 0.0, 0.4 | 0.3, 0.5 | 0.2, 0.4
Median (Min-Max) | 0.1 (0.0, 2.0) | 0.0 (0.0, 2.0) | 0.2 (0.0, 1.7) | 0.2 (0.0, 1.7) | 0.1 (0.0, 1.3) | 0.1 (0.0, 0.8) | 0.1 (0.0, 2.0) | 0.1 (0.0, 2.0)
24 Hour Visit
N | 38 | 26 | 29 | 32 | 6 | 5 | 73 | 63
Mean (SD) | 0.5 (0.7) | 0.3 (0.5) | 0.3 (0.4) | 0.3 (0.3) | 0.0 (0.1) | 0.6 (0.3) | 0.4 (0.6) | 0.3 (0.4)
95% CI of the Mean | 0.2, 0.7 | 0.1, 0.6 | 0.2, 0.5 | 0.2, 0.4 | 0.0, 0.1 | 0.2, 0.9 | 0.3, 0.5 | 0.2, 0.4
Median (Min-Max) | 0.3 (0.0, 3.0) | 0.0 (0.0, 2.0) | 0.2 (0.0, 1.2) | 0.3 (0.0, 1.0) | 0.0 (0.0, 0.2) | 0.5 (0.3, 1.0) | 0.2 (0.0, 3.0) | 0.3 (0.0, 2.0)
Change from Baseline to 24 hour Visit
N | 32 | 20 | 22 | 26 | 5 | 4 | 59 | 50
Mean (SD) | 0.1 (0.7) | 0.1 (0.6) | 0.0 (0.6) | −0.1 (0.6) | 0.0 (0.1) | 0.4 (0.5) | 0.0 (0.6) | 0.0 (0.6)
95% CI of the Mean | 0.0, 0.3 | 0.0, 0.4 | 0.0, 0.2 | 0.0, 0.1 | 0.0, 0.1 | 0.0, 1.1 | 0.0, 0.2 | 0.0, 0.2
Median (Min-Max) | 0.0 (−1.5, 1.8) | 0.0 (−1.0, 2.0) | 0.0 (−1.7, 1.0) | 0.0 (−1.7, 1.0) | 0.0 (−0.2, 0.1) | 0.3 (−0.1, 1.0) | 0.0 (−1.7, 1.8) | 0.0 (−1.7, 2.0)

Table 14.3.6.2.1 Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group White Blood Count (×10^3^/cumm) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 36 (46.8%) | 38 (53.5%) | 41 (60.3%) | 32 (50.8%) | 11 (64.7%) | 7 (50.0%) | 88 (54.3%) | 77 (52.0%)
Abnormal, Not Clinically Significant | 5 (6.5%) | 7 (9.9%) | 3 (4.4%) | 3 (4.8%) | 0 | 0 | 8 (4.9%) | 10 (6.8%)
Abnormal, Clinically Significant | 22 (28.6%) | 16 (22.5%) | 16 (23.5%) | 16 (25.4%) | 3 (17.6%) | 5 (35.7%) | 41 (25.3%) | 37 (25.0%)
24 Hour Visit
Normal | 33 (42.9%) | 35 (49.3%) | 38 (55.9%) | 38 (60.3%) | 10 (58.8%) | 8 (57.1%) | 81 (50.0%) | 81 (54.7%)
Abnormal, Not Clinically Significant | 5 (6.5%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 7 (4.3%) | 4 (2.7%)
Abnormal, Clinically Significant | 10 (13.0%) | 4 (5.6%) | 4 (5.9%) | 4 (6.3%) | 1 (5.9%) | 1 (7.1%) | 15 (9.3%) | 9 (6.1%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 17 (22.1%) | 19 (26.8%) | 26 (38.2%) | 19 (30.2%) | 8 (47.1%) | 5 (35.7%) | 51 (31.5%) | 43 (29.1%)
Normal - Abnormal,NCS | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Normal - Abnormal,CS | 5 (6.5%) | 1 (1.4%) | 1 (1.5%) | 3 (4.8%) | 0 | 0 | 6 (3.7%) | 4 (2.7%)
Abnormal, NCS - Normal | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 2 (1.4%)
Abnormal, NCS - Abnormal, NCS (no change) | 2 (2.6%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 4 (2.7%)
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 6 (7.8%) | 9 (12.7%) | 9 (13.2%) | 14 (22.2%) | 1 (5.9%) | 2 (14.3%) | 16 (9.9%) | 25 (16.9%)
Abnormal, CS - Abnormal, NCS | 2 (2.6%) | 0 | 0 | 0 | 0 | 0 | 2 (1.2%) | 0
Abnormal, CS - Abnormal, CS (no change) | 3 (3.9%) | 2 (2.8%) | 1 (1.5%) | 0 | 1 (5.9%) | 1 (7.1%) | 5 (3.1%) | 3 (2.0%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.6.2.2 Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group Red Blood Count (×10^3^/cumm) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 36 (46.8%) | 38 (53.5%) | 41 (60.3%) | 32 (50.8%) | 11 (64.7%) | 7 (50.0%) | 88 (54.3%) | 77 (52.0%)
Abnormal, Not Clinically Significant | 5 (6.5%) | 7 (9.9%) | 3 (4.4%) | 3 (4.8%) | 0 | 0 | 8 (4.9%) | 10 (6.8%)
Abnormal, Clinically Significant | 22 (28.6%) | 16 (22.5%) | 16 (23.5%) | 16 (25.4%) | 3 (17.6%) | 5 (35.7%) | 41 (25.3%) | 37 (25.0%)
24 Hour Visit
Normal | 33 (42.9%) | 35 (49.3%) | 38 (55.9%) | 38 (60.3%) | 10 (58.8%) | 8 (57.1%) | 81 (50.0%) | 81 (54.7%)
Abnormal, Not Clinically Significant | 5 (6.5%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 7 (4.3%) | 4 (2.7%)
Abnormal, Clinically Significant | 10 (13.0%) | 4 (5.6%) | 4 (5.9%) | 4 (6.3%) | 1 (5.9%) | 1 (7.1%) | 15 (9.3%) | 9 (6.1%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 17 (22.1%) | 19 (26.8%) | 26 (38.2%) | 19 (30.2%) | 8 (47.1%) | 5 (35.7%) | 51 (31.5%) | 43 (29.1%)
Normal - Abnormal,NCS | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Normal - Abnormal,CS | 5 (6.5%) | 1 (1.4%) | 1 (1.5%) | 3 (4.8%) | 0 | 0 | 6 (3.7%) | 4 (2.7%)
Abnormal, NCS - Normal | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 2 (1.4%)
Abnormal, NCS - Abnormal, NCS (no change) | 2 (2.6%) | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 4 (2.7%)
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 6 (7.8%) | 9 (12.7%) | 9 (13.2%) | 14 (22.2%) | 1 (5.9%) | 2 (14.3%) | 16 (9.9%) | 25 (16.9%)
Abnormal, CS - Abnormal, NCS | 2 (2.6%) | 0 | 0 | 0 | 0 | 0 | 2 (1.2%) | 0
Abnormal, CS - Abnormal, CS (no change) | 3 (3.9%) | 2 (2.8%) | 1 (1.5%) | 0 | 1 (5.9%) | 1 (7.1%) | 5 (3.1%) | 3 (2.0%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.6.2.3 Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group Hemaglobin (g/dL) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 50 (64.9%) | 51 (71.8%) | 48 (70.6%) | 45 (71.4%) | 10 (58.8%) | 8 (57.1%) | 108 (66.7%) | 104 (70.3%)
Abnormal, Not Clinically Significant | 0 | 0 | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 1 (0.6%) | 1 (0.7%)
Abnormal, Clinically Significant | 13 (16.9%) | 10 (14.1%) | 12 (17.6%) | 6 (9.5%) | 3 (17.6%) | 4 (28.6%) | 28 (17.3%) | 20 (13.5%)
24 Hour Visit
Normal | 31 (40.3%) | 31 (43.7%) | 32 (47.1%) | 28 (44.4%) | 8 (47.1%) | 5 (35.7%) | 71 (43.8%) | 64 (43.2%)
Abnormal, Not Clinically Significant | 4 (5.2%) | 1 (1.4%) | 0 | 2 (3.2%) | 0 | 0 | 4 (2.5%) | 3 (2.0%)
Abnormal, Clinically Significant | 13 (16.9%) | 10 (14.1%) | 12 (17.6%) | 13 (20.6%) | 3 (17.6%) | 4 (28.6%) | 28 (17.3%) | 27 (18.2%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 22 (28.6%) | 27 (38.0%) | 25 (36.8%) | 23 (36.5%) | 7 (41.2%) | 4 (28.6%) | 54 (33.3%) | 54 (36.5%)
Normal - Abnormal, NCS | 3 (3.9%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 2 (1.4%)
Normal - Abnormal, CS | 7 (9.1%) | 3 (4.2%) | 7 (10.3%) | 7 (11.1%) | 1 (5.9%) | 0 | 15 (9.3%) | 10 (6.8%)
Abnormal, NCS - Normal | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, NCS (no change) | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 1 (1.3%) | 1 (1.4%) | 6 (8.8%) | 3 (4.8%) | 0 | 1 (7.1%) | 7 (4.3%) | 5 (3.4%)
Abnormal, CS - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, CS - Abnormal, CS (no change) | 4 (5.2%) | 4 (5.6%) | 2 (2.9%) | 3 (4.8%) | 2 (11.8%) | 3 (21.4%) | 8 (4.9%) | 10 (6.8%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.6.2.4 Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group Hematocrit (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 53 (68.8%) | 54 (76.1%) | 45 (66.2%) | 46 (73.0%) | 11 (64.7%) | 9 (64.3%) | 109 (67.3%) | 109 (73.6%)
Abnormal, Not Clinically Significant | 0 | 0 | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 1 (0.6%) | 1 (0.7%)
Abnormal, Clinically Significant | 10 (13.0%) | 7 (9.9%) | 15 (22.1%) | 5 (7.9%) | 2 (11.8%) | 3 (21.4%) | 27 (16.7%) | 15 (10.1%)
24 Hour Visit
Normal | 32 (41.6%) | 34 (47.9%) | 24 (35.3%) | 23 (36.5%) | 8 (47.1%) | 5 (35.7%) | 64 (39.5%) | 62 (41.9%)
Abnormal, Not Clinically Significant | 3 (3.9%) | 1 (1.4%) | 0 | 2 (3.2%) | 0 | 0 | 3 (1.9%) | 3 (2.0%)
Abnormal, Clinically Significant | 13 (16.9%) | 7 (9.9%) | 20 (29.4%) | 18 (28.6%) | 3 (17.6%) | 4 (28.6%) | 36 (22.2%) | 29 (19.6%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 24 (31.2%) | 28 (39.4%) | 17 (25.0%) | 20 (31.7%) | 7 (41.2%) | 5 (35.7%) | 48 (29.6%) | 53 (35.8%)
Normal - Abnormal, NCS | 3 (3.9%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 3 (1.9%) | 2 (1.4%)
Normal - Abnormal, CS | 7 (9.1%) | 4 (5.6%) | 13 (19.1%) | 11 (17.5%) | 2 (11.8%) | 0 | 22 (13.6%) | 15 (10.1%)
Abnormal, NCS - Normal | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, NCS (no change) | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 1 (1.3%) | 2 (2.8%) | 7 (10.3%) | 2 (3.2%) | 0 | 0 | 8 (4.9%) | 4 (2.7%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 3 (3.9%) | 1 (1.4%) | 3 (4.4%) | 3 (4.8%) | 1 (5.9%) | 3 (21.4%) | 7 (4.3%) | 7 (4.7%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.6.2.5 Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group Platelet Count (×10^3^/cumm) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 47 (61.0%) | 45 (63.4%) | 52 (76.5%) | 41 (65.1%) | 14 (82.4%) | 10 (71.4%) | 113 (69.8%) | 96 (64.9%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 2 (2.8%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 3 (2.0%)
Abnormal, Clinically Significant | 15 (19.5%) | 14 (19.7%) | 7 (10.3%) | 9 (14.3%) | 0 | 2 (14.3%) | 22 (13.6%) | 25 (16.9%)
24 Hour Visit
Normal | 37 (48.1%) | 37 (52.1%) | 40 (58.8%) | 35 (55.6%) | 9 (52.9%) | 7 (50.0%) | 86 (53.1%) | 79 (53.4%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
Abnormal, Clinically Significant | 9 (11.7%) | 4 (5.6%) | 2 (2.9%) | 8 (12.7%) | 2 (11.8%) | 2 (14.3%) | 13 (8.0%) | 14 (9.5%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 24 (31.2%) | 28 (39.4%) | 30 (44.1%) | 27 (42.9%) | 9 (52.9%) | 6 (42.9%) | 63 (38.9%) | 61 (41.2%)
Normal - Abnormal, NCS | 0 | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Normal - Abnormal, CS | 6 (7.8%) | 0 | 2 (2.9%) | 3 (4.8%) | 1 (5.9%) | 1 (7.1%) | 9 (5.6%) | 4 (2.7%)
Abnormal, NCS - Normal | 0 | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, NCS - Abnormal, CS | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Abnormal, CS - Normal | 5 (6.5%) | 5 (7.0%) | 6 (8.8%) | 1 (1.6%) | 0 | 0 | 11 (6.8%) | 6 (4.1%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 1 (1.3%) | 0 | 0 | 5 (7.9%) | 0 | 1 (7.1%) | 1 (0.6%) | 6 (4.1%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.6.2.6 Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group Neutrophils (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 33 (42.9%) | 28 (39.4%) | 29 (42.6%) | 26 (41.3%) | 6 (35.3%) | 7 (50.0%) | 68 (42.0%) | 61 (41.2%)
Abnormal, Not Clinically Significant | 3 (3.9%) | 2 (2.8%) | 1 (1.5%) | 0 | 1 (5.9%) | 0 | 5 (3.1%) | 2 (1.4%)
Abnormal, Clinically Significant | 24 (31.2%) | 23 (32.4%) | 20 (29.4%) | 17 (27.0%) | 4 (23.5%) | 3 (21.4%) | 48 (29.6%) | 43 (29.1%)
24 Hour Visit
Normal | 23 (29.9%) | 16 (22.5%) | 15 (22.1%) | 22 (34.9%) | 6 (35.3%) | 4 (28.6%) | 44 (27.2%) | 42 (28.4%)
Abnormal, Not Clinically Significant | 4 (5.2%) | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 5 (3.1%) | 2 (1.4%)
Abnormal, Clinically Significant | 15 (19.5%) | 16 (22.5%) | 15 (22.1%) | 10 (15.9%) | 0 | 2 (14.3%) | 30 (18.5%) | 28 (18.9%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 13 (16.9%) | 10 (14.1%) | 8 (11.8%) | 10 (15.9%) | 4 (23.5%) | 3 (21.4%) | 25 (15.4%) | 23 (15.5%)
Normal - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Normal - Abnormal, CS | 2 (2.6%) | 4 (5.6%) | 5 (7.4%) | 3 (4.8%) | 0 | 1 (7.1%) | 7 (4.3%) | 8 (5.4%)
Abnormal, NCS - Normal | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Abnormal, NCS - Abnormal, NCS (no change) | 2 (2.6%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 1 (0.7%)
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 5 (6.5%) | 2 (2.8%) | 7 (10.3%) | 8 (12.7%) | 1 (5.9%) | 1 (7.1%) | 13 (8.0%) | 11 (7.4%)
Abnormal, CS - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, CS - Abnormal, CS (no change) | 9 (11.7%) | 8 (11.3%) | 6 (8.8%) | 5 (7.9%) | 0 | 0 | 15 (9.3%) | 13 (8.8%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.6.2.7 Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group Lymphocytes (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 30 (39.0%) | 25 (35.2%) | 30 (44.1%) | 25 (39.7%) | 7 (41.2%) | 7 (50.0%) | 67 (41.4%) | 57 (38.5%)
Abnormal, Not Clinically Significant | 3 (3.9%) | 1 (1.4%) | 0 | 0 | 1 (5.9%) | 0 | 4 (2.5%) | 1 (0.7%)
Abnormal, Clinically Significant | 27 (35.1%) | 27 (38.0%) | 20 (29.4%) | 18 (28.6%) | 3 (17.6%) | 3 (21.4%) | 50 (30.9%) | 48 (32.4%)
24 Hour Visit
Normal | 23 (29.9%) | 20 (28.2%) | 16 (23.5%) | 20 (31.7%) | 6 (35.3%) | 5 (35.7%) | 45 (27.8%) | 45 (30.4%)
Abnormal, Not Clinically Significant | 5 (6.5%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 5 (3.1%) | 2 (1.4%)
Abnormal, Clinically Significant | 14 (18.2%) | 12 (16.9%) | 15 (22.1%) | 12 (19.0%) | 0 | 1 (7.1%) | 29 (17.9%) | 25 (16.9%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 15 (19.5%) | 12 (16.9%) | 10 (14.7%) | 9 (14.3%) | 4 (23.5%) | 3 (21.4%) | 29 (17.9%) | 24 (16.2%)
Normal - Abnormal, NCS | 1 (1.3%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
Normal - Abnormal, CS | 3 (3.9%) | 2 (2.8%) | 4 (5.9%) | 2 (3.2%) | 0 | 0 | 7 (4.3%) | 4 (2.7%)
Abnormal, NCS - Normal | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Abnormal, NCS - Abnormal, NCS (no change) | 3 (3.9%) | 0 | 0 | 0 | 0 | 0 | 3 (1.9%) | 0
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 4 (5.2%) | 3 (4.2%) | 5 (7.4%) | 7 (11.1%) | 1 (5.9%) | 1 (7.1%) | 10 (6.2%) | 11 (7.4%)
Abnormal, CS - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, CS - Abnormal, CS (no change) | 7 (9.1%) | 7 (9.9%) | 8 (11.8%) | 8 (12.7%) | 0 | 1 (7.1%) | 15 (9.3%) | 16 (10.8%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.6.2.8 Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group Monocytes (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 51 (66.2%) | 40 (56.3%) | 38 (55.9%) | 34 (54.0%) | 5 (29.4%) | 9 (64.3%) | 94 (58.0%) | 83 (56.1%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 2 (2.8%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 2 (1.4%)
Abnormal, Clinically Significant | 8 (10.4%) | 11 (15.5%) | 12 (17.6%) | 9 (14.3%) | 6 (35.3%) | 1 (7.1%) | 26 (16.0%) | 21 (14.2%)
24 Hour Visit
Normal | 39 (50.6%) | 24 (33.8%) | 25 (36.8%) | 27 (42.9%) | 6 (35.3%) | 5 (35.7%) | 70 (43.2%) | 56 (37.8%)
Abnormal, Not Clinically Significant | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, Clinically Significant | 3 (3.9%) | 9 (12.7%) | 6 (8.8%) | 6 (9.5%) | 0 | 1 (7.1%) | 9 (5.6%) | 16 (10.8%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 28 (36.4%) | 14 (19.7%) | 19 (27.9%) | 18 (28.6%) | 4 (23.5%) | 3 (21.4%) | 51 (31.5%) | 35 (23.6%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Normal - Abnormal, CS | 2 (2.6%) | 4 (5.6%) | 1 (1.5%) | 2 (3.2%) | 0 | 1 (7.1%) | 3 (1.9%) | 7 (4.7%)
Abnormal, NCS - Normal | 1 (1.3%) | 2 (2.8%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 2 (1.4%)
Abnormal, NCS - Abnormal, NCS (no change) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 3 (3.9%) | 2 (2.8%) | 4 (5.9%) | 4 (6.3%) | 1 (5.9%) | 1 (7.1%) | 8 (4.9%) | 7 (4.7%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 0 | 4 (5.6%) | 3 (4.4%) | 3 (4.8%) | 0 | 0 | 3 (1.9%) | 7 (4.7%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.6.2.9 Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group Eosinophils (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 51 (66.2%) | 44 (62.0%) | 46 (67.6%) | 39 (61.9%) | 10 (58.8%) | 10 (71.4%) | 107 (66.0%) | 93 (62.8%)
Abnormal, Not Clinically Significant | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, Clinically Significant | 4 (5.2%) | 1 (1.4%) | 1 (1.5%) | 3 (4.8%) | 1 (5.9%) | 0 | 6 (3.7%) | 4 (2.7%)
24 Hour Visit
Normal | 36 (46.8%) | 27 (38.0%) | 26 (38.2%) | 31 (49.2%) | 6 (35.3%) | 6 (42.9%) | 68 (42.0%) | 64 (43.2%)
Abnormal, Not Clinically Significant | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, Clinically Significant | 0 | 3 (4.2%) | 2 (2.9%) | 2 (3.2%) | 0 | 0 | 2 (1.2%) | 5 (3.4%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 28 (36.4%) | 19 (26.8%) | 22 (32.4%) | 23 (36.5%) | 5 (29.4%) | 5 (35.7%) | 55 (34.0%) | 47 (31.8%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Normal - Abnormal, CS | 0 | 1 (1.4%) | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
Abnormal, NCS - Normal | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, NCS (no change) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 1 (1.3%) | 0 | 1 (1.5%) | 2 (3.2%) | 0 | 0 | 2 (1.2%) | 2 (1.4%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.6.2.10 Summary of Clinical Laboratory Hematology Assessment by Visit and Treatment Group Basophils (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 54 (70.1%) | 43 (60.6%) | 42 (61.8%) | 41 (65.1%) | 11 (64.7%) | 8 (57.1%) | 107 (66.0%) | 92 (62.2%)
Abnormal, Not Clinically Significant | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, Clinically Significant | 3 (3.9%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 1 (7.1%) | 4 (2.5%) | 2 (1.4%)
24 Hour Visit
Normal | 36 (46.8%) | 26 (36.6%) | 27 (39.7%) | 32 (50.8%) | 6 (35.3%) | 4 (28.6%) | 69 (42.6%) | 62 (41.9%)
Abnormal, Not Clinically Significant | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, Clinically Significant | 2 (2.6%) | 0 | 1 (1.5%) | 0 | 0 | 1 (7.1%) | 3 (1.9%) | 1 (0.7%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 30 (39.0%) | 21 (29.6%) | 20 (29.4%) | 26 (41.3%) | 5 (29.4%) | 3 (21.4%) | 55 (34.0%) | 50 (33.8%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Normal - Abnormal, CS | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, NCS - Normal | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, NCS (no change) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 0
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.1.1 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group Glucose (mg/dL) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 39 | 41 | 39 | 30 | 7 | 7 | 85 | 78
Mean (SD) | 144.6 (48.5) | 124.2 (37.9) | 138.9 (40.1) | 120.3 (37.0) | 112.4 (31.8) | 103.9 (25.7) | 139.4 (44.0) | 120.9 (36.7)
95% CI of the Mean | 128.9, 160.4 | 112.3, 136.2 | 125.9, 151.9 | 106.5, 134.1 | 83.0, 141.8 | 80.1, 127.6 | 129.9, 148.9 | 112.6, 129.2
Median (Min-Max) | 136.0 (49.0, 257.0) | 124.0 (56.0, 217.0) | 128.0 (68.0, 278.0) | 116.5 (70.0, 226.0) | 115.0 (74.0, 171.0) | 100.0 (59.0, 141.0) | 125.0 (49.0, 278.0) | 114.0 (56.0, 226.0)
24 Hour Visit
N | 19 | 16 | 19 | 19 | 4 | 3 | 42 | 38
Mean (SD) | 110.6 (41.0) | 96.3 (20.8) | 96.3 (17.4) | 102.3 (14.4) | 109.5 (14.5) | 79.7 (11.0) | 104.0 (30.6) | 98.0 (17.9)
95% CI of the Mean | 90.8, 130.3 | 85.2, 107.4 | 87.9, 104.7 | 95.4, 109.2 | 86.3, 132.7 | 52.3, 107.0 | 94.5, 113.6 | 92.1, 103.9
Median (Min-Max) | 100.0 (64.0, 248.0) | 91.5 (64.0, 145.0) | 93.0 (79.0, 146.0) | 102.0 (79.0, 129.0) | 109.0 (96.0, 124.0) | 79.0 (69.0, 91.0) | 93.5 (64.0, 248.0) | 95.5 (64.0, 145.0)
Change from Baseline to 24 hour Visit
N | 13 | 12 | 15 | 14 | 3 | 2 | 31 | 28
Mean (SD) | −20.5 (56.4) | −34.3 (34.3) | −33.7 (53.2) | −12.1 (35.4) | −32.3 (37.5) | 5.5 (20.5) | −28.0 (52.2) | −20.3 (35.6)
95% CI of the Mean | 0.0, 13.5 | 0.0, −12.5 | 0.0, −4.2 | 0.0, 8.3 | 0.0, 60.9 | 0.0, 189.7 | 0.0, −8.9 | 0.0, −6.5
Median (Min-Max) | −25.0 (−155.0, 97.0) | −36.0 (−84.0, 17.0) | −29.0 (−188.0, 34.0) | −0.5 (−99.0, 21.0) | −25.0 (−73.0, 1.0) | 5.5 (−9.0, 20.0) | −25.0 (−188.0, 97.0) | −7.0 (−99.0, 21.0)

Table 14.3.7.1.2 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group GGT (U/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 48 | 38 | 46 | 37 | 10 | 9 | 104 | 84
Mean (SD) | 23.7 (35.0) | 44.9 (63.9) | 30.5 (57.1) | 26.6 (23.1) | 30.0 (16.4) | 23.6 (9.4) | 27.3 (44.9) | 34.6 (46.4)
95% CI of the Mean | 13.6, 33.9 | 23.9, 65.9 | 13.6, 47.5 | 18.9, 34.4 | 18.3, 41.7 | 16.3, 30.8 | 18.6, 36.1 | 24.5, 44.6
Median (Min-Max) | 15.0 (2.0, 242.0) | 17.5 (3.0, 288.0) | 18.5 (9.0, 394.0) | 20.0 (9.0, 130.0) | 25.0 (10.0, 69.0) | 22.0 (9.0, 36.0) | 18.0 (2.0, 394.0) | 20.5 (3.0, 288.0)
24 Hour Visit
N | 42 | 37 | 43 | 38 | 10 | 7 | 95 | 82
Mean (SD) | 17.7 (9.7) | 23.1 (24.9) | 20.5 (14.5) | 25.0 (21.6) | 28.1 (23.0) | 19.6 (7.6) | 20.1 (14.0) | 23.7 (22.3)
95% CI of the Mean | 14.7, 20.7 | 14.8, 31.4 | 16.0, 24.9 | 17.9, 32.1 | 11.6, 44.6 | 12.5, 26.6 | 17.2, 22.9 | 18.8, 28.6
Median (Min-Max) | 14.5 (2.0, 50.0) | 16.0 (2.0, 118.0) | 15.0 (8.0, 90.0) | 18.0 (9.0, 122.0) | 20.5 (15.0, 92.0) | 19.0 (10.0, 30.0) | 15.0 (2.0, 92.0) | 17.0 (2.0, 122.0)
Change from Baseline to 24 hour Visit
N | 30 | 22 | 29 | 26 | 7 | 6 | 66 | 54
Mean (SD) | −1.7 (5.0) | −9.0 (17.5) | −0.1 (4.9) | −2.1 (3.4) | −3.7 (2.8) | −2.7 (2.7) | −1.2 (4.8) | −4.9 (11.8)
95% CI of the Mean | 0.0, 0.2 | 0.0, −1.2 | 0.0, 1.7 | 0.0, −0.7 | 0.0, −1.2 | 0.0, 0.2 | 0.0, 0.0 | 0.0, −1.7
Median (Min-Max) | −0.5 (−18.0, 10.0) | −3.0 (−75.0, 6.0) | −1.0 (−11.0, 16.0) | −1.5 (−10.0, 3.0) | −2.0 (−8.0, −1.0) | −3.0 (−6.0, 1.0) | −1.0 (−18.0, 16.0) | −2.0 (−75.0, 6.0)

Table 14.3.7.1.3 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group Sodium (mEq/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 65 | 63 | 59 | 53 | 14 | 14 | 138 | 130
Mean (SD) | 137.1 (4.6) | 136.0 (4.1) | 139.2 (4.1) | 138.6 (3.5) | 139.1 (5.7) | 140.1 (4.1) | 138.2 (4.6) | 137.5 (4.2)
95% CI of the Mean | 136.0, 138.3 | 134.9, 137.0 | 138.1, 140.2 | 137.6, 139.6 | 135.9, 142.4 | 137.7, 142.5 | 137.4, 139.0 | 136.8, 138.2
Median (Min-Max) | 137.0 (125.0, 151.0) | 137.0 (121.0, 143.0) | 139.0 (131.0, 158.0) | 138.0 (131.0, 150.0) | 139.0 (125.0, 150.0) | 140.0 (130.0, 146.0) | 138.0 (125.0, 158.0) | 138.0 (121.0, 150.0)
24 Hour Visit
N | 50 | 46 | 44 | 45 | 11 | 9 | 105 | 100
Mean (SD) | 137.8 (3.6) | 137.2 (3.1) | 139.0 (3.6) | 138.1 (3.1) | 139.9 (3.0) | 138.1 (2.1) | 138.5 (3.6) | 137.7 (3.0)
95% CI of the Mean | 136.8, 138.9 | 136.3, 138.1 | 137.9, 140.1 | 137.2, 139.1 | 137.9, 142.0 | 136.5, 139.8 | 137.8, 139.2 | 137.1, 138.3
Median (Min-Max) | 137.5 (133.0, 157.0) | 137.5 (127.0, 144.0) | 139.0 (130.0, 152.0) | 138.0 (133.0, 147.0) | 140.0 (135.0, 143.0) | 138.0 (135.0, 141.0) | 138.0 (130.0, 157.0) | 138.0 (127.0, 147.0)
Change from Baseline to 24 hour Visit
N | 43 | 40 | 39 | 37 | 10 | 9 | 92 | 86
Mean (SD) | 1.1 (4.0) | 1.8 (5.1) | −0.3 (3.8) | −0.3 (2.6) | −0.5 (4.8) | −2.2 (3.2) | 0.3 (4.0) | 0.5 (4.2)
95% CI of the Mean | 0.0, 2.3 | 0.2, 3.4 | 0.0, 0.9 | 0.0, 0.6 | 0.0, 2.9 | 0.0, 0.2 | 0.0, 1.2 | 0.0, 1.4
Median (Min-Max) | 0.0 (−8.0, 11.0) | 1.0 (−9.0, 16.0) | 0.0 (−9.0, 9.0) | 0.0 (−8.0, 5.0) | 0.5 (−8.0, 8.0) | −1.0 (−7.0, 1.0) | 0.0 (−9.0, 11.0) | 0.0 (−9.0, 16.0)

Table 14.3.7.1.4 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group Potassium (mEq/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 65 | 61 | 58 | 53 | 14 | 14 | 137 | 128
Mean (SD) | 4.4 (0.6) | 4.5 (0.8) | 4.0 (0.5) | 4.0 (0.5) | 4.4 (1.2) | 4.0 (0.6) | 4.2 (0.7) | 4.2 (0.7)
95% CI of the Mean | 4.2, 4.5 | 4.3, 4.7 | 3.8, 4.1 | 3.9, 4.1 | 3.7, 5.0 | 3.6, 4.3 | 4.1, 4.3 | 4.1, 4.3
Median (Min-Max) | 4.3 (3.3, 6.0) | 4.4 (3.2, 7.0) | 4.0 (3.0, 5.3) | 3.9 (3.2, 5.3) | 4.1 (3.0, 8.0) | 4.0 (3.1, 5.2) | 4.2 (3.0, 8.0) | 4.1 (3.1, 7.0)
24 Hour Visit
N | 49 | 46 | 44 | 45 | 11 | 9 | 104 | 100
Mean (SD) | 4.3 (0.5) | 4.3 (0.7) | 4.1 (1.0) | 3.9 (0.6) | 4.0 (0.2) | 3.6 (0.3) | 4.2 (0.8) | 4.1 (0.7)
95% CI of the Mean | 4.2, 4.5 | 4.1, 4.5 | 3.8, 4.4 | 3.8, 4.1 | 3.8, 4.1 | 3.5, 3.8 | 4.0, 4.3 | 3.9, 4.2
Median (Min-Max) | 4.3 (2.9, 5.7) | 4.3 (2.8, 6.5) | 3.9 (3.0, 8.4) | 3.9 (2.0, 5.3) | 3.9 (3.7, 4.3) | 3.6 (3.3, 4.0) | 4.0 (2.9, 8.4) | 4.0 (2.0, 6.5)
Change from Baseline to 24 hour Visit
N | 42 | 39 | 38 | 37 | 10 | 9 | 90 | 85
Mean (SD) | 0.0 (0.8) | −0.1 (1.0) | 0.1 (1.0) | 0.0 (0.7) | −0.4 (1.3) | −0.3 (0.4) | 0.0 (1.0) | −0.1 (0.9)
95% CI of the Mean | 0.0, 0.2 | 0.0, 0.3 | 0.0, 0.5 | 0.0, 0.2 | 0.0, 0.6 | 0.0, 0.0 | 0.0, 0.2 | 0.0, 0.1
Median (Min-Max) | 0.1 (−2.5, 1.9) | −0.1 (−2.6, 3.0) | −0.1 (−1.3, 4.2) | 0.1 (−2.0, 1.0) | −0.1 (−4.0, 0.7) | −0.3 (−1.2, 0.4) | 0.0 (−4.0, 4.2) | 0.0 (−2.6, 3.0)

Table 14.3.7.1.5 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group Chloride (mEq/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 64 | 63 | 59 | 53 | 14 | 13 | 137 | 129
Mean (SD) | 103.1 (5.2) | 101.9 (3.7) | 103.8 (3.7) | 103.7 (3.4) | 102.1 (5.9) | 104.3 (4.5) | 103.3 (4.7) | 102.9 (3.8)
95% CI of the Mean | 101.8, 104.4 | 101.0, 102.8 | 102.8, 104.7 | 102.8, 104.7 | 98.7, 105.6 | 101.6, 107.0 | 102.5, 104.1 | 102.2, 103.5
Median (Min-Max) | 103.0 (93.0, 128.0) | 102.0 (86.0, 108.0) | 104.0 (95.0, 118.0) | 104.0 (98.0, 115.0) | 101.5 (87.0, 115.0) | 104.0 (92.0, 110.0) | 103.0 (87.0, 128.0) | 103.0 (86.0, 115.0)
24 Hour Visit
N | 50 | 46 | 44 | 45 | 11 | 9 | 105 | 100
Mean (SD) | 105.0 (4.2) | 105.0 (3.2) | 105.0 (4.0) | 104.5 (3.5) | 105.7 (3.4) | 106.0 (2.8) | 105.1 (4.0) | 104.9 (3.3)
95% CI of the Mean | 103.8, 106.2 | 104.1, 106.0 | 103.8, 106.2 | 103.5, 105.6 | 103.4, 108.0 | 103.9, 108.1 | 104.3, 105.9 | 104.2, 105.5
Median (Min-Max) | 105.0 (98.0, 121.0) | 105.0 (97.0, 112.0) | 104.5 (99.0, 118.0) | 104.0 (98.0, 112.0) | 105.0 (101.0, 112.0) | 106.0 (103.0, 111.0) | 105.0 (98.0, 121.0) | 105.0 (97.0, 112.0)
Change from Baseline to 24 hour Visit
N | 42 | 40 | 39 | 37 | 10 | 9 | 91 | 86
Mean (SD) | 1.8 (5.4) | 3.5 (5.1) | 1.1 (3.7) | 0.8 (3.5) | 2.4 (5.9) | 0.2 (3.2) | 1.6 (4.8) | 2.0 (4.5)
95% CI of the Mean | 0.1, 3.5 | 1.9, 5.1 | 0.0, 2.3 | 0.0, 2.0 | 0.0, 6.6 | 0.0, 2.7 | 0.6, 2.6 | 1.0, 2.9
Median (Min-Max) | 2.0 (−19.0, 14.0) | 2.0 (−5.0, 20.0) | 0.0 (−5.0, 15.0) | 1.0 (−10.0, 8.0) | 2.0 (−9.0, 12.0) | 1.0 (−6.0, 5.0) | 2.0 (−19.0, 15.0) | 1.0 (−10.0, 20.0)

Table 14.3.7.1.6 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group Carbon Dioxide (mEq/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 65 | 63 | 58 | 53 | 14 | 13 | 137 | 129
Mean (SD) | 21.6 (3.7) | 22.4 (3.4) | 23.3 (3.8) | 23.4 (2.9) | 22.2 (3.8) | 20.9 (5.0) | 22.4 (3.8) | 22.7 (3.5)
95% CI of the Mean | 20.7, 22.5 | 21.5, 23.2 | 22.4, 24.3 | 22.6, 24.2 | 20.0, 24.4 | 17.9, 23.9 | 21.8, 23.0 | 22.0, 23.3
Median (Min-Max) | 22.0 (12.0, 32.0) | 22.0 (15.0, 30.0) | 24.0 (10.0, 30.0) | 23.0 (17.0, 30.0) | 21.5 (17.0, 28.0) | 22.0 (9.0, 28.0) | 23.0 (10.0, 32.0) | 23.0 (9.0, 30.0)
24 Hour Visit
N | 50 | 46 | 44 | 45 | 11 | 9 | 105 | 100
Mean (SD) | 22.8 (4.9) | 22.3 (2.9) | 23.5 (3.1) | 23.3 (2.9) | 25.5 (1.9) | 24.4 (3.2) | 23.4 (4.0) | 23.0 (3.0)
95% CI of the Mean | 21.4, 24.2 | 21.5, 23.2 | 22.6, 24.5 | 22.5, 24.2 | 24.2, 26.7 | 22.0, 26.9 | 22.6, 24.2 | 22.4, 23.6
Median (Min-Max) | 22.5 (12.0, 46.0) | 22.0 (15.0, 31.0) | 24.0 (15.0, 32.0) | 23.0 (16.0, 29.0) | 26.0 (22.0, 28.0) | 25.0 (20.0, 30.0) | 23.0 (12.0, 46.0) | 23.0 (15.0, 31.0)
Change from Baseline to 24 hour Visit
N | 43 | 40 | 38 | 37 | 10 | 9 | 91 | 86
Mean (SD) | 2.0 (5.7) | 0.2 (3.8) | 0.9 (3.9) | −0.2 (3.6) | 4.0 (3.9) | 3.3 (4.9) | 1.7 (4.9) | 0.3 (3.9)
95% CI of the Mean | 0.2, 3.7 | 0.0, 1.4 | 0.0, 2.2 | 0.0, 1.0 | 1.2, 6.8 | 0.0, 7.1 | 0.7, 2.7 | 0.0, 1.2
Median (Min-Max) | 2.0 (−10.0, 30.0) | 0.0 (−9.0, 8.0) | 0.0 (−6.0, 13.0) | 0.0 (−10.0, 7.0) | 3.5 (−2.0, 11.0) | 2.0 (−4.0, 11.0) | 1.0 (−10.0, 30.0) | 0.5 (−10.0, 11.0)

Table 14.3.7.1.7 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group BUN (mg/dL) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 63 | 64 | 61 | 52 | 13 | 13 | 137 | 129
Mean (SD) | 12.8 (7.2) | 11.4 (5.4) | 12.4 (8.7) | 12.2 (3.6) | 16.2 (12.4) | 13.8 (4.5) | 12.9 (8.5) | 12.0 (4.7)
95% CI of the Mean | 11.0, 14.6 | 10.0, 12.8 | 10.2, 14.6 | 11.2, 13.1 | 8.6, 23.7 | 11.1, 16.6 | 11.5, 14.4 | 11.1, 12.8
Median (Min-Max) | 11.0 (4.0, 51.0) | 10.0 (3.0, 34.0) | 11.0 (6.0, 75.0) | 12.0 (7.0, 25.0) | 12.0 (6.0, 54.0) | 13.0 (7.0, 21.0) | 11.0 (4.0, 75.0) | 11.0 (3.0, 34.0)
24 Hour Visit
N | 49 | 46 | 44 | 45 | 11 | 9 | 104 | 100
Mean (SD) | 8.8 (7.1) | 6.3 (3.0) | 8.8 (5.7) | 9.3 (5.0) | 11.5 (7.2) | 9.9 (3.6) | 9.1 (6.5) | 8.0 (4.3)
95% CI of the Mean | 6.7, 10.8 | 5.5, 7.2 | 7.1, 10.6 | 7.8, 10.8 | 6.6, 16.3 | 7.1, 12.6 | 7.8, 10.4 | 7.1, 8.9
Median (Min-Max) | 6.0 (2.0, 36.0) | 6.5 (1.0, 14.0) | 8.0 (2.0, 38.0) | 8.0 (1.0, 24.0) | 8.0 (5.0, 27.0) | 10.0 (4.0, 15.0) | 8.0 (2.0, 38.0) | 8.0 (1.0, 24.0)
Change from Baseline to 24 hour Visit
N | 40 | 41 | 40 | 36 | 9 | 9 | 89 | 86
Mean (SD) | −4.8 (4.3) | −5.8 (5.7) | −4.6 (6.5) | −3.6 (4.2) | −6.2 (8.3) | −4.7 (4.1) | −4.8 (5.8) | −4.7 (5.0)
95% CI of the Mean | 0.0, −3.4 | 0.0, −4.0 | 0.0, −2.5 | 0.0, −2.2 | 0.0, 0.1 | 0.0, −1.5 | 0.0, −3.6 | 0.0, −3.7
Median (Min-Max) | −3.0 (−18.0, 0.0) | −4.0 (−25.0, 3.0) | −3.0 (−37.0, 4.0) | −3.0 (−12.0, 5.0) | −5.0 (−27.0, 0.0) | −4.0 (−14.0, 0.0) | −3.0 (−37.0, 4.0) | −3.0 (−25.0, 5.0)

Table 14.3.7.1.8 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group Creatinine (mg/dL) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 63 | 63 | 59 | 52 | 14 | 13 | 136 | 128
Mean (SD) | 0.5 (0.8) | 0.3 (0.1) | 0.5 (0.3) | 0.5 (0.2) | 1.1 (1.6) | 0.8 (0.2) | 0.6 (0.8) | 0.4 (0.2)
95% CI of the Mean | 0.3, 0.7 | 0.3, 0.4 | 0.4, 0.6 | 0.4, 0.5 | 0.2, 2.0 | 0.7, 1.0 | 0.4, 0.7 | 0.4, 0.5
Median (Min-Max) | 0.4 (0.1, 6.5) | 0.3 (0.1, 0.6) | 0.5 (0.2, 2.9) | 0.4 (0.2, 1.4) | 0.7 (0.4, 6.5) | 0.9 (0.6, 1.4) | 0.4 (0.1, 6.5) | 0.4 (0.1, 1.4)
24 Hour Visit
N | 49 | 45 | 45 | 43 | 11 | 9 | 105 | 97
Mean (SD) | 0.4 (0.4) | 0.3 (0.1) | 0.4 (0.1) | 0.5 (0.5) | 1.0 (1.1) | 0.7 (0.2) | 0.5 (0.5) | 0.4 (0.3)
95% CI of the Mean | 0.3, 0.5 | 0.3, 0.3 | 0.4, 0.5 | 0.4, 0.6 | 0.2, 1.8 | 0.6, 0.9 | 0.4, 0.6 | 0.4, 0.5
Median (Min-Max) | 0.3 (0.2, 2.7) | 0.3 (0.1, 0.5) | 0.4 (0.2, 0.8) | 0.4 (0.2, 3.4) | 0.8 (0.4, 4.4) | 0.7 (0.5, 1.0) | 0.4 (0.2, 4.4) | 0.3 (0.1, 3.4)
Change from Baseline to 24 hour Visit
N | 40 | 39 | 39 | 34 | 10 | 9 | 89 | 82
Mean (SD) | −0.2 (0.6) | −0.1 (0.1) | −0.1 (0.4) | 0.0 (0.5) | −0.3 (0.7) | −0.1 (0.2) | −0.1 (0.5) | 0.0 (0.4)
95% CI of the Mean | 0.0, 0.0 | 0.0, 0.0 | 0.0, 0.0 | 0.0, 0.2 | 0.0, 0.2 | 0.0, 0.0 | 0.0, 0.0 | 0.0, 0.1
Median (Min-Max) | −0.1 (−3.8, 0.2) | 0.0 (−0.5, 0.2) | 0.0 (−2.2, 0.1) | 0.0 (−0.7, 3.0) | 0.0 (−2.1, 0.0) | −0.1 (−0.3, 0.1) | 0.0 (−3.8, 0.2) | 0.0 (−0.7, 3.0)

Table 14.3.7.1.9 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group Calcium (mg/dL) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 64 | 60 | 55 | 52 | 14 | 13 | 133 | 125
Mean (SD) | 9.4 (0.6) | 9.3 (0.6) | 9.1 (0.6) | 9.0 (0.6) | 9.2 (0.5) | 9.1 (0.6) | 9.3 (0.6) | 9.2 (0.6)
95% CI of the Mean | 9.2, 9.5 | 9.1, 9.5 | 9.0, 9.3 | 8.9, 9.2 | 8.9, 9.5 | 8.8, 9.5 | 9.2, 9.4 | 9.1, 9.3
Median (Min-Max) | 9.4 (7.9, 10.5) | 9.3 (7.8, 10.8) | 9.2 (6.8, 10.6) | 9.1 (7.1, 10.0) | 9.2 (8.4, 10.2) | 9.2 (7.9, 10.0) | 9.3 (6.8, 10.6) | 9.2 (7.1, 10.8)
24 Hour Visit
N | 48 | 45 | 43 | 43 | 11 | 9 | 102 | 97
Mean (SD) | 9.3 (0.6) | 9.2 (0.7) | 9.0 (0.6) | 9.1 (0.6) | 8.8 (0.6) | 8.6 (1.0) | 9.2 (0.6) | 9.1 (0.7)
95% CI of the Mean | 9.2, 9.5 | 9.0, 9.4 | 8.9, 9.2 | 8.9, 9.3 | 8.5, 9.2 | 7.8, 9.3 | 9.0, 9.3 | 8.9, 9.2
Median (Min-Max) | 9.3 (7.5, 10.3) | 9.2 (7.7, 10.9) | 9.2 (7.1, 10.1) | 9.1 (7.5, 9.9) | 8.8 (7.6, 9.8) | 8.8 (6.5, 9.5) | 9.3 (7.1, 10.3) | 9.1 (6.5, 10.9)
Change from Baseline to 24 hour Visit
N | 40 | 38 | 35 | 35 | 10 | 9 | 85 | 82
Mean (SD) | 0.1 (0.7) | −0.1 (0.6) | −0.2 (0.7) | 0.0 (0.7) | −0.2 (0.6) | −0.6 (0.7) | −0.1 (0.7) | −0.1 (0.7)
95% CI of the Mean | 0.0, 0.3 | 0.0, 0.1 | 0.0, 0.0 | 0.0, 0.2 | 0.0, 0.2 | 0.0, −0.1 | 0.0, 0.1 | 0.0, 0.0
Median (Min-Max) | 0.1 (−2.2, 1.4) | 0.0 (−1.6, 1.1) | −0.2 (−1.4, 1.5) | 0.0 (−1.8, 1.6) | −0.3 (−1.3, 0.8) | −0.4 (−2.2, 0.0) | 0.0 (−2.2, 1.5) | 0.0 (−2.2, 1.6)

Table 14.3.7.1.10 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group ALT (U/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 54 | 47 | 58 | 43 | 12 | 12 | 124 | 102
Mean (SD) | 39.3 (56.2) | 32.2 (17.5) | 40.6 (72.7) | 26.0 (11.4) | 47.2 (75.1) | 29.5 (22.5) | 40.7 (65.7) | 29.3 (16.0)
95% CI of the Mean | 24.0, 54.6 | 27.1, 37.4 | 21.5, 59.8 | 22.5, 29.6 | 0.0, 94.9 | 15.2, 43.8 | 29.0, 52.4 | 26.1, 32.4
Median (Min-Max) | 30.5 (6.0, 429.0) | 33.0 (6.0, 82.0) | 24.5 (6.0, 477.0) | 25.0 (5.0, 53.0) | 28.0 (6.0, 281.0) | 23.5 (8.0, 94.0) | 27.5 (6.0, 477.0) | 25.5 (5.0, 94.0)
24 Hour Visit
N | 46 | 43 | 44 | 44 | 11 | 9 | 101 | 96
Mean (SD) | 79.7 (337.7) | 28.7 (12.0) | 46.1 (106.4) | 24.1 (13.3) | 40.8 (67.4) | 27.7 (23.4) | 60.8 (238.6) | 26.5 (14.0)
95% CI of the Mean | 0.0, 179.9 | 25.0, 32.4 | 13.8, 78.5 | 20.1, 28.2 | 0.0, 86.1 | 9.7, 45.6 | 13.7, 107.9 | 23.7, 29.3
Median (Min-Max) | 26.5 (10.0, 2318.0) | 31.0 (3.0, 54.0) | 21.5 (4.0, 695.0) | 21.5 (2.0, 51.0) | 21.0 (5.0, 242.0) | 21.0 (10.0, 83.0) | 24.0 (4.0, 2318.0) | 24.5 (2.0, 83.0)
Change from Baseline to 24 hour Visit
N | 29 | 28 | 37 | 31 | 9 | 8 | 75 | 67
Mean (SD) | 64.0 (351.1) | −0.8 (10.5) | 11.3 (113.9) | −0.1 (8.0) | −5.1 (14.5) | −3.3 (4.8) | 29.7 (231.9) | −0.8 (8.8)
95% CI of the Mean | 0.0, 197.6 | 0.0, 3.3 | 0.0, 49.2 | 0.0, 2.8 | 0.0, 6.0 | 0.0, 0.8 | 0.0, 83.0 | 0.0, 1.4
Median (Min-Max) | 1.0 (−34.0, 1889.0) | −2.5 (−23.0, 39.0) | −2.0 (−133.0, 668.0) | 0.0 (−17.0, 15.0) | −5.0 (−39.0, 13.0) | −3.0 (−11.0, 4.0) | −1.0 (−133.0, 1889.0) | −2.0 (−23.0, 39.0)

Table 14.3.7.1.11 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and Treatment Group AST (U/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 54 | 47 | 58 | 43 | 12 | 12 | 124 | 102
Mean (SD) | 66.1 (139.3) | 48.8 (22.2) | 51.2 (60.5) | 39.2 (18.1) | 58.1 (61.9) | 36.7 (28.0) | 58.4 (102.2) | 43.3 (21.7)
95% CI of the Mean | 28.1, 104.1 | 42.3, 55.3 | 35.3, 67.1 | 33.6, 44.7 | 18.8, 97.4 | 18.9, 54.5 | 40.2, 76.5 | 39.1, 47.6
Median (Min-Max) | 47.0 (18.0, 1063.0) | 42.0 (7.0, 137.0) | 35.5 (14.0, 410.0) | 36.0 (15.0, 94.0) | 31.0 (20.0, 207.0) | 24.5 (14.0, 100.0) | 39.0 (14.0, 1063.0) | 39.0 (7.0, 137.0)
24 Hour Visit
N | 47 | 43 | 44 | 44 | 11 | 9 | 102 | 96
Mean (SD) | 150.9 (688.9) | 45.5 (16.8) | 56.7 (100.4) | 37.7 (15.3) | 45.5 (49.2) | 24.9 (16.6) | 98.9 (472.2) | 40.0 (17.1)
95% CI of the Mean | 0.0, 353.2 | 40.4, 50.7 | 26.1, 87.2 | 33.0, 42.3 | 12.4, 78.5 | 12.1, 37.7 | 6.1, 191.7 | 36.5, 43.5
Median (Min-Max) | 47.0 (20.0, 4768.0) | 41.0 (16.0, 95.0) | 35.0 (15.0, 687.0) | 37.0 (15.0, 88.0) | 28.0 (17.0, 191.0) | 16.0 (9.0, 56.0) | 39.0 (15.0, 4768.0) | 38.0 (9.0, 95.0)
Change from Baseline to 24 hour Visit
N | 30 | 28 | 37 | 30 | 9 | 8 | 76 | 66
Mean (SD) | 121.1 (677.2) | −0.6 (18.3) | 9.5 (112.3) | −1.5 (11.5) | −21.3 (47.4) | −15.4 (17.7) | 49.9 (432.5) | −2.8 (16.0)
95% CI of the Mean | 0.0, 374.0 | 0.0, 6.5 | 0.0, 46.9 | 0.0, 2.8 | 0.0, 15.1 | 0.0, −0.5 | 0.0, 148.7 | 0.0, 1.1
Median (Min-Max) | −3.0 (−48.0, 3705.0) | −1.5 (−36.0, 33.0) | −4.0 (−188.0, 635.0) | −3.0 (−33.0, 23.0) | −3.0 (−143.0, 6.0) | −9.0 (−55.0, −3.0) | −3.0 (−188.0, 3705.0) | −4.0 (−55.0, 33.0)

Table 14.3.7.2.1 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group Glucose (mg/dL) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 16 (20.8%) | 24 (33.8%) | 16 (23.5%) | 19 (30.2%) | 4 (23.5%) | 6 (42.9%) | 36 (22.2%) | 49 (33.1%)
Abnormal, Not Clinically Significant | 2 (2.6%) | 0 | 1 (1.5%) | 2 (3.2%) | 0 | 1 (7.1%) | 3 (1.9%) | 3 (2.0%)
Abnormal, Clinically Significant | 21 (27.3%) | 17 (23.9%) | 21 (30.9%) | 9 (14.3%) | 3 (17.6%) | 0 | 45 (27.8%) | 26 (17.6%)
24 Hour Visit
Normal | 11 (14.3%) | 13 (18.3%) | 16 (23.5%) | 15 (23.8%) | 3 (17.6%) | 2 (14.3%) | 30 (18.5%) | 30 (20.3%)
Abnormal, Not Clinically Significant | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, Clinically Significant | 8 (10.4%) | 3 (4.2%) | 3 (4.4%) | 4 (6.3%) | 1 (5.9%) | 1 (7.1%) | 12 (7.4%) | 8 (5.4%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 3 (3.9%) | 4 (5.6%) | 6 (8.8%) | 7 (11.1%) | 1 (5.9%) | 1 (7.1%) | 10 (6.2%) | 12 (8.1%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Normal - Abnormal, CS | 3 (3.9%) | 0 | 0 | 0 | 0 | 0 | 3 (1.9%) | 0
Abnormal, NCS - Normal | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 1 (7.1%) | 1 (0.6%) | 2 (1.4%)
Abnormal, NCS - Abnormal, NCS (no change) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 3 (3.9%) | 6 (8.5%) | 7 (10.3%) | 3 (4.8%) | 2 (11.8%) | 0 | 12 (7.4%) | 9 (6.1%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 3 (3.9%) | 2 (2.8%) | 2 (2.9%) | 3 (4.8%) | 0 | 0 | 5 (3.1%) | 5 (3.4%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.2.2 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group GGT (U/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 38 (49.4%) | 28 (39.4%) | 31 (45.6%) | 19 (30.2%) | 9 (52.9%) | 9 (64.3%) | 78 (48.1%) | 56 (37.8%)
Abnormal, Not Clinically Significant | 2 (2.6%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 0
Abnormal, Clinically Significant | 8 (10.4%) | 10 (14.1%) | 14 (20.6%) | 18 (28.6%) | 1 (5.9%) | 0 | 23 (14.2%) | 28 (18.9%)
24 Hour Visit
Normal | 34 (44.2%) | 29 (40.8%) | 31 (45.6%) | 22 (34.9%) | 9 (52.9%) | 6 (42.9%) | 74 (45.7%) | 57 (38.5%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, Clinically Significant | 7 (9.1%) | 9 (12.7%) | 12 (17.6%) | 16 (25.4%) | 1 (5.9%) | 1 (7.1%) | 20 (12.3%) | 26 (17.6%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 23 (29.9%) | 16 (22.5%) | 17 (25.0%) | 13 (20.6%) | 7 (41.2%) | 6 (42.9%) | 47 (29.0%) | 35 (23.6%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Normal - Abnormal, CS | 0 | 1 (1.4%) | 3 (4.4%) | 0 | 0 | 0 | 3 (1.9%) | 1 (0.7%)
Abnormal, NCS - Normal | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%)
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 2 (2.6%) | 1 (1.4%) | 3 (4.4%) | 2 (3.2%) | 0 | 0 | 5 (3.1%) | 3 (2.0%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 4 (5.2%) | 4 (5.6%) | 6 (8.8%) | 11 (17.5%) | 0 | 0 | 10 (6.2%) | 15 (10.1%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.2.3 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group Sodium (mEq/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 51 (66.2%) | 52 (73.2%) | 49 (72.1%) | 46 (73.0%) | 12 (70.6%) | 14 (100.0%) | 112 (69.1%) | 112 (75.7%)
Abnormal, Not Clinically Significant | 3 (3.9%) | 1 (1.4%) | 0 | 2 (3.2%) | 1 (5.9%) | 0 | 4 (2.5%) | 3 (2.0%)
Abnormal, Clinically Significant | 11 (14.3%) | 10 (14.1%) | 10 (14.7%) | 5 (7.9%) | 1 (5.9%) | 0 | 22 (13.6%) | 15 (10.1%)
24 Hour Visit
Normal | 45 (58.4%) | 38 (53.5%) | 38 (55.9%) | 35 (55.6%) | 11 (64.7%) | 8 (57.1%) | 94 (58.0%) | 81 (54.7%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 1 (0.7%)
Abnormal, Clinically Significant | 4 (5.2%) | 7 (9.9%) | 5 (7.4%) | 10 (15.9%) | 0 | 1 (7.1%) | 9 (5.6%) | 18 (12.2%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 33 (42.9%) | 27 (38.0%) | 31 (45.6%) | 30 (47.6%) | 9 (52.9%) | 8 (57.1%) | 73 (45.1%) | 65 (43.9%)
Normal - Abnormal, NCS | 0 | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Normal - Abnormal, CS | 1 (1.3%) | 5 (7.0%) | 1 (1.5%) | 2 (3.2%) | 0 | 1 (7.1%) | 2 (1.2%) | 8 (5.4%)
Abnormal, NCS - Normal | 1 (1.3%) | 1 (1.4%) | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Abnormal, CS - Normal | 7 (9.1%) | 6 (8.5%) | 5 (7.4%) | 0 | 1 (5.9%) | 0 | 13 (8.0%) | 6 (4.1%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 0 | 0 | 1 (1.5%) | 3 (4.8%) | 0 | 0 | 1 (0.6%) | 3 (2.0%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.2.4 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group Potassium (mEq/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 54 (70.1%) | 51 (71.8%) | 49 (72.1%) | 45 (71.4%) | 11 (64.7%) | 13 (92.9%) | 114 (70.4%) | 109 (73.6%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 0 | 0 | 0 | 1 (5.9%) | 0 | 2 (1.2%) | 0
Abnormal, Clinically Significant | 10 (13.0%) | 10 (14.1%) | 9 (13.2%) | 8 (12.7%) | 2 (11.8%) | 1 (7.1%) | 21 (13.0%) | 19 (12.8%)
24 Hour Visit
Normal | 46 (59.7%) | 37 (52.1%) | 36 (52.9%) | 37 (58.7%) | 11 (64.7%) | 6 (42.9%) | 93 (57.4%) | 80 (54.1%)
Abnormal, Not Clinically Significant | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Abnormal, Clinically Significant | 3 (3.9%) | 9 (12.7%) | 8 (11.8%) | 7 (11.1%) | 0 | 3 (21.4%) | 11 (6.8%) | 19 (12.8%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 33 (42.9%) | 26 (36.6%) | 30 (44.1%) | 27 (42.9%) | 8 (47.1%) | 5 (35.7%) | 71 (43.8%) | 58 (39.2%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | | 1 (0.7%)
Normal - Abnormal, CS | 1 (1.3%) | 5 (7.0%) | 5 (7.4%) | 2 (3.2%) | 0 | 3 (21.4%) | 6 (3.7%) | 10 (6.8%)
Abnormal, NCS - Normal | 1 (1.3%) | 0 | 0 | 0 | 1 (5.9%) | 0 | 2 (1.2%)
Abnormal, NCS - Abnormal, NCS (no change) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 5 (6.5%) | 6 (8.5%) | 2 (2.9%) | 5 (7.9%) | 1 (5.9%) | 1 (7.1%) | 8 (4.9%) | 12 (8.1%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | | 0
Abnormal, CS - Abnormal, CS (no change) | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 2 (3.2%) | 0 | 0 | 3 (1.9%) | 4 (2.7%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.2.5 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group Chloride (mEq/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 55 (71.4%) | 60 (84.5%) | 55 (80.9%) | 48 (76.2%) | 12 (70.6%) | 12 (85.7%) | 122 (75.3%) | 120 (81.1%)
Abnormal, Not Clinically Significant | 2 (2.6%) | 0 | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 3 (1.9%) | 1 (0.7%)
Abnormal, Clinically Significant | 7 (9.1%) | 3 (4.2%) | 4 (5.9%) | 4 (6.3%) | 1 (5.9%) | 1 (7.1%) | 12 (7.4%) | 8 (5.4%)
24 Hour Visit
Normal | 40 (51.9%) | 38 (53.5%) | 39 (57.4%) | 36 (57.1%) | 9 (52.9%) | 8 (57.1%) | 88 (54.3%) | 82 (55.4%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Abnormal, Clinically Significant | 9 (11.7%) | 7 (9.9%) | 5 (7.4%) | 9 (14.3%) | 2 (11.8%) | 1 (7.1%) | 16 (9.9%) | 17 (11.5%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 29 (37.7%) | 32 (45.1%) | 34 (50.0%) | 28 (44.4%) | 7 (41.2%) | 7 (50.0%) | 70 (43.2%) | 67 (45.3%)
Normal - Abnormal, NCS | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Normal - Abnormal, CS | 5 (6.5%) | 4 (5.6%) | 2 (2.9%) | 4 (6.3%) | 2 (11.8%) | 1 (7.1%) | 9 (5.6%) | 9 (6.1%)
Abnormal, NCS - Normal | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Normal | 3 (3.9%) | 2 (2.8%) | 1 (1.5%) | 1 (1.6%) | 1 (5.9%) | 1 (7.1%) | 5 (3.1%) | 4 (2.7%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 3 (3.9%) | 1 (1.4%) | 2 (2.9%) | 3 (4.8%) | 0 | 0 | 5 (3.1%) | 4 (2.7%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.2.6 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group Carbon Dioxide (mEq/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 42 (54.5%) | 49 (69.0%) | 45 (66.2%) | 44 (69.8%) | 9 (52.9%) | 9 (64.3%) | 96 (59.3%) | 102 (68.9%)
Abnormal, Not Clinically Significant | 3 (3.9%) | 1 (1.4%) | 0 | 0 | 0 | 2 (14.3%) | 3 (1.9%) | 3 (2.0%)
Abnormal, Clinically Significant | 20 (26.0%) | 13 (18.3%) | 13 (19.1%) | 9 (14.3%) | 5 (29.4%) | 2 (14.3%) | 38 (23.5%) | 24 (16.2%)
24 Hour Visit
Normal | 35 (45.5%) | 41 (57.7%) | 30 (44.1%) | 35 (55.6%) | 7 (41.2%) | 7 (50.0%) | 72 (44.4%) | 83 (56.1%)
Abnormal, Not Clinically Significant | 2 (2.6%) | 1 (1.4%) | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 1 (0.7%)
Abnormal, Clinically Significant | 13 (16.9%) | 4 (5.6%) | 13 (19.1%) | 10 (15.9%) | 4 (23.5%) | 2 (14.3%) | 30 (18.5%) | 16 (10.8%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 19 (24.7%) | 28 (39.4%) | 25 (36.8%) | 26 (41.3%) | 5 (29.4%) | 7 (50.0%) | 49 (30.2%) | 61 (41.2%)
Normal - Abnormal, NCS | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Normal - Abnormal, CS | 5 (6.5%) | 1 (1.4%) | 7 (10.3%) | 4 (6.3%) | 1 (5.9%) | 0 | 13 (8.0%) | 5 (3.4%)
Abnormal, NCS - Normal | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, NCS - Abnormal, CS | 1 (1.3%) | 0 | 0 | 0 | 0 | 2 (14.3%) | 1 (0.6%) | 2 (1.4%)
Abnormal, CS - Normal | 12 (15.6%) | 7 (9.9%) | 2 (2.9%) | 2 (3.2%) | 2 (11.8%) | 0 | 16 (9.9%) | 9 (6.1%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 4 (5.2%) | 2 (2.8%) | 4 (5.9%) | 5 (7.9%) | 2 (11.8%) | 0 | 10 (6.2%) | 7 (4.7%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.2.7 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group BUN (mg/dL) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 54 (70.1%) | 53 (74.6%) | 58 (85.3%) | 50 (79.4%) | 10 (58.8%) | 13 (92.9%) | 122 (75.3%) | 116 (78.4%)
Abnormal, Not Clinically Significant | 2 (2.6%) | 1 (1.4%) | 1 (1.5%) | 0 | 1 (5.9%) | 0 | 4 (2.5%) | 1 (0.7%)
Abnormal, Clinically Significant | 7 (9.1%) | 10 (14.1%) | 2 (2.9%) | 2 (3.2%) | 2 (11.8%) | 0 | 11 (6.8%) | 12 (8.1%)
24 Hour Visit
Normal | 34 (44.2%) | 32 (45.1%) | 35 (51.5%) | 36 (57.1%) | 6 (35.3%) | 6 (42.9%) | 75 (46.3%) | 74 (50.0%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, Clinically Significant | 14 (18.2%) | 14 (19.7%) | 10 (14.7%) | 9 (14.3%) | 5 (29.4%) | 3 (21.4%) | 29 (17.9%) | 26 (17.6%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 23 (29.9%) | 24 (33.8%) | 30 (44.1%) | 27 (42.9%) | 3 (17.6%) | 6 (42.9%) | 56 (34.6%) | 57 (38.5%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Normal - Abnormal, CS | 10 (13.0%) | 10 (14.1%) | 8 (11.8%) | 7 (11.1%) | 3 (17.6%) | 3 (21.4%) | 21 (13.0%) | 20 (13.5%)
Abnormal, NCS - Normal | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%)
Abnormal, NCS - Abnormal, CS | 1 (1.3%) | 0 | 0 | 0 | 1 (5.9%) | 0 | 2 (1.2%) | 0
Abnormal, CS - Normal | 4 (5.2%) | 5 (7.0%) | 2 (2.9%) | 0 | 1 (5.9%) | 0 | 7 (4.3%) | 5 (3.4%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 1 (1.3%) | 2 (2.8%) | 0 | 2 (3.2%) | 1 (5.9%) | 0 | 2 (1.2%) | 4 (2.7%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.2.8 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group Creatinine (mg/dL) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 58 (75.3%) | 61 (85.9%) | 54 (79.4%) | 47 (74.6%) | 11 (64.7%) | 13 (92.9%) | 123 (75.9%) | 121 (81.8%)
Abnormal, Not Clinically Significant | 2 (2.6%) | 0 | 0 | 1 (1.6%) | 1 (5.9%) | 0 | 3 (1.9%) | 1 (0.7%)
Abnormal, Clinically Significant | 3 (3.9%) | 2 (2.8%) | 5 (7.4%) | 4 (6.3%) | 2 (11.8%) | 0 | 10 (6.2%) | 6 (4.1%)
24 Hour Visit
Normal | 46 (59.7%) | 41 (57.7%) | 43 (63.2%) | 40 (63.5%) | 8 (47.1%) | 9 (64.3%) | 97 (59.9%) | 90 (60.8%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, Clinically Significant | 2 (2.6%) | 4 (5.6%) | 2 (2.9%) | 3 (4.8%) | 3 (17.6%) | 0 | 7 (4.3%) | 7 (4.7%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 35 (45.5%) | 36 (50.7%) | 38 (55.9%) | 29 (46.0%) | 7 (41.2%) | 9 (64.3%) | 80 (49.4%) | 74 (50.0%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Normal - Abnormal, CS | 1 (1.3%) | 2 (2.8%) | 0 | 0 | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)
Abnormal, NCS - Normal | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%)
Abnormal, NCS - Abnormal, CS | 1 (1.3%) | 0 | 0 | 0 | 1 (5.9%) | 0 | 2 (1.2%) | 0
Abnormal, CS - Normal | 2 (2.6%) | 1 (1.4%) | 0 | 2 (3.2%) | 0 | 0 | 2 (1.2%) | 3 (2.0%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 0 | 0 | 1 (1.5%) | 2 (3.2%) | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.2.9 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group Calcium (mg/dL) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 55 (71.4%) | 45 (63.4%) | 48 (70.6%) | 46 (73.0%) | 13 (76.5%) | 12 (85.7%) | 116 (71.6%) | 103 (69.6%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, Clinically Significant | 8 (10.4%) | 15 (21.1%) | 7 (10.3%) | 6 (9.5%) | 1 (5.9%) | 1 (7.1%) | 16 (9.9%) | 22 (14.9%)
24 Hour Visit
Normal | 44 (57.1%) | 36 (50.7%) | 35 (51.5%) | 36 (57.1%) | 8 (47.1%) | 6 (42.9%) | 87 (53.7%) | 78 (52.7%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, Clinically Significant | 3 (3.9%) | 9 (12.7%) | 8 (11.8%) | 7 (11.1%) | 3 (17.6%) | 3 (21.4%) | 14 (8.6%) | 19 (12.8%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 30 (39.0%) | 24 (33.8%) | 25 (36.8%) | 27 (42.9%) | 6 (35.3%) | 6 (42.9%) | 61 (37.7%) | 57 (38.5%)
Normal - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%)
Normal - Abnormal, CS | 2 (2.6%) | 4 (5.6%) | 5 (7.4%) | 5 (7.9%) | 3 (17.6%) | 2 (14.3%) | 10 (6.2%) | 11 (7.4%)
Abnormal, NCS - Normal | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, NCS (no change) | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, CS | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%)
Abnormal, CS - Normal | 6 (7.8%) | 7 (9.9%) | 3 (4.4%) | 2 (3.2%) | 1 (5.9%) | 0 | 10 (6.2%) | 9 (6.1%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 0 | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 0 | 1 (7.1%) | 2 (1.2%) | 5 (3.4%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.2.10 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group ALT (U/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 46 (59.7%) | 39 (54.9%) | 51 (75.0%) | 39 (61.9%) | 10 (58.8%) | 10 (71.4%) | 107 (66.0%) | 88 (59.5%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 1 (7.1%) | 2 (1.2%) | 1 (0.7%)
Abnormal, Clinically Significant | 7 (9.1%) | 8 (11.3%) | 6 (8.8%) | 4 (6.3%) | 2 (11.8%) | 1 (7.1%) | 15 (9.3%) | 13 (8.8%)
24 Hour Visit
Normal | 41 (53.2%) | 40 (56.3%) | 34 (50.0%) | 34 (54.0%) | 8 (47.1%) | 7 (50.0%) | 83 (51.2%) | 81 (54.7%)
Abnormal, Not Clinically Significant | 2 (2.6%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 0
Abnormal, Clinically Significant | 3 (3.9%) | 3 (4.2%) | 9 (13.2%) | 10 (15.9%) | 3 (17.6%) | 2 (14.3%) | 15 (9.3%) | 15 (10.1%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 25 (32.5%) | 24 (33.8%) | 27 (39.7%) | 22 (34.9%) | 6 (35.3%) | 6 (42.9%) | 58 (35.8%) | 52 (35.1%)
Normal - Abnormal, NCS | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%)
Normal - Abnormal, CS | 1 (1.3%) | 0 | 3 (4.4%) | 6 (9.5%) | 1 (5.9%) | 0 | 5 (3.1%) | 6 (4.1%)
Abnormal, NCS - Normal | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%)
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Abnormal, CS - Normal | 1 (1.3%) | 2 (2.8%) | 2 (2.9%) | 2 (3.2%) | 0 | 0 | 3 (1.9%) | 4 (2.7%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 1 (1.3%) | 2 (2.8%) | 4 (5.9%) | 1 (1.6%) | 2 (11.8%) | 1 (7.1%) | 7 (4.3%) | 4 (2.7%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.7.2.11 Summary of Clinical Laboratory Serum Chemistry Assessment by Visit and Treatment Group AST (U/L) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 44 (57.1%) | 41 (57.7%) | 49 (72.1%) | 35 (55.6%) | 10 (58.8%) | 10 (71.4%) | 103 (63.6%) | 86 (58.1%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 0 | 2 (2.9%) | 0 | 0 | 1 (7.1%) | 3 (1.9%) | 1 (0.7%)
Abnormal, Clinically Significant | 9 (11.7%) | 6 (8.5%) | 7 (10.3%) | 8 (12.7%) | 2 (11.8%) | 1 (7.1%) | 18 (11.1%) | 15 (10.1%)
24 Hour Visit
Normal | 38 (49.4%) | 32 (45.1%) | 33 (48.5%) | 34 (54.0%) | 9 (52.9%) | 6 (42.9%) | 80 (49.4%) | 72 (48.6%)
Abnormal, Not Clinically Significant | 2 (2.6%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 0
Abnormal, Clinically Significant | 7 (9.1%) | 11 (15.5%) | 10 (14.7%) | 10 (15.9%) | 2 (11.8%) | 3 (21.4%) | 19 (11.7%) | 24 (16.2%)
Change from Baseline to 24 hour Visit
Normal - Normal (no change) | 24 (31.2%) | 20 (28.2%) | 27 (39.7%) | 20 (31.7%) | 6 (35.3%) | 6 (42.9%) | 57 (35.2%) | 46 (31.1%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Normal - Abnormal, CS | 2 (2.6%) | 6 (8.5%) | 2 (2.9%) | 4 (6.3%) | 1 (5.9%) | 0 | 5 (3.1%) | 10 (6.8%)
Abnormal, NCS - Normal | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%)
Abnormal, NCS - Abnormal, CS | 0 | 0 | 0 | 0 | 0 | 1 (7.1%) | 0 | 1 (0.7%)
Abnormal, CS - Normal | 1 (1.3%) | 1 (1.4%) | 3 (4.4%) | 2 (3.2%) | 1 (5.9%) | 0 | 5 (3.1%) | 3 (2.0%)
Abnormal, CS - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0
Abnormal, CS - Abnormal, CS (no change) | 2 (2.6%) | 1 (1.4%) | 4 (5.9%) | 4 (6.3%) | 1 (5.9%) | 1 (7.1%) | 7 (4.3%) | 6 (4.1%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.8.1.1 Summary of Clinical Laboratory ABG-VBG Gases Measurement by Age Stratum and Treatment Group pH Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 39 | 48 | 39 | 36 | 12 | 8 | 90 | 92
Mean (SD) | 7.2 (0.1) | 7.2 (0.2) | 7.2 (0.1) | 7.2 (0.1) | 7.2 (0.1) | 7.3 (0.1) | 7.2 (0.1) | 7.2 (0.1)
95% CI of the Mean | 7.2, 7.3 | 7.1, 7.2 | 7.2, 7.3 | 7.2, 7.3 | 7.1, 7.3 | 7.2, 7.4 | 7.2, 7.3 | 7.2, 7.2
Median (Min-Max) | 7.3 (7.0, 7.5) | 7.2 (6.9, 7.4) | 7.2 (7.0, 7.5) | 7.2 (6.9, 7.5) | 7.2 (7.0, 7.5) | 7.3 (7.1, 7.4) | 7.2 (7.0, 7.5) | 7.2 (6.9, 7.5)
1 Hour Visit
N | 47 | 50 | 45 | 44 | 11 | 10 | 103 | 104
Mean (SD) | 7.3 (0.1) | 7.3 (0.1) | 7.3 (0.1) | 7.3 (0.1) | 7.3 (0.1) | 7.4 (0.1) | 7.3 (0.1) | 7.3 (0.1)
95% CI of the Mean | 7.3, 7.3 | 7.3, 7.3 | 7.3, 7.3 | 7.3, 7.3 | 7.2, 7.4 | 7.3, 7.4 | 7.3, 7.3 | 7.3, 7.3
Median (Min-Max) | 7.3 (7.1, 7.5) | 7.3 (7.0, 7.5) | 7.3 (6.9, 7.5) | 7.3 (7.1, 7.4) | 7.3 (6.9, 7.4) | 7.4 (7.3, 7.4) | 7.3 (6.9, 7.5) | 7.3 (7.0, 7.5)
Change from Baseline to 1 hour Visit
N | 26 | 34 | 26 | 23 | 10 | 6 | 62 | 63
Mean (SD) | 0.1 (0.1) | 0.1 (0.2) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.1)
95% CI of the Mean | 0.0, 0.1 | 0.1, 0.2 | 0.1, 0.1 | 0.0, 0.2 | 0.0, 0.2 | 0.0, 0.2 | 0.1, 0.1 | 0.1, 0.2
Median (Min-Max) | 0.1 (−0.2, 0.3) | 0.1 (−0.1, 0.5) | 0.1 (−0.1, 0.3) | 0.1 (−0.2, 0.4) | 0.0 (−0.1, 0.3) | 0.1 (−0.1, 0.2) | 0.1 (−0.2, 0.3) | 0.1 (−0.2, 0.5)

Table 14.3.8.1.2 Summary of Clinical Laboratory ABG-VBG Gases Measurement by Age Stratum and Treatment Group PCO_2_ Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 39 | 48 | 39 | 35 | 11 | 8 | 89 | 91
Mean (SD) | 55.6 (22.0) | 66.2 (27.3) | 63.4 (23.8) | 61.7 (24.0) | 54.4 (12.8) | 43.7 (21.1) | 58.8 (22.1) | 62.5 (26.1)
95% CI of the Mean | 48.5, 62.7 | 58.2, 74.1 | 55.7, 71.1 | 53.5, 70.0 | 45.8, 63.0 | 26.0, 61.3 | 54.2, 63.5 | 57.1, 67.9
Median (Min-Max) | 49.0 (26.0, 115.0) | 56.0 (22.0, 130.0) | 62.0 (33.9, 124.0) | 51.0 (28.0, 122.0) | 54.0 (35.0, 74.6) | 42.5 (19.8, 90.0) | 54.0 (26.0, 124.0) | 53.0 (19.8, 130.0)
1 Hour Visit
N | 47 | 50 | 45 | 44 | 11 | 10 | 103 | 104
Mean (SD) | 44.0 (12.0) | 46.3 (13.7) | 52.8 (19.2) | 50.3 (12.5) | 57.1 (31.0) | 45.4 (9.8) | 49.2 (18.5) | 47.9 (12.9)
95% CI of the Mean | 40.4, 47.5 | 42.4, 50.2 | 47.0, 58.6 | 46.5, 54.1 | 36.2, 77.9 | 38.3, 52.4 | 45.6, 52.9 | 45.4, 50.4
Median (Min-Max) | 43.0 (13.0, 82.8) | 43.8 (24.0, 110.3) | 47.0 (32.0, 138.0) | 47.5 (33.0, 80.0) | 45.0 (37.0, 147.0) | 41.0 (35.7, 66.0) | 45.0 (13.0, 147.0) | 44.7 (24.0, 110.3)
Change from Baseline to 1 hour Visit
N | 26 | 34 | 26 | 22 | 9 | 6 | 61 | 62
Mean (SD) | −10.8 (20.5) | −24.8 (26.2) | −19.8 (22.5) | −15.9 (20.2) | −5.7 (14.6) | −1.5 (15.6) | −13.9 (21.1) | −19.4 (24.2)
95% CI of the Mean | 0.0, −2.6 | 0.0, −15.7 | 0.0, −10.7 | 0.0, −6.9 | 0.0, 5.6 | 0.0, 14.9 | 0.0, −8.5 | 0.0, −13.2
Median (Min-Max) | −6.6 (−62.0, 19.0) | −17.5 (−96.0, 14.3) | −12.5 (−79.0, 8.0) | −13.2 (−60.7, 16.0) | −12.0 (−28.7, 16.9) | −1.7 (−24.0, 24.2) | −8.5 (−79.0, 19.0) | −13.2 (−96.0, 24.2)

Table 14.3.8.1.3 Summary of Clinical Laboratory ABG-VBG Gases Measurement by Age Stratum and Treatment Group PO_2_ Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 35 | 45 | 36 | 34 | 12 | 8 | 83 | 87
Mean (SD) | 90.0 (58.4) | 90.3 (66.6) | 106.3 (78.5) | 97.2 (73.0) | 102.5 (87.1) | 101.1 (52.1) | 98.9 (71.5) | 94.0 (67.5)
95% CI of the Mean | 69.9, 110.1 | 70.2, 110.3 | 79.7, 132.8 | 71.7, 122.7 | 47.1, 157.9 | 57.6, 144.7 | 83.2, 114.5 | 79.6, 108.4
Median (Min-Max) | 71.0 (32.0, 254.0) | 73.0 (25.0, 359.0) | 78.5 (24.0, 387.0) | 71.0 (29.0, 306.0) | 70.5 (33.0, 316.0) | 88.5 (46.0, 201.0) | 74.0 (24.0, 387.0) | 73.0 (25.0, 359.0)
1 Hour Visit
N | 44 | 48 | 44 | 44 | 11 | 10 | 99 | 102
Mean (SD) | 54.1 (24.4) | 85.0 (69.4) | 59.0 (23.2) | 63.4 (36.8) | 53.9 (15.3) | 62.4 (24.7) | 56.3 (23.0) | 73.4 (54.7)
95% CI of the Mean | 46.7, 61.5 | 64.8, 105.1 | 51.9, 66.1 | 52.2, 74.6 | 43.6, 64.2 | 44.7, 80.1 | 51.7, 60.8 | 62.7, 84.2
Median (Min-Max) | 46.0 (21.0, 128.0) | 59.0 (27.0, 329.0) | 56.0 (21.0, 129.0) | 51.5 (22.0, 186.0) | 53.0 (36.0, 88.0) | 51.5 (33.0, 105.0) | 52.0 (21.0, 129.0) | 55.5 (22.0, 329.0)
Change from Baseline to 1 hour Visit
N | 23 | 32 | 25 | 23 | 10 | 6 | 58 | 61
Mean (SD) | −35.7 (70.5) | 11.4 (75.4) | −66.4 (86.9) | −28.7 (75.4) | −18.5 (60.3) | −58.2 (55.1) | −46.0 (77.6) | −10.6 (76.7)
95% CI of the Mean | 0.0, −5.2 | 0.0, 38.6 | 0.0, −30.6 | 0.0, 3.9 | 0.0, 24.6 | 0.0, −0.3 | 0.0, −25.6 | 0.0, 9.1
Median (Min-Max) | −12.0 (−224.0, 86.0) | 1.0 (−84.0, 300.0) | −41.0 (−324.0, 40.0) | −15.0 (−232.0, 96.0) | −8.5 (−175.0, 55.0) | −62.5 (−152.0, 3.0) | −15.5 (−324.0, 86.0) | −11.0 (−232.0, 300.0)

Table 14.3.8.1.4 Summary of Clinical Laboratory ABG-VBG Gases Measurement by Age Stratum and Treatment Group SO_2_ Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 32 | 37 | 30 | 29 | 8 | 5 | 70 | 71
Mean (SD) | 83.3 (18.5) | 82.1 (19.2) | 86.9 (16.8) | 85.3 (19.4) | 89.1 (12.2) | 94.0 (5.7) | 85.5 (17.1) | 84.3 (18.8)
95% CI of the Mean | 76.7, 90.0 | 75.7, 88.5 | 80.6, 93.2 | 78.0, 92.7 | 79.0, 99.3 | 86.9, 101.1 | 81.5, 89.6 | 79.8, 88.7
Median (Min-Max) | 92.0 (31.0, 100.0) | 90.0 (22.0, 100.0) | 92.5 (31.0, 100.0) | 94.0 (30.0, 100.0) | 93.5 (68.0, 100.0) | 93.0 (86.0, 100.0) | 92.0 (31.0, 100.0) | 92.0 (22.0, 100.0)
1 Hour Visit
N | 38 | 41 | 36 | 37 | 10 | 8 | 84 | 86
Mean (SD) | 74.1 (20.6) | 79.0 (21.4) | 82.4 (13.7) | 77.9 (17.9) | 78.7 (12.8) | 83.5 (16.0) | 78.2 (17.4) | 79.0 (19.3)
95% CI of the Mean | 67.4, 80.9 | 72.3, 85.8 | 77.8, 87.0 | 72.0, 83.9 | 69.6, 87.8 | 70.1, 96.9 | 74.4, 82.0 | 74.8, 83.1
Median (Min-Max) | 81.0 (31.0, 97.0) | 88.0 (33.0, 100.0) | 85.5 (51.0, 98.0) | 81.0 (34.0, 99.0) | 81.0 (63.0, 97.0) | 89.0 (55.0, 98.0) | 84.0 (31.0, 98.0) | 85.0 (33.0, 100.0)
Change from Baseline to 1 hour Visit
N | 21 | 27 | 21 | 19 | 7 | 4 | 49 | 50
Mean (SD) | −4.0 (20.6) | 3.0 (19.4) | −7.1 (18.7) | −1.0 (24.3) | −4.7 (15.1) | −16.0 (15.6) | −5.4 (18.8) | 0.0 (21.4)
95% CI of the Mean | 0.0, 5.4 | 0.0, 10.7 | 0.0, 1.4 | 0.0, 10.7 | 0.0, 9.3 | 0.0, 8.8 | 0.0, −0.1 | 0.0, 6.1
Median (Min-Max) | −5.0 (−52.0, 35.0) | 1.0 (−34.0, 66.0) | −6.0 (−40.0, 53.0) | −2.0 (−57.0, 53.0) | −6.0 (−32.0, 18.0) | −11.0 (−38.0, −4.0) | −6.0 (−52.0, 53.0) | −1.0 (−57.0, 66.0)

Table 14.3.8.1.5 Summary of Clinical Laboratory ABG-VBG Gases Measurement by Age Stratum and Treatment Group HCO_3_ Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 38 | 47 | 38 | 37 | 11 | 8 | 87 | 92
Mean (SD) | 22.0 (3.7) | 23.3 (3.5) | 24.6 (3.4) | 24.0 (3.5) | 23.8 (4.0) | 20.4 (6.9) | 23.4 (3.8) | 23.3 (3.9)
95% CI of the Mean | 20.8, 23.3 | 22.2, 24.3 | 23.5, 25.8 | 22.8, 25.1 | 21.2, 26.5 | 14.6, 26.2 | 22.6, 24.2 | 22.5, 24.1
Median (Min-Max) | 22.2 (13.1, 30.0) | 24.0 (13.0, 30.0) | 24.1 (16.0, 31.0) | 25.0 (19.0, 29.7) | 24.0 (17.0, 29.9) | 20.0 (11.2, 29.0) | 23.4 (13.1, 31.0) | 24.0 (11.2, 30.0)
1 Hour Visit
N | 47 | 50 | 44 | 44 | 10 | 10 | 101 | 104
Mean (SD) | 21.5 (3.9) | 22.0 (3.1) | 24.2 (3.6) | 24.2 (3.4) | 24.2 (2.4) | 25.0 (3.3) | 22.9 (3.8) | 23.2 (3.5)
95% CI of the Mean | 20.3, 22.6 | 21.1, 22.8 | 23.1, 25.3 | 23.2, 25.3 | 22.5, 25.9 | 22.7, 27.4 | 22.2, 23.7 | 22.5, 23.9
Median (Min-Max) | 22.0 (9.0, 28.5) | 22.0 (14.0, 28.8) | 24.0 (12.9, 30.0) | 24.0 (14.0, 32.1) | 23.9 (21.0, 27.2) | 24.4 (21.0, 32.0) | 23.0 (9.0, 30.0) | 23.2 (14.0, 32.1)
Change from Baseline to 1 hour Visit
N | 25 | 33 | 25 | 24 | 9 | 6 | 59 | 63
Mean (SD) | −0.5 (3.2) | −1.4 (2.9) | −1.3 (3.2) | −0.8 (2.7) | 1.3 (4.3) | 3.7 (4.9) | −0.6 (3.4) | −0.7 (3.3)
95% CI of the Mean | 0.0, 0.9 | 0.0, −0.4 | 0.0, 0.0 | 0.0, 0.4 | 0.0, 4.6 | 0.0, 8.8 | 0.0, 0.3 | 0.0, 0.1
Median (Min-Max) | 0.0 (−11.0, 4.6) | −1.5 (−8.0, 9.0) | −1.2 (−10.4, 5.0) | −1.0 (−6.0, 5.0) | 2.3 (−7.0, 6.0) | 4.9 (−3.0, 8.9) | 0.0 (−11.0, 6.0) | −1.0 (−8.0, 9.0)

Table 14.3.8.2.1 Summary of Clinical Laboratory ABG-VBG Gases Assessment by Age Stratum and Treatment Group pH Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 13 (16.9%) | 18 (25.4%) | 10 (14.7%) | 10 (15.9%) | 4 (23.5%) | 4 (28.6%) | 27 (16.7%) | 32 (21.6%)
Abnormal, Not Clinically Significant | 7 (9.1%) | 11 (15.5%) | 12 (17.6%) | 9 (14.3%) | 2 (11.8%) | 2 (14.3%) | 21 (13.0%) | 22 (14.9%)
Abnormal, Clinically Significant | 19 (24.7%) | 19 (26.8%) | 17 (25.0%) | 17 (27.0%) | 6 (35.3%) | 2 (14.3%) | 42 (25.9%) | 38 (25.7%)
1 Hour Visit
Normal | 26 (33.8%) | 22 (31.0%) | 21 (30.9%) | 21 (33.3%) | 8 (47.1%) | 7 (50.0%) | 55 (34.0%) | 50 (33.8%)
Abnormal, Not Clinically Significant | 3 (3.9%) | 3 (4.2%) | 3 (4.4%) | 7 (11.1%) | 1 (5.9%) | 0 | 7 (4.3%) | 10 (6.8%)
Abnormal, Clinically Significant | 18 (23.4%) | 25 (35.2%) | 21 (30.9%) | 16 (25.4%) | 2 (11.8%) | 3 (21.4%) | 41 (25.3%) | 44 (29.7%)
Change from Baseline to 1 hour Visit
Normal - Normal (no change) | 8 (10.4%) | 7 (9.9%) | 6 (8.8%) | 5 (7.9%) | 3 (17.6%) | 3 (21.4%) | 17 (10.5%) | 15 (10.1%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Normal - Abnormal, CS | 2 (2.6%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 1 (0.7%)
Abnormal, NCS - Normal | 2 (2.6%) | 4 (5.6%) | 6 (8.8%) | 3 (4.8%) | 1 (5.9%) | 1 (7.1%) | 9 (5.6%) | 8 (5.4%)
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 1 (1.5%) | 3 (4.8%) | 1 (5.9%) | 0 | 3 (1.9%) | 3 (2.0%)
Abnormal, NCS - Abnormal, CS | 2 (2.6%) | 5 (7.0%) | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 4 (2.5%) | 6 (4.1%)
Abnormal, CS - Normal | 7 (9.1%) | 8 (11.3%) | 3 (4.4%) | 2 (3.2%) | 3 (17.6%) | 0 | 13 (8.0%) | 10 (6.8%)
Abnormal, CS - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Abnormal, CS - Abnormal, CS (no change) | 3 (3.9%) | 10 (14.1%) | 8 (11.8%) | 6 (9.5%) | 2 (11.8%) | 2 (14.3%) | 13 (8.0%) | 18 (12.2%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.8.2.2 Summary of Clinical Laboratory ABG-VBG Gases Assessment by Age Stratum and Treatment Group PCO_2_ Safety Population

| 3 mo - <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 17 (22.1%) | 14 (19.7%) | 13 (19.1%) | 16 (25.4%) | 4 (23.5%) | 6 (42.9%) | 34 (21.0%) | 36 (24.3%)
Abnormal, Not Clinically Significant | 4 (5.2%) | 14 (19.7%) | 11 (16.2%) | 9 (14.3%) | 2 (11.8%) | 1 (7.1%) | 17 (10.5%) | 24 (16.2%)
Abnormal, Clinically Significant | 18 (23.4%) | 20 (28.2%) | 15 (22.1%) | 11 (17.5%) | 5 (29.4%) | 1 (7.1%) | 38 (23.5%) | 32 (21.6%)
1 Hour Visit
Normal | 27 (35.1%) | 32 (45.1%) | 23 (33.8%) | 21 (33.3%) | 7 (41.2%) | 7 (50.0%) | 57 (35.2%) | 60 (40.5%)
Abnormal, Not Clinically Significant | 4 (5.2%) | 5 (7.0%) | 6 (8.8%) | 7 (11.1%) | 1 (5.9%) | 0 | 11 (6.8%) | 12 (8.1%)
Abnormal, Clinically Significant | 16 (20.8%) | 13 (18.3%) | 16 (23.5%) | 16 (25.4%) | 3 (17.6%) | 3 (21.4%) | 35 (21.6%) | 32 (21.6%)
Change from Baseline to 1 hour Visit
Normal - Normal (no change) | 7 (9.1%) | 7 (9.9%) | 6 (8.8%) | 4 (6.3%) | 3 (17.6%) | 4 (28.6%) | 16 (9.9%) | 15 (10.1%)
Normal - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Normal - Abnormal, CS | 4 (5.2%) | 0 | 1 (1.5%) | 2 (3.2%) | 1 (5.9%) | 1 (7.1%) | 6 (3.7%) | 3 (2.0%)
Abnormal, NCS - Normal | 1 (1.3%) | 8 (11.3%) | 5 (7.4%) | 4 (6.3%) | 2 (11.8%) | 0 | 8 (4.9%) | 12 (8.1%)
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 2 (2.8%) | 2 (2.9%) | 3 (4.8%) | 0 | 0 | 3 (1.9%) | 5 (3.4%)
Abnormal, NCS - Abnormal, CS | 2 (2.6%) | 2 (2.8%) | 2 (2.9%) | 0 | 0 | 0 | 4 (2.5%) | 2 (1.4%)
Abnormal, CS - Normal | 4 (5.2%) | 10 (14.1%) | 4 (5.9%) | 5 (7.9%) | 1 (5.9%) | 0 | 9 (5.6%) | 15 (10.1%)
Abnormal, CS - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Abnormal, CS - Abnormal, CS (no change) | 5 (6.5%) | 5 (7.0%) | 6 (8.8%) | 3 (4.8%) | 2 (11.8%) | 1 (7.1%) | 13 (8.0%) | 9 (6.1%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.8.2.3 Summary of Clinical Laboratory ABG-VBG Gases Assessment by Age Stratum and Treatment Group PO_2_ Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 17 (22.1%) | 18 (25.4%) | 14 (20.6%) | 14 (22.2%) | 4 (23.5%) | 4 (28.6%) | 35 (21.6%) | 36 (24.3%)
Abnormal, Not Clinically Significant | 4 (5.2%) | 9 (12.7%) | 4 (5.9%) | 5 (7.9%) | 0 | 1 (7.1%) | 8 (4.9%) | 15 (10.1%)
Abnormal, Clinically Significant | 14 (18.2%) | 18 (25.4%) | 18 (26.5%) | 15 (23.8%) | 8 (47.1%) | 3 (21.4%) | 40 (24.7%) | 36 (24.3%)
1 Hour Visit
Normal | 23 (29.9%) | 19 (26.8%) | 23 (33.8%) | 24 (38.1%) | 9 (52.9%) | 5 (35.7%) | 55 (34.0%) | 48 (32.4%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 2 (2.8%) | 1 (1.5%) | 5 (7.9%) | 1 (5.9%) | 0 | 3 (1.9%) | 7 (4.7%)
Abnormal, Clinically Significant | 20 (26.0%) | 27 (38.0%) | 20 (29.4%) | 15 (23.8%) | 1 (5.9%) | 5 (35.7%) | 41 (25.3%) | 47 (31.8%)
Change from Baseline to 1 hour Visit
Normal - Normal (no change) | 8 (10.4%) | 8 (11.3%) | 7 (10.3%) | 5 (7.9%) | 4 (23.5%) | 2 (14.3%) | 19 (11.7%) | 15 (10.1%)
Normal - Abnormal, NCS | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
Normal - Abnormal, CS | 4 (5.2%) | 5 (7.0%) | 0 | 4 (6.3%) | 0 | 1 (7.1%) | 4 (2.5%) | 10 (6.8%)
Abnormal, NCS - Normal | 2 (2.6%) | 2 (2.8%) | 2 (2.9%) | 2 (3.2%) | 0 | 0 | 4 (2.5%) | 4 (2.7%)
Abnormal, NCS - Abnormal, NCS (no change) | 0 | 0 | 0 | 2 (3.2%) | 0 | 0 | 0 | 2 (1.4%)
Abnormal, NCS - Abnormal, CS | 1 (1.3%) | 5 (7.0%) | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 5 (3.4%)
Abnormal, CS - Normal | 3 (3.9%) | 3 (4.2%) | 3 (4.4%) | 4 (6.3%) | 4 (23.5%) | 2 (14.3%) | 10 (6.2%) | 9 (6.1%)
Abnormal, CS - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 2 (3.2%) | 1 (5.9%) | 0 | 2 (1.2%) | 2 (1.4%)
Abnormal, CS - Abnormal, CS (no change) | 4 (5.2%) | 9 (12.7%) | 11 (16.2%) | 4 (6.3%) | 1 (5.9%) | 1 (7.1%) | 16 (9.9%) | 14 (9.5%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.8.2.4 Summary of Clinical Laboratory ABG-VBG Gases Assessment by Age Stratum and Treatment Group SO_2_ Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 19 (24.7%) | 16 (22.5%) | 17 (25.0%) | 16 (25.4%) | 4 (23.5%) | 4 (28.6%) | 40 (24.7%) | 36 (24.3%)
Abnormal, Not Clinically Significant | 4 (5.2%) | 6 (8.5%) | 2 (2.9%) | 2 (3.2%) | 0 | 0 | 6 (3.7%) | 8 (5.4%)
Abnormal, Clinically Significant | 9 (11.7%) | 15 (21.1%) | 11 (16.2%) | 11 (17.5%) | 4 (23.5%) | 1 (7.1%) | 24 (14.8%) | 27 (18.2%)
1 Hour Visit
Normal | 15 (19.5%) | 21 (29.6%) | 21 (30.9%) | 18 (28.6%) | 6 (35.3%) | 4 (28.6%) | 42 (25.9%) | 43 (29.1%)
Abnormal, Not Clinically Significant | 3 (3.9%) | 2 (2.8%) | 0 | 3 (4.8%) | 1 (5.9%) | 0 | 4 (2.5%) | 5 (3.4%)
Abnormal, Clinically Significant | 20 (26.0%) | 18 (25.4%) | 15 (22.1%) | 16 (25.4%) | 3 (17.6%) | 4 (28.6%) | 38 (23.5%) | 38 (25.7%)
Change from Baseline to 1 hour Visit
Normal - Normal (no change) | 8 (10.4%) | 10 (14.1%) | 10 (14.7%) | 9 (14.3%) | 4 (23.5%) | 2 (14.3%) | 22 (13.6%) | 21 (14.2%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Normal - Abnormal, CS | 3 (3.9%) | 1 (1.4%) | 2 (2.9%) | 2 (3.2%) | 0 | 1 (7.1%) | 5 (3.1%) | 4 (2.7%)
Abnormal, NCS - Normal | 2 (2.6%) | 2 (2.8%) | 1 (1.5%) | 0 | 0 | 0 | 3 (1.9%) | 2 (1.4%)
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, NCS - Abnormal, CS | 1 (1.3%) | 3 (4.2%) | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 4 (2.7%)
Abnormal, CS - Normal | 0 | 3 (4.2%) | 3 (4.4%) | 0 | 1 (5.9%) | 0 | 4 (2.5%) | 3 (2.0%)
Abnormal, CS - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 2 (3.2%) | 0 | 0 | 1 (0.6%) | 2 (1.4%)
Abnormal, CS - Abnormal, CS (no change) | 5 (6.5%) | 8 (11.3%) | 5 (7.4%) | 5 (7.9%) | 2 (11.8%) | 1 (7.1%) | 12 (7.4%) | 14 (9.5%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.8.2.5 Summary of Clinical Laboratory ABG-VBG Gases Assessment by Age Stratum and Treatment Group HCO_3_ Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 31 (40.3%) | 38 (53.5%) | 25 (36.8%) | 27 (42.9%) | 8 (47.1%) | 5 (35.7%) | 64 (39.5%) | 70 (47.3%)
Abnormal, Not Clinically Significant | 1 (1.3%) | 5 (7.0%) | 3 (4.4%) | 1 (1.6%) | 1 (5.9%) | 2 (14.3%) | 5 (3.1%) | 8 (5.4%)
Abnormal, Clinically Significant | 6 (7.8%) | 4 (5.6%) | 10 (14.7%) | 9 (14.3%) | 2 (11.8%) | 1 (7.1%) | 18 (11.1%) | 14 (9.5%)
1 Hour Visit
Normal | 35 (45.5%) | 42 (59.2%) | 32 (47.1%) | 33 (52.4%) | 10 (58.8%) | 8 (57.1%) | 77 (47.5%) | 83 (56.1%)
Abnormal, Not Clinically Significant | 2 (2.6%) | 0 | 1 (1.5%) | 3 (4.8%) | 0 | 0 | 3 (1.9%) | 3 (2.0%)
Abnormal, Clinically Significant | 10 (13.0%) | 8 (11.3%) | 11 (16.2%) | 8 (12.7%) | 0 | 2 (14.3%) | 21 (13.0%) | 18 (12.2%)
Change from Baseline to 1 hour Visit
Normal - Normal (no change) | 18 (23.4%) | 26 (36.6%) | 13 (19.1%) | 17 (27.0%) | 7 (41.2%) | 4 (28.6%) | 38 (23.5%) | 47 (31.8%)
Normal - Abnormal, NCS | 0 | 0 | 0 | 1 (1.6%) | 0 | 0 | 0 | 1 (0.7%)
Normal - Abnormal, CS | 4 (5.2%) | 2 (2.8%) | 2 (2.9%) | 0 | 0 | 0 | 6 (3.7%) | 2 (1.4%)
Abnormal, NCS - Normal | 0 | 3 (4.2%) | 2 (2.9%) | 1 (1.6%) | 1 (5.9%) | 1 (7.1%) | 3 (1.9%) | 5 (3.4%)
Abnormal, NCS - Abnormal, NCS (no change) | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, NCS - Abnormal, CS | 0 | 1 (1.4%) | 0 | 0 | 0 | 0 | 0 | 1 (0.7%)
Abnormal, CS - Normal | 0 | 1 (1.4%) | 3 (4.4%) | 3 (4.8%) | 1 (5.9%) | 1 (7.1%) | 4 (2.5%) | 5 (3.4%)
Abnormal, CS - Abnormal, NCS | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Abnormal, CS - Abnormal, CS (no change) | 1 (1.3%) | 0 | 5 (7.4%) | 2 (3.2%) | 0 | 0 | 6 (3.7%) | 2 (1.4%)

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.9.1.1 Summary of Vital Signs by Visit and Treatment Group Respiration Rate (rpm) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 69 | 66 | 59 | 57 | 16 | 13 | 144 | 136
Mean (SD) | 36.5 (14.9) | 34.3 (11.9) | 27.8 (11.7) | 29.6 (11.9) | 22.7 (8.8) | 21.8 (7.0) | 31.4 (14.0) | 31.1 (12.0)
95% CI of the Mean | 32.9, 40.1 | 31.4, 37.2 | 24.8, 30.9 | 26.4, 32.7 | 18.0, 27.4 | 17.5, 26.0 | 29.1, 33.7 | 29.1, 33.2
Median (Min-Max) | 34.0 (15.0, 85.0) | 31.5 (12.0, 69.0) | 24.0 (8.0, 84.0) | 26.0 (14.0, 74.0) | 19.0 (16.0, 44.0) | 22.0 (6.0, 32.0) | 28.0 (8.0, 85.0) | 30.0 (6.0, 74.0)
15 Minute Visit
N | 71 | 67 | 59 | 58 | 15 | 13 | 145 | 138
Mean (SD) | 35.6 (12.6) | 36.7 (13.4) | 28.2 (9.5) | 28.0 (9.3) | 22.2 (6.9) | 20.7 (4.5) | 31.2 (11.8) | 31.5 (12.4)
95% CI of the Mean | 32.6, 38.6 | 33.4, 39.9 | 25.7, 30.7 | 25.6, 30.4 | 18.4, 26.0 | 18.0, 23.4 | 29.3, 33.1 | 29.4, 33.6
Median (Min-Max) | 33.0 (15.0, 79.0) | 34.0 (11.0, 79.0) | 28.0 (10.0, 60.0) | 25.0 (16.0, 61.0) | 20.0 (13.0, 41.0) | 20.0 (14.0, 28.0) | 28.0 (10.0, 79.0) | 28.0 (11.0, 79.0)
30 Minute Visit
N | 71 | 67 | 58 | 56 | 16 | 12 | 145 | 135
Mean (SD) | 32.9 (10.5) | 35.6 (14.3) | 25.9 (9.2) | 26.7 (9.3) | 22.9 (9.4) | 21.3 (3.8) | 29.0 (10.6) | 30.6 (12.8)
95% CI of the Mean | 30.4, 35.4 | 32.1, 39.1 | 23.4, 28.3 | 24.2, 29.2 | 17.9, 27.9 | 18.9, 23.7 | 27.2, 30.7 | 28.4, 32.8
Median (Min-Max) | 30.0 (16.0, 62.0) | 32.0 (14.0, 82.0) | 24.5 (12.0, 52.0) | 24.5 (13.0, 60.0) | 21.0 (12.0, 47.0) | 20.5 (17.0, 28.0) | 28.0 (12.0, 62.0) | 27.0 (13.0, 82.0)
45 Minute Visit
N | 71 | 62 | 60 | 57 | 14 | 12 | 145 | 131
Mean (SD) | 32.3 (9.8) | 34.5 (12.7) | 24.8 (7.6) | 26.1 (6.3) | 20.7 (5.7) | 23.2 (6.3) | 28.1 (9.6) | 29.8 (10.8)
95% CI of the Mean | 30.0, 34.6 | 31.3, 37.8 | 22.8, 26.8 | 24.5, 27.8 | 17.4, 24.0 | 19.2, 27.1 | 26.5, 29.7 | 28.0, 31.7
Median (Min-Max) | 31.0 (16.0, 66.0) | 33.0 (20.0, 89.0) | 24.0 (12.0, 54.0) | 25.0 (16.0, 43.0) | 19.5 (12.0, 31.0) | 22.0 (17.0, 40.0) | 27.0 (12.0, 66.0) | 27.0 (16.0, 89.0)
60 Minute Visit
N | 72 | 64 | 64 | 55 | 16 | 12 | 152 | 131
Mean (SD) | 31.5 (9.3) | 33.3 (11.2) | 24.7 (6.2) | 26.0 (7.4) | 20.8 (6.0) | 22.7 (3.3) | 27.5 (8.7) | 29.3 (10.1)
95% CI of the Mean | 29.3, 33.7 | 30.4, 36.1 | 23.2, 26.3 | 24.0, 28.0 | 17.6, 24.0 | 20.5, 24.8 | 26.1, 28.9 | 27.5, 31.0
Median (Min-Max) | 30.0 (14.0, 62.0) | 32.0 (16.0, 72.0) | 24.0 (14.0, 41.0) | 25.0 (16.0, 53.0) | 21.0 (12.0, 37.0) | 22.0 (18.0, 28.0) | 26.5 (12.0, 62.0) | 28.0 (16.0, 72.0)
75 Minute Visit
N | 25 | 16 | 14 | 21 | 3 | 3 | 42 | 40
Mean (SD) | 32.0 (10.5) | 38.8 (17.0) | 22.6 (5.9) | 27.2 (9.6) | 25.7 (9.5) | 21.0 (1.7) | 28.4 (10.0) | 31.4 (14.1)
95% CI of the Mean | 27.6, 36.3 | 29.8, 47.9 | 19.2, 26.0 | 22.8, 31.6 | 2.1, 49.3 | 16.7, 25.3 | 25.3, 31.5 | 26.9, 35.9
Median (Min-Max) | 30.0 (17.0, 69.0) | 38.5 (15.0, 75.0) | 22.0 (16.0, 40.0) | 24.0 (15.0, 55.0) | 26.0 (16.0, 35.0) | 22.0 (19.0, 22.0) | 26.0 (16.0, 69.0) | 27.5 (15.0, 75.0)
90 Minute Visit
N | 15 | 7 | 8 | 10 | 1 | 0 | 24 | 17
Mean (SD) | 34.3 (9.7) | 36.6 (8.7) | 21.9 (4.4) | 29.2 (15.9) | 16.0 | 0 | 29.4 (10.3) | 32.2 (13.6)
95% CI of the Mean | 29.0, 39.7 | 28.6, 44.6 | 18.2, 25.6 | 17.8, 40.6 | . | 0 | 25.1, 33.8 | 25.2, 39.2
Median (Min-Max) | 33.0 (20.0, 54.0) | 35.0 (26.0, 51.0) | 20.5 (16.0, 29.0) | 23.0 (16.0, 59.0) | 16.0 | 0 | 28.0 (16.0, 54.0) | 29.0 (16.0, 59.0)
105 Minute Visit
N | 7 | 9 | 5 | 4 | 1 | 0 | 13 | 13
Mean (SD) | 37.6 (8.3) | 31.8 (11.4) | 28.0 (10.8) | 29.8 (12.4) | 17.0 | 0 | 32.3 (10.8) | 31.2 (11.2)
95% CI of the Mean | 29.9, 45.2 | 23.0, 40.5 | 14.6, 41.4 | 10.0, 49.5 | . | 0 | 25.8, 38.8 | 24.4, 37.9
Median (Min-Max) | 36.0 (31.0, 55.0) | 27.0 (22.0, 58.0) | 30.0 (12.0, 42.0) | 28.5 (16.0, 46.0) | 17.0 | 0 | 32.0 (12.0, 55.0) | 27.0 (16.0, 58.0)
Change from Baseline to 105 Minute Visit
N | 6 | 9 | 5 | 4 | 1 | 0 | 12 | 13
Mean (SD) | −0.5 (13.4) | −0.1 (9.1) | −1.6 (22.5) | −7.0 (14.1) | −6.0 | 0 | −1.4 (16.4) | −2.2 (10.7)
95% CI of the Mean | 0.0, 13.6 | 0.0, 6.9 | 0.0, 26.4 | 0.0, 15.4 | . | 0 | 0.0, 9.0 | 0.0, 4.3
Median (Min-Max) | 2.0 (−25.0, 11.0) | 2.0 (−11.0, 11.0) | 8.0 (−36.0, 22.0) | −5.5 (−25.0, 8.0) | −6.0 | 0 | 2.0 (−36.0, 22.0) | −1.0 (−25.0, 11.0)

Table 14.3.9.1.2 Summary of Vital Signs by Visit and Treatment Group Pulse Rate (bpm) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 73 | 68 | 59 | 59 | 16 | 13 | 148 | 140
Mean (SD) | 160.5 (31.5) | 158.1 (29.2) | 134.4 (25.5) | 127.3 (27.4) | 111.6 (28.3) | 110.8 (31.9) | 144.8 (33.3) | 140.7 (33.5)
95% CI of the Mean | 153.1, 167.8 | 151.1, 165.2 | 127.8, 141.1 | 120.1, 134.4 | 96.5, 126.7 | 91.5, 130.0 | 139.4, 150.2 | 135.1, 146.3
Median (Min-Max) | 163.0 (72.0, 228.0) | 158.0 (102.0, 242.0) | 130.0 (81.0, 195.0) | 129.0 (64.0, 187.0) | 107.5 (66.0, 167.0) | 113.0 (63.0, 175.0) | 144.5 (66.0, 228.0) | 138.5 (63.0, 242.0)
15 Minute Visit
N | 70 | 70 | 61 | 59 | 16 | 13 | 147 | 142
Mean (SD) | 154.2 (26.4) | 158.0 (24.4) | 128.2 (24.9) | 127.9 (23.8) | 103.8 (20.0) | 108.4 (25.8) | 137.9 (30.3) | 141.0 (29.9)
95% CI of the Mean | 147.9, 160.5 | 152.2, 163.9 | 121.8, 134.5 | 121.7, 134.1 | 93.1, 114.5 | 92.8, 124.0 | 133.0, 142.9 | 136.0, 145.9
Median (Min-Max) | 153.0 (97.0, 213.0) | 154.0 (117.0, 221.0) | 122.0 (86.0, 188.0) | 128.0 (61.0, 180.0) | 100.0 (79.0, 158.0) | 106.0 (64.0, 168.0) | 138.0 (79.0, 213.0) | 138.0 (61.0, 221.0)
30 Minute Visit
N | 70 | 68 | 61 | 56 | 16 | 12 | 147 | 136
Mean (SD) | 151.6 (26.3) | 151.7 (23.5) | 123.5 (23.8) | 123.3 (23.6) | 97.8 (20.0) | 101.6 (17.2) | 134.1 (30.7) | 135.6 (28.6)
95% CI of the Mean | 145.4, 157.9 | 146.0, 157.4 | 117.4, 129.6 | 117.0, 129.7 | 87.1, 108.4 | 90.7, 112.5 | 129.1, 139.1 | 130.7, 140.5
Median (Min-Max) | 153.0 (96.0, 202.0) | 151.5 (86.0, 210.0) | 123.0 (78.0, 180.0) | 123.0 (62.0, 180.0) | 96.5 (62.0, 140.0) | 102.5 (59.0, 124.0) | 135.0 (62.0, 202.0) | 134.0 (59.0, 210.0)
45 Minute Visit
N | 71 | 66 | 63 | 57 | 14 | 12 | 148 | 135
Mean (SD) | 148.1 (27.7) | 148.9 (21.6) | 121.6 (27.6) | 121.6 (21.4) | 94.1 (23.3) | 105.9 (22.0) | 131.7 (32.3) | 133.6 (26.5)
95% CI of the Mean | 141.5, 154.7 | 143.6, 154.2 | 114.7, 128.6 | 115.9, 127.3 | 80.7, 107.6 | 91.9, 119.9 | 126.5, 137.0 | 129.1, 138.1
Median (Min-Max) | 150.0 (88.0, 236.0) | 149.0 (90.0, 196.0) | 118.0 (73.0, 198.0) | 121.0 (79.0, 173.0) | 85.5 (66.0, 142.0) | 101.5 (68.0, 158.0) | 129.0 (66.0, 236.0) | 134.0 (68.0, 196.0)
60 Minute Visit
N | 72 | 66 | 66 | 56 | 16 | 12 | 154 | 134
Mean (SD) | 145.6 (28.0) | 146.2 (24.0) | 118.3 (23.6) | 119.0 (23.5) | 98.1 (21.7) | 97.2 (16.4) | 129.0 (30.4) | 130.4 (28.4)
95% CI of the Mean | 139.0, 152.2 | 140.3, 152.1 | 112.5, 124.1 | 112.7, 125.3 | 86.6, 109.7 | 86.7, 107.6 | 124.1, 133.8 | 125.6, 135.3
Median (Min-Max) | 142.5 (88.0, 236.0) | 150.0 (87.0, 197.0) | 115.0 (76.0, 188.0) | 119.0 (67.0, 177.0) | 94.5 (68.0, 145.0) | 97.0 (67.0, 119.0) | 128.5 (68.0, 236.0) | 128.0 (67.0, 197.0)
75 Minute Visit
N | 25 | 16 | 14 | 21 | 3 | 3 | 42 | 40
Mean (SD) | 144.6 (19.0) | 160.6 (21.2) | 119.2 (26.5) | 116.6 (22.7) | 84.7 (11.4) | 89.7 (6.0) | 131.8 (27.5) | 132.2 (32.2)
95% CI of the Mean | 136.7, 152.4 | 149.3, 171.8 | 103.9, 134.5 | 106.3, 126.9 | 56.4, 112.9 | 74.7, 104.6 | 123.3, 140.4 | 121.9, 142.5
Median (Min-Max) | 142.0 (110.0, 192.0) | 162.5 (124.0, 201.0) | 110.5 (88.0, 183.0) | 116.0 (70.0, 160.0) | 88.0 (72.0, 94.0) | 89.0 (84.0, 96.0) | 134.5 (72.0, 192.0) | 128.5 (70.0, 201.0)
90 Minute Visit
N | 15 | 9 | 8 | 9 | 1 | 0 | 24 | 18
Mean (SD) | 153.9 (27.7) | 153.2 (24.8) | 117.4 (20.0) | 117.6 (16.9) | 67.0 | 0 | 138.1 (33.5) | 135.4 (27.6)
95% CI of the Mean | 138.6, 169.3 | 134.2, 172.3 | 100.7, 134.1 | 104.6, 130.5 | . | 0 | 124.0, 152.3 | 121.7, 149.1
Median (Min-Max) | 153.0 (101.0, 199.0) | 160.0 (101.0, 180.0) | 114.0 (80.0, 140.0) | 111.0 (100.0, 148.0) | 67.0 | 0 | 139.0 (67.0, 199.0) | 134.5 (100.0, 180.0)
105 Minute Visit
N | 7 | 10 | 5 | 4 | 1 | 0 | 13 | 14
Mean (SD) | 155.4 (25.4) | 146.2 (18.8) | 100.2 (29.9) | 121.5 (29.0) | 68.0 | 0 | 127.5 (41.0) | 139.1 (23.9)
95% CI of the Mean | 132.0, 178.9 | 132.7, 159.7 | 63.0, 137.4 | 75.4, 167.6 | . | 0 | 102.7, 152.2 | 125.3, 153.0
Median (Min-Max) | 147.0 (129.0, 196.0) | 147.5 (120.0, 178.0) | 104.0 (60.0, 140.0) | 110.0 (102.0, 164.0) | 68.0 | 0 | 132.0 (60.0, 196.0) | 138.0 (102.0, 178.0)
Change from Baseline to 105 Minute Visit
N | 7 | 10 | 5 | 4 | 1 | 0 | 13 | 14
Mean (SD) | −24.3 (44.0) | −0.9 (32.6) | −38.8 (24.2) | −15.3 (35.4) | 2.0 | 0 | −27.8 (36.0) | −5.0 (32.7)
95% CI of the Mean | 0.0, 16.4 | 0.0, 22.4 | 0.0, −8.7 | 0.0, 41.0 | . | 0 | 0.0, −6.1 | 0.0, 13.9
Median (Min-Max) | −12.0 (−88.0, 34.0) | −2.0 (−35.0, 76.0) | −36.0 (−75.0, −13.0) | −15.5 (−52.0, 22.0) | 2.0 | 0 | −22.0 (−88.0, 34.0) | −2.0 (−52.0, 76.0)

Table 14.3.9.1.3 Summary of Vital Signs by Visit and Treatment Group O_2_ Sat (%) Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 71 | 67 | 56 | 58 | 15 | 13 | 142 | 138
Mean (SD) | 98.5 (3.3) | 97.5 (4.8) | 97.7 (3.4) | 97.5 (4.1) | 99.0 (1.8) | 98.1 (3.7) | 98.3 (3.2) | 97.5 (4.4)
95% CI of the Mean | 97.8, 99.3 | 96.3, 98.7 | 96.8, 98.6 | 96.4, 98.6 | 98.0, 100.0 | 95.9, 100.3 | 97.7, 98.8 | 96.8, 98.3
Median (Min-Max) | 100.0 (82.0, 100.0) | 99.0 (75.0, 100.0) | 99.0 (83.0, 100.0) | 99.0 (80.0, 100.0) | 100.0 (94.0, 100.0) | 100.0 (88.0, 100.0) | 100.0 (82.0, 100.0) | 99.0 (75.0, 100.0)
15 Minute Visit
N | 69 | 69 | 60 | 58 | 16 | 13 | 145 | 140
Mean (SD) | 98.7 (2.5) | 98.8 (1.8) | 98.6 (2.0) | 98.9 (1.5) | 98.3 (2.4) | 98.0 (2.2) | 98.6 (2.3) | 98.8 (1.8)
95% CI of the Mean | 98.1, 99.2 | 98.3, 99.2 | 98.1, 99.1 | 98.5, 99.3 | 97.1, 99.6 | 96.7, 99.3 | 98.2, 98.9 | 98.5, 99.1
Median (Min-Max) | 100.0 (85.0, 100.0) | 100.0 (91.0, 100.0) | 99.0 (90.0, 100.0) | 100.0 (95.0, 100.0) | 99.5 (93.0, 100.0) | 99.0 (95.0, 100.0) | 100.0 (85.0, 100.0) | 100.0 (91.0, 100.0)
30 Minute Visit
N | 70 | 67 | 60 | 56 | 16 | 12 | 146 | 135
Mean (SD) | 98.6 (2.7) | 98.4 (2.3) | 98.4 (2.3) | 98.7 (1.8) | 98.9 (1.7) | 98.5 (2.2) | 98.6 (2.4) | 98.5 (2.1)
95% CI of the Mean | 98.0, 99.3 | 97.8, 98.9 | 97.8, 99.0 | 98.2, 99.2 | 98.0, 99.8 | 97.1, 99.9 | 98.2, 99.0 | 98.2, 98.9
Median (Min-Max) | 100.0 (87.0, 100.0) | 100.0 (90.0, 100.0) | 99.0 (90.0, 100.0) | 100.0 (94.0, 100.0) | 99.5 (95.0, 100.0) | 100.0 (94.0, 100.0) | 100.0 (87.0, 100.0) | 100.0 (90.0, 100.0)
45 Minute Visit
N | 71 | 65 | 62 | 57 | 14 | 12 | 147 | 134
Mean (SD) | 98.9 (1.9) | 98.6 (2.0) | 98.5 (2.1) | 98.4 (2.2) | 98.5 (2.3) | 98.5 (1.5) | 98.7 (2.0) | 98.5 (2.1)
95% CI of the Mean | 98.5, 99.4 | 98.2, 99.1 | 98.0, 99.0 | 97.8, 98.9 | 97.2, 99.8 | 97.5, 99.5 | 98.4, 99.0 | 98.2, 98.9
Median (Min-Max) | 100.0 (90.0, 100.0) | 100.0 (90.0, 100.0) | 99.0 (91.0, 100.0) | 99.0 (90.0, 100.0) | 100.0 (93.0, 100.0) | 99.0 (96.0, 100.0) | 100.0 (90.0, 100.0) | 99.0 (90.0, 100.0)
60 Minute Visit
N | 72 | 66 | 65 | 55 | 16 | 12 | 153 | 133
Mean (SD) | 98.3 (4.4) | 98.7 (2.1) | 97.5 (6.1) | 98.4 (2.9) | 98.5 (2.2) | 98.6 (1.5) | 98.0 (5.1) | 98.5 (2.4)
95% CI of the Mean | 97.3, 99.4 | 98.2, 99.2 | 95.9, 99.0 | 97.6, 99.2 | 97.3, 99.7 | 97.6, 99.5 | 97.2, 98.8 | 98.1, 99.0
Median (Min-Max) | 100.0 (65.0, 100.0) | 100.0 (91.0, 100.0) | 99.0 (55.0, 100.0) | 100.0 (82.0, 100.0) | 99.5 (94.0, 100.0) | 98.0 (95.0, 100.0) | 100.0 (55.0, 100.0) | 100.0 (82.0, 100.0)
75 Minute Visit
N | 26 | 17 | 14 | 21 | 3 | 3 | 43 | 41
Mean (SD) | 98.7 (3.1) | 95.7 (9.6) | 97.8 (3.8) | 98.3 (2.6) | 99.0 (1.7) | 98.7 (1.2) | 98.4 (3.2) | 97.2 (6.5)
95% CI of the Mean | 97.5, 99.9 | 90.7, 100.7 | 95.6, 100.0 | 97.1, 99.5 | 94.7, 103.3 | 95.8, 101.5 | 97.4, 99.4 | 95.2, 99.3
Median (Min-Max) | 100.0 (85.0, 100.0) | 98.0 (60.0, 100.0) | 99.5 (86.0, 100.0) | 100.0 (92.0, 100.0) | 100.0 (97.0, 100.0) | 98.0 (98.0, 100.0) | 100.0 (85.0, 100.0) | 99.0 (60.0, 100.0)
90 Minute Visit
N | 15 | 9 | 8 | 9 | 2 | 0 | 25 | 18
Mean (SD) | 97.9 (5.4) | 98.3 (1.7) | 98.9 (1.6) | 97.9 (2.4) | 98.0 (2.8) | 0 | 98.2 (4.3) | 98.1 (2.0)
95% CI of the Mean | 94.9, 100.9 | 97.1, 99.6 | 97.5, 100.2 | 96.0, 99.7 | 72.6, 123.4 | 0 | 96.4, 100.0 | 97.1, 99.1
Median (Min-Max) | 100.0 (79.0, 100.0) | 98.0 (96.0, 100.0) | 100.0 (96.0, 100.0) | 99.0 (94.0, 100.0) | 98.0 (96.0, 100.0) | 0 | 100.0 (79.0, 100.0) | 98.5 (94.0, 100.0)
105 Minute Visit
N | 7 | 10 | 5 | 4 | 1 | 0 | 13 | 14
Mean (SD) | 98.0 (2.9) | 98.8 (1.6) | 96.4 (4.1) | 97.8 (4.5) | 85.0 | 0 | 96.4 (4.7) | 98.5 (2.6)
95% CI of the Mean | 95.3, 100.7 | 97.6, 100.0 | 91.3, 101.5 | 90.6, 104.9 | . | 0 | 93.5, 99.2 | 97.0, 100.0
Median (Min-Max) | 100.0 (93.0, 100.0) | 100.0 (96.0, 100.0) | 96.0 (90.0, 100.0) | 100.0 (91.0, 100.0) | 85.0 | 0 | 98.0 (85.0, 100.0) | 100.0 (91.0, 100.0)
Change from Baseline to 105 Minute Visit
N | 6 | 9 | 5 | 4 | 1 | 0 | 12 | 13
Mean (SD) | 1.0 (8.8) | 1.2 (2.9) | −0.8 (3.3) | −0.5 (3.9) | −15.0 | 0 | −1.1 (7.7) | 0.7 (3.2)
95% CI of the Mean | 0.0, 10.2 | 0.0, 3.5 | 0.0, 3.4 | 0.0, 5.7 | . | 0 | 0.0, 3.8 | 0.0, 2.6
Median (Min-Max) | −0.5 (−7.0, 18.0) | 0.0 (−2.0, 7.0) | 0.0 (−4.0, 4.0) | 0.5 (−6.0, 3.0) | −15.0 | 0 | −0.5 (−15.0, 18.0) | 0.0 (−6.0, 7.0)

Table 14.3.9.1.4 Summary of Vital Signs by Visit and Treatment Group Systolic BP Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 59 | 53 | 48 | 51 | 16 | 12 | 123 | 116
Mean (SD) | 113.2 (21.9) | 105.4 (19.5) | 121.1 (18.2) | 118.5 (16.4) | 128.3 (24.4) | 131.1 (23.3) | 118.2 (21.4) | 113.8 (20.3)
95% CI of the Mean | 107.5, 118.9 | 100.0, 110.8 | 115.8, 126.4 | 113.8, 123.1 | 115.3, 141.2 | 116.3, 145.9 | 114.4, 122.0 | 110.1, 117.5
Median (Min-Max) | 112.0 (78.0, 194.0) | 105.0 (57.0, 171.0) | 119.0 (75.0, 165.0) | 122.0 (82.0, 167.0) | 126.5 (71.0, 166.0) | 119.0 (109.0, 176.0) | 115.0 (71.0, 194.0) | 113.0 (57.0, 176.0)
15 Minute Visit
N | 60 | 60 | 60 | 50 | 14 | 10 | 134 | 120
Mean (SD) | 102.2 (15.5) | 104.3 (17.8) | 108.9 (14.9) | 109.0 (15.3) | 121.0 (23.6) | 115.1 (9.5) | 107.2 (17.1) | 107.2 (16.5)
95% CI of the Mean | 98.2, 106.2 | 99.7, 108.9 | 105.1, 112.8 | 104.7, 113.4 | 107.4, 134.6 | 108.3, 121.9 | 104.3, 110.1 | 104.2, 110.1
Median (Min-Max) | 101.0 (72.0, 145.0) | 104.0 (70.0, 174.0) | 109.0 (73.0, 149.0) | 105.5 (84.0, 162.0) | 114.5 (93.0, 179.0) | 114.0 (101.0, 130.0) | 106.0 (72.0, 179.0) | 106.0 (70.0, 174.0)
30 Minute Visit
N | 60 | 58 | 52 | 52 | 15 | 11 | 127 | 121
Mean (SD) | 99.4 (13.8) | 97.9 (13.7) | 107.2 (14.6) | 108.2 (15.5) | 115.7 (22.6) | 116.2 (16.0) | 104.5 (16.2) | 104.0 (15.9)
95% CI of the Mean | 95.8, 102.9 | 94.3, 101.5 | 103.2, 111.3 | 103.8, 112.5 | 103.2, 128.2 | 105.4, 127.0 | 101.7, 107.4 | 101.1, 106.8
Median (Min-Max) | 99.0 (67.0, 129.0) | 95.0 (71.0, 131.0) | 107.0 (80.0, 136.0) | 107.5 (71.0, 145.0) | 113.0 (89.0, 176.0) | 115.0 (101.0, 156.0) | 103.0 (67.0, 176.0) | 102.0 (71.0, 156.0)
45 Minute Visit
N | 59 | 60 | 58 | 50 | 13 | 11 | 130 | 121
Mean (SD) | 98.9 (15.6) | 96.2 (11.7) | 106.0 (14.6) | 106.0 (14.0) | 114.5 (17.5) | 121.9 (21.2) | 103.6 (16.0) | 102.6 (15.6)
95% CI of the Mean | 94.8, 102.9 | 93.1, 99.2 | 102.2, 109.9 | 102.1, 110.0 | 103.9, 125.0 | 107.7, 136.2 | 100.8, 106.4 | 99.8, 105.4
Median (Min-Max) | 99.0 (72.0, 153.0) | 94.5 (69.0, 131.0) | 107.0 (75.0, 135.0) | 103.0 (84.0, 146.0) | 116.0 (83.0, 144.0) | 112.0 (100.0, 160.0) | 103.0 (72.0, 153.0) | 98.0 (69.0, 160.0)
60 Minute Visit
N | 67 | 63 | 58 | 51 | 15 | 12 | 140 | 126
Mean (SD) | 97.9 (17.6) | 96.3 (12.8) | 104.2 (13.9) | 105.2 (14.7) | 109.2 (24.4) | 115.8 (17.5) | 101.7 (17.4) | 101.8 (15.2)
95% CI of the Mean | 93.6, 102.2 | 93.1, 99.6 | 100.5, 107.8 | 101.1, 109.3 | 95.7, 122.7 | 104.6, 126.9 | 98.8, 104.6 | 99.1, 104.5
Median (Min-Max) | 97.0 (55.0, 174.0) | 96.0 (67.0, 133.0) | 104.0 (75.0, 140.0) | 103.0 (77.0, 136.0) | 106.0 (62.0, 165.0) | 108.0 (97.0, 155.0) | 100.5 (55.0, 174.0) | 100.0 (67.0, 155.0)
75 Minute Visit
N | 18 | 13 | 12 | 16 | 2 | 2 | 32 | 31
Mean (SD) | 93.4 (16.4) | 97.3 (10.0) | 106.4 (21.5) | 102.9 (14.7) | 107.5 (14.8) | 101.0 (2.8) | 99.2 (19.0) | 100.5 (12.5)
95% CI of the Mean | 85.2, 101.6 | 91.3, 103.3 | 92.8, 120.1 | 95.1, 110.8 | 0.0, 240.9 | 75.6, 126.4 | 92.3, 106.0 | 95.9, 105.0
Median (Min-Max) | 93.0 (69.0, 127.0) | 96.0 (85.0, 118.0) | 103.0 (77.0, 147.0) | 103.0 (75.0, 131.0) | 107.5 (97.0, 118.0) | 101.0 (99.0, 103.0) | 97.5 (69.0, 147.0) | 98.0 (75.0, 131.0)
90 Minute Visit
N | 11 | 9 | 7 | 9 | 1 | 0 | 19 | 18
Mean (SD) | 94.2 (10.3) | 94.1 (13.0) | 98.9 (14.0) | 97.2 (13.6) | 97.0 | 0 | 96.1 (11.4) | 95.7 (13.0)
95% CI of the Mean | 87.3, 101.1 | 84.1, 104.1 | 85.9, 111.8 | 86.8, 107.7 | . | 0 | 90.6, 101.5 | 89.2, 102.1
Median (Min-Max) | 91.0 (75.0, 114.0) | 91.0 (75.0, 119.0) | 99.0 (82.0, 124.0) | 96.0 (74.0, 117.0) | 97.0 | 0 | 95.0 (75.0, 124.0) | 94.5 (74.0, 119.0)
105 Minute Visit
N | 6 | 9 | 5 | 4 | 1 | 0 | 12 | 13
Mean (SD) | 97.0 (27.9) | 99.8 (13.7) | 88.4 (18.8) | 91.0 (12.0) | 97.0 | 0 | 93.4 (22.4) | 97.1 (13.4)
95% CI of the Mean | 67.8, 126.2 | 89.2, 110.3 | 65.0, 111.8 | 71.9, 110.1 | . | 0 | 79.2, 107.6 | 89.0, 105.2
Median (Min-Max) | 97.5 (60.0, 134.0) | 103.0 (81.0, 121.0) | 85.0 (67.0, 112.0) | 92.5 (77.0, 102.0) | 97.0 | 0 | 92.0 (60.0, 134.0) | 100.0 (77.0, 121.0)
Change from Baseline to 105 Minute Visit
N | 5 | 8 | 4 | 3 | 1 | 0 | 10 | 11
Mean (SD) | −36.0 (46.5) | −1.3 (13.0) | −60.5 (21.6) | −17.0 (21.8) | 26.0 | 0 | −39.6 (42.4) | −5.5 (16.4)
95% CI of the Mean | 0.0, 21.8 | 0.0, 9.6 | 0.0, −26.1 | 0.0, 37.1 | . | 0 | 0.0, −9.3 | 0.0, 5.4
Median (Min-Max) | −25.0 (−116.0, 2.0) | −1.0 (−22.0, 15.0) | −56.5 (−90.0, −39.0) | −7.0 (−42.0, −2.0) | 26.0 | 0 | −35.0 (−116.0, 26.0) | −7.0 (−42.0, 15.0)

Table 14.3.9.1.5 Summary of Vital Signs by Visit and Treatment Group Diastolic BP Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
N | 59 | 53 | 48 | 51 | 16 | 12 | 123 | 116
Mean (SD) | 63.1 (16.9) | 65.6 (17.8) | 68.4 (15.6) | 68.3 (15.1) | 75.0 (17.6) | 70.8 (20.3) | 66.7 (16.8) | 67.3 (16.9)
95% CI of the Mean | 58.7, 67.5 | 60.7, 70.5 | 63.9, 73.0 | 64.1, 72.5 | 65.6, 84.4 | 58.0, 83.7 | 63.7, 69.7 | 64.2, 70.4
Median (Min-Max) | 59.0 (25.0, 112.0) | 63.0 (22.0, 126.0) | 68.5 (38.0, 111.0) | 66.0 (21.0, 99.0) | 71.0 (52.0, 114.0) | 66.5 (44.0, 104.0) | 65.0 (25.0, 114.0) | 64.5 (21.0, 126.0)
15 Minute Visit
N | 59 | 60 | 59 | 50 | 14 | 10 | 132 | 120
Mean (SD) | 58.8 (14.1) | 60.5 (12.9) | 61.5 (12.8) | 62.7 (13.6) | 67.4 (14.2) | 58.2 (13.2) | 60.9 (13.7) | 61.2 (13.2)
95% CI of the Mean | 55.1, 62.5 | 57.2, 63.9 | 58.2, 64.9 | 58.9, 66.6 | 59.2, 75.6 | 48.8, 67.6 | 58.6, 63.3 | 58.9, 63.6
Median (Min-Max) | 59.0 (34.0, 98.0) | 60.5 (33.0, 97.0) | 59.0 (40.0, 95.0) | 62.0 (41.0, 103.0) | 65.5 (48.0, 100.0) | 58.5 (38.0, 79.0) | 60.0 (34.0, 100.0) | 61.0 (33.0, 103.0)
30 Minute Visit
N | 60 | 58 | 52 | 52 | 15 | 11 | 127 | 121
Mean (SD) | 55.9 (11.7) | 57.8 (13.4) | 61.9 (15.1) | 61.8 (14.7) | 68.1 (19.7) | 61.0 (14.9) | 59.8 (14.7) | 59.8 (14.1)
95% CI of the Mean | 52.9, 58.9 | 54.2, 61.3 | 57.7, 66.1 | 57.7, 65.9 | 57.2, 79.0 | 51.0, 71.0 | 57.2, 62.4 | 57.3, 62.4
Median (Min-Max) | 57.0 (34.0, 85.0) | 54.0 (34.0, 94.0) | 59.0 (37.0, 98.0) | 61.5 (33.0, 97.0) | 65.0 (30.0, 97.0) | 61.0 (39.0, 92.0) | 59.0 (30.0, 98.0) | 60.0 (33.0, 97.0)
45 Minute Visit
N | 59 | 60 | 58 | 50 | 13 | 11 | 130 | 121
Mean (SD) | 56.2 (16.0) | 52.4 (9.3) | 61.6 (13.5) | 58.4 (13.0) | 61.1 (11.0) | 62.2 (14.4) | 59.1 (14.6) | 55.8 (11.9)
95% CI of the Mean | 52.0, 60.3 | 50.0, 54.8 | 58.0, 65.1 | 54.7, 62.1 | 54.4, 67.7 | 52.5, 71.9 | 56.5, 61.6 | 53.6, 57.9
Median (Min-Max) | 55.0 (25.0, 105.0) | 51.0 (39.0, 83.0) | 60.5 (36.0, 98.0) | 58.0 (33.0, 88.0) | 59.0 (47.0, 86.0) | 62.0 (42.0, 88.0) | 59.0 (25.0, 105.0) | 54.0 (33.0, 88.0)
60 Minute Visit
N | 66 | 63 | 58 | 51 | 15 | 12 | 139 | 126
Mean (SD) | 54.5 (15.8) | 53.2 (12.0) | 58.6 (11.1) | 60.5 (13.4) | 61.7 (18.8) | 63.4 (14.3) | 57.0 (14.5) | 57.1 (13.3)
95% CI of the Mean | 50.6, 58.4 | 50.2, 56.2 | 55.7, 61.5 | 56.7, 64.3 | 51.3, 72.1 | 54.3, 72.5 | 54.5, 59.4 | 54.8, 59.5
Median (Min-Max) | 53.5 (20.0, 100.0) | 51.0 (36.0, 91.0) | 57.5 (34.0, 89.0) | 61.0 (33.0, 99.0) | 61.0 (30.0, 106.0) | 61.5 (48.0, 98.0) | 57.0 (20.0, 106.0) | 56.0 (33.0, 99.0)
75 Minute Visit
N | 18 | 13 | 12 | 16 | 2 | 2 | 32 | 31
Mean (SD) | 51.1 (15.9) | 54.2 (16.8) | 59.4 (17.9) | 60.8 (11.9) | 62.0 (0.0) | 53.0 (2.8) | 54.9 (16.5) | 57.5 (14.0)
95% CI of the Mean | 43.2, 59.0 | 44.1, 64.4 | 48.1, 70.8 | 54.5, 67.2 | ., . | 27.6, 78.4 | 49.0, 60.8 | 52.4, 62.7
Median (Min-Max) | 50.0 (20.0, 87.0) | 54.0 (27.0, 99.0) | 54.0 (40.0, 106.0) | 62.0 (37.0, 82.0) | 62.0 (62.0, 62.0) | 53.0 (51.0, 55.0) | 52.5 (20.0, 106.0) | 56.0 (27.0, 99.0)
90 Minute Visit
N | 11 | 9 | 7 | 9 | 1 | 0 | 19 | 18
Mean (SD) | 51.8 (11.4) | 52.1 (10.2) | 58.0 (12.6) | 56.3 (14.1) | 62.0 | 0 | 54.6 (11.7) | 54.2 (12.1)
95% CI of the Mean | 44.2, 59.5 | 44.3, 60.0 | 46.3, 69.7 | 45.5, 67.1 | . | 0 | 49.0, 60.3 | 48.2, 60.2
Median (Min-Max) | 49.0 (35.0, 70.0) | 51.0 (39.0, 70.0) | 55.0 (41.0, 81.0) | 55.0 (39.0, 80.0) | 62.0 | 0 | 54.0 (35.0, 81.0) | 52.5 (39.0, 80.0)
105 Minute Visit
N | 6 | 9 | 5 | 4 | 1 | 0 | 12 | 13
Mean (SD) | 51.5 (17.3) | 54.4 (11.1) | 50.4 (13.1) | 50.0 (7.5) | 62.0 | 0 | 51.9 (14.5) | 53.1 (10.1)
95% CI of the Mean | 33.3, 69.7 | 45.9, 63.0 | 34.2, 66.6 | 38.1, 61.9 | . | 0 | 42.7, 61.1 | 47.0, 59.2
Median (Min-Max) | 58.0 (22.0, 66.0) | 55.0 (33.0, 70.0) | 47.0 (35.0, 70.0) | 49.0 (42.0, 60.0) | 62.0 | 0 | 53.5 (22.0, 70.0) | 54.0 (33.0, 70.0)
Change from Baseline to 105 Minute Visit
N | 5 | 8 | 4 | 3 | 1 | 0 | 10 | 11
Mean (SD) | −3.0 (15.6) | −6.4 (15.7) | −34.0 (31.5) | −25.3 (22.5) | 5.0 | 0 | −14.6 (26.9) | −11.5 (18.8)
95% CI of the Mean | 0.0, 16.4 | 0.0, 6.7 | 0.0, 16.1 | 0.0, 30.7 | . | 0 | 0.0, 4.6 | 0.0, 1.1
Median (Min-Max) | −3.0 (−26.0, 18.0) | 0.0 (−30.0, 10.0) | −28.0 (−76.0, −4.0) | −27.0 (−47.0, −2.0) | 5.0 | 0 | −3.5 (−76.0, 18.0) | −4.0 (−47.0, 10.0)

Table 14.3.10 Summary of ECG Results by Age Stratum and Treatment Group Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Normal | 28 (36.4%) | 35 (49.3%) | 35 (51.5%) | 33 (52.4%) | 11 (64.7%) | 7 (50.0%) | 74 (45.7%) | 75 (50.7%)
Abnormal - Not clinically significant | 13 (16.9%) | 16 (22.5%) | 6 (8.8%) | 6 (9.5%) | 1 (5.9%) | 1 (7.1%) | 20 (12.3%) | 23 (15.5%)
Abnormal - Clinically significant | 0 | 0 | 1 (1.5%) | 1 (1.6%) | 0 | 1 (7.1%) | 1 (0.6%) | 2 (1.4%)
15 Minute Visit
Normal | 41 (53.2%) | 40 (56.3%) | 45 (66.2%) | 38 (60.3%) | 9 (52.9%) | 9 (64.3%) | 95 (58.6%) | 87 (58.8%)
Abnormal - Not clinically significant | 13 (16.9%) | 13 (18.3%) | 6 (8.8%) | 7 (11.1%) | 0 | 1 (7.1%) | 19 (11.7%) | 21 (14.2%)
Abnormal - Clinically significant | 0 | 0 | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 1 (0.7%)
30 Minute Visit
Normal | 47 (61.0%) | 39 (54.9%) | 41 (60.3%) | 38 (60.3%) | 11 (64.7%) | 9 (64.3%) | 99 (61.1%) | 86 (58.1%)
Abnormal - Not clinically significant | 11 (14.3%) | 13 (18.3%) | 6 (8.8%) | 9 (14.3%) | 1 (5.9%) | 0 | 18 (11.1%) | 22 (14.9%)
Abnormal - Clinically significant | 0 | 0 | 2 (2.9%) | 1 (1.6%) | 0 | 0 | 2 (1.2%) | 1 (0.7%)
45 Minute Visit
Normal | 47 (61.0%) | 39 (54.9%) | 49 (72.1%) | 39 (61.9%) | 9 (52.9%) | 10 (71.4%) | 105 (64.8%) | 88 (59.5%)
Abnormal - Not clinically significant | 10 (13.0%) | 12 (16.9%) | 4 (5.9%) | 8 (12.7%) | 1 (5.9%) | 0 | 15 (9.3%) | 20 (13.5%)
Abnormal - Clinically significant | 0 | 0 | 1 (1.5%) | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
1 Hour Visit
Normal | 50 (64.9%) | 46 (64.8%) | 49 (72.1%) | 39 (61.9%) | 13 (76.5%) | 9 (64.3%) | 112 (69.1%) | 94 (63.5%)
Abnormal - Not clinically significant | 14 (18.2%) | 12 (16.9%) | 6 (8.8%) | 12 (19.0%) | 1 (5.9%) | 0 | 21 (13.0%) | 24 (16.2%)
Abnormal - Clinically significant | 1 (1.3%) | 0 | 0 | 1 (1.6%) | 0 | 0 | 1 (0.6%) | 1 (0.7%)
2 Hour Visit
Normal | 49 (63.6%) | 52 (73.2%) | 46 (67.6%) | 37 (58.7%) | 10 (58.8%) | 6 (42.9%) | 105 (64.8%) | 95 (64.2%)
Abnormal - Not clinically significant | 11 (14.3%) | 11 (15.5%) | 7 (10.3%) | 9 (14.3%) | 1 (5.9%) | 1 (7.1%) | 19 (11.7%) | 21 (14.2%)
Abnormal - Clinically significant | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
3 Hour Visit
Normal | 46 (59.7%) | 46 (64.8%) | 45 (66.2%) | 42 (66.7%) | 9 (52.9%) | 8 (57.1%) | 100 (61.7%) | 96 (64.9%)
Abnormal - Not clinically significant | 11 (14.3%) | 13 (18.3%) | 7 (10.3%) | 8 (12.7%) | 2 (11.8%) | 1 (7.1%) | 20 (12.3%) | 22 (14.9%)
Abnormal - Clinically significant | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
4 Hour Visit
Normal | 46 (59.7%) | 45 (63.4%) | 44 (64.7%) | 33 (52.4%) | 7 (41.2%) | 10 (71.4%) | 97 (59.9%) | 88 (59.5%)
Abnormal - Not clinically significant | 8 (10.4%) | 14 (19.7%) | 3 (4.4%) | 11 (17.5%) | 2 (11.8%) | 0 | 13 (8.0%) | 25 (16.9%)
Abnormal - Clinically significant | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Table 14.3.11 Summary of Riker Score by Age Stratum and Treatment Group Safety Population

| 3 mo – <3 yrs | | 3 yrs – <13 yrs | | ≥13 yrs | | Total
| Diazepam (N=77) | Lorazepam (N=71) | Diazepam (N=68) | Lorazepam (N=63) | Diazepam (N=17) | Lorazepam (N=14) | Diazepam (N=162) | Lorazepam (N=148)
Baseline Visit
Riker 1 & 2 (very sedated) | 74 (96.1%) | 67 (94.4%) | 66 (97.1%) | 62 (98.4%) | 17 (100.0%) | 13 (92.9%) | 157 (96.9%) | 142 (95.9%)
Riker 3, 4 & 5 | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
Riker 6 & 7 (very agitated) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
30 Minute Visit
Riker 1 & 2 (very sedated) | 33 (42.9%) | 41 (57.7%) | 30 (44.1%) | 44 (69.8%) | 7 (41.2%) | 5 (35.7%) | 70 (43.2%) | 90 (60.8%)
Riker 3, 4 & 5 | 37 (48.1%) | 18 (25.4%) | 27 (39.7%) | 13 (20.6%) | 9 (52.9%) | 6 (42.9%) | 73 (45.1%) | 37 (25.0%)
Riker 6 & 7 (very agitated) | 1 (1.3%) | 1 (1.4%) | 0 | 0 | 0 | 0 | 1 (0.6%) | 1 (0.7%)
1 Hour Visit
Riker 1 & 2 (very sedated) | 25 (32.5%) | 35 (49.3%) | 31 (45.6%) | 37 (58.7%) | 7 (41.2%) | 4 (28.6%) | 63 (38.9%) | 76 (51.4%)
Riker 3, 4 & 5 | 47 (61.0%) | 31 (43.7%) | 32 (47.1%) | 23 (36.5%) | 7 (41.2%) | 9 (64.3%) | 86 (53.1%) | 63 (42.6%)
Riker 6 & 7 (very agitated) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
2 Hour Visit
Riker 1 & 2 (very sedated) | 16 (20.8%) | 36 (50.7%) | 23 (33.8%) | 28 (44.4%) | 5 (29.4%) | 4 (28.6%) | 44 (27.2%) | 68 (45.9%)
Riker 3, 4 & 5 | 48 (62.3%) | 27 (38.0%) | 30 (44.1%) | 29 (46.0%) | 7 (41.2%) | 7 (50.0%) | 85 (52.5%) | 63 (42.6%)
Riker 6 & 7 (very agitated) | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
3 Hour Visit
Riker 1 & 2 (very sedated) | 13 (16.9%) | 28 (39.4%) | 22 (32.4%) | 17 (27.0%) | 4 (23.5%) | 1 (7.1%) | 39 (24.1%) | 46 (31.1%)
Riker 3, 4 & 5 | 38 (49.4%) | 33 (46.5%) | 26 (38.2%) | 35 (55.6%) | 9 (52.9%) | 10 (71.4%) | 73 (45.1%) | 78 (52.7%)
Riker 6 & 7 (very agitated) | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0
4 Hour Visit
Riker 1 & 2 (very sedated) | 13 (16.9%) | 25 (35.2%) | 18 (26.5%) | 15 (23.8%) | 3 (17.6%) | 2 (14.3%) | 34 (21.0%) | 42 (28.4%)
Riker 3, 4 & 5 | 32 (41.6%) | 32 (45.1%) | 24 (35.3%) | 34 (54.0%) | 10 (58.8%) | 9 (64.3%) | 66 (40.7%) | 75 (50.7%)
Riker 6 & 7 (very agitated) | 1 (1.3%) | 0 | 1 (1.5%) | 0 | 0 | 0 | 2 (1.2%) | 0
Change from Baseline to 4 Hour Visit
Change 0 | 8 (10.4%) | 5 (7.0%) | 7 (10.3%) | 6 (9.5%) | 1 (5.9%) | 1 (7.1%) | 16 (9.9%) | 12 (8.1%)
Change +1 | 5 (6.5%) | 20 (28.2%) | 11 (16.2%) | 8 (12.7%) | 2 (11.8%) | 1 (7.1%) | 18 (11.1%) | 29 (19.6%)
Change +2 | 6 (7.8%) | 17 (23.9%) | 6 (8.8%) | 17 (27.0%) | 3 (17.6%) | 7 (50.0%) | 15 (9.3%) | 41 (27.7%)
Change +3 | 23 (29.9%) | 13 (18.3%) | 17 (25.0%) | 15 (23.8%) | 6 (35.3%) | 2 (14.3%) | 46 (28.4%) | 30 (20.3%)
Change +4 | 3 (3.9%) | 0 | 0 | 2 (3.2%) | 1 (5.9%) | 0 | 4 (2.5%) | 2 (1.4%)
Change +5 | 1 (1.3%) | 0 | 0 | 0 | 0 | 0 | 1 (0.6%) | 0
Change +6 | 0 | 0 | 1 (1.5%) | 0 | 0 | 0 | 1 (0.6%) | 0

Note: The percentages are based on the total number of randomizations in each treatment group with assessment.

N= Number of Randomizations.

Figure 14.2.1 Time to Cessation of Initial Convulsion by Treatment Group MITT population

Figure 14.2.1.S Time to Cessation of Initial Convulsion by Treatment Group ITT population

Figure 14.2.2 Time to New Seizure Activity by Treatment Group MITT population

Figure 14.2.2.S Time to New Seizure Activity by Treatment Group ITT population

Figure 14.2.3 Time to Return to Baseline Functioning/Mental Status by Treatment Group MITT population

Figure 14.2.3.S Time to Return to Baseline Functioning/Mental Status by Treatment Group ITT population

Figure 14.4.2 Primary Safety Endpoint All Randomizations

Figure 14.4.3.1

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Clinical Laboratory Evaluations Hematology Panel White Blood Count (×10^3^/cumm)

Clinical Laboratory Evaluations Hematology Panel Red Blood Count (×10^3^/cumm)

Clinical Laboratory Evaluations Hematology Panel Hemoglobin (g/dL)

Clinical Laboratory Evaluations Hematology Panel Hematocrit (%)

Clinical Laboratory Evaluations Hematology Panel Platelet Count (×103cumm)

Clinical Laboratory Evaluations Hematology Panel Neutrophils (%)

Clinical Laboratory Evaluations Hematology Panel Lymphocytes (%)

Clinical Laboratory Evaluations Hematology Panel Monocytes (%)

Clinical Laboratory Evaluations Hematology Panel Eosinophils (%)

Clinical Laboratory Evaluations Hematology Panel Basophils (%)

Figure 14.4.3.2

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Clinical Laboratory Evaluations Chemistry Panel Glucose (mg/dL)

Clinical Laboratory Evaluations Chemistry Panel GGT (U/L)

Clinical Laboratory Evaluations Chemistry Panel Sodium (mEq/L)

Clinical Laboratory Evaluations Chemistry Panel Potassium (mEq/L)

Clinical Laboratory Evaluations Chemistry Panel Chloride (mEq/L)

Clinical Laboratory Evaluations Chemistry Panel Carbon Dioxide (mEq/L)

Clinical Laboratory Evaluations Chemistry Panel BUN (mg/dL)

Clinical Laboratory Evaluations Chemistry Panel Creatinine (mg/dL)

Clinical Laboratory Evaluations Chemistry Panel Calcium (mg/dL)

Clinical Laboratory Evaluations Chemistry Panel ALT (U/L)

Clinical Laboratory Evaluations Chemistry Panel AST (U/L)