# 5 ETHICS

## 5.1 Institutional Review Board (IRB)

Institutional Review Board (IRB) approval of the protocol, informed consent, and participant information and/or advertising as relevant was obtained prior to the authorization of study medication shipment to a study site. All amendments to the protocol received IRB approval prior to implementation of any changes made to the study design. Detailed IRB information is provided in Appendix 16.1.3.

## 5.2 Ethical Conduct of the Study

This study was conducted in accordance with the ethical principles originating from the Declaration of Helsinki and current Good Clinical Practices (GCP) and in compliance with local regulatory requirements, 21CFR 312, 21CFR 56 and 21CFR 50 including part 50.24 (Exception from Informed Consent for Emergency Research).

## 5.3 Participant Information, Consent, and Assent

Most participants in this study were minors (under the age of 17 years); three participants were inadvertently enrolled who were older than 18 years of age because the participant age was unknown at the time of enrollment. The data from these participants were used for both safety and efficacy analysis. Participants were enrolled under two different cohorts: cohort 1 and cohort 2. Cohort 1 included participants who were pre-consented; informed consent was obtained from the legally authorized representative (LAR) before they presented to the emergency department (ED) in status epilepticus (SE). Cohort 2 included participants who appeared in the ED with SE and qualified for the study but had not given prior consent. The informed consent process of cohorts 1 and 2 are detailed in Section 9.3.

In brief, for Cohort 1, the investigator or designated representative explained the nature of the study to the participant and the participant’s parents or legal guardian, to the extent compatible with the participant’s understanding, and answered all questions regarding this study. Prior to any study related screening procedures performed on the participant, the informed consent (parental permission) statement was signed and dated by the participant’s parent or legal guardian and by the person who administered the informed consent. The participant gave assent when appropriate. A copy of the informed consent form (ICF) and assent (when applicable) was given to the participant’s parents or legal guardian, and the original was placed in the participant’s medical record. An entry was made in the participant’s source documents to confirm that informed consent was obtained prior to any study-related procedures and that the participant, or the participant’s parents or legal guardian, received a signed copy.

For Cohort 2, the participants were enrolled under the Exception from Informed Consent (EFIC) regulations. If an ED clinician determined that it was appropriate to approach the parent/guardian, the ED clinician informed the parent/guardian that a research study is ongoing in the ED and their child may automatically be enrolled in the study. This allowed the parent/guardian to object to participation or ask additional questions. The child was enrolled (dosed) with study medication under the EFIC. Once the child was stabilized, a research staff member approached the parent or LAR to obtain informed consent to continue the child’s participation in the study. If a parent or LAR refused continued participation, no further study procedures were performed beyond four hours. A copy of the informed consent document was given to the parent or LAR even though he/she did not consent for the study. Safety data were collected up to four hours in accordance with federal regulations.

In addition, the Health Insurance Portability and Accountability Act (HIPAA) authorization was reviewed, signed, and dated by the participant’s parent or legal guardian. A sample ICF is provided in Appendix 16.1.3. Some sites used Spanish translation and some used Russian as well as Spanish translations of the ICF. All translated ICF documents were approved by the IRB.