# Descriptive Supplementary Documents

- Study Protocol
- Manual of Operations
- Project Summaries
- Data Collection Instruments
- Codebook/Variable Dictionary
- Data Analysis Plan
- De-Identification Methodology
- List of Publications
- Status 2 IRBs and Sample ICFs Redacted
- Status 2 PK Report