# 16 APPENDICES

16.1 Study Information
  16.1.1 Protocol and Protocol Amendments
  16.1.2 Sample Case Report Form
  16.1.3 Institutional Review Boards (IRBs) and Participant Consents and Information
    16.1.3.1 Names and Addresses of IRBs
    16.1.3.2 Sample Informed Consent Forms
  16.1.4 Description of Investigators
    16.1.4.1 Investigators and Locations
    16.1.4.2 CVs of Principal Investigator
  16.1.5 Signature Page
  16.1.6 Listing of Batch Numbers by Participant
  16.1.7 Randomization Scheme and Codes
  16.1.8 Audit Certificates (if available)
  16.1.9 Statistical Analysis Plan
  16.1.10 Documentation of Inter-laboratory Standardization Methods and Quality Assurance Procedures, if Used
  16.1.11 Publications Based on the Study
  16.1.12 Important Publications Referenced in the Report
  16.1.13 Written Request - Lorazepam
16.2 Participant Data Listings
16.3 Case Report Forms for Participants with SAEs
16.4 Miscellaneous
  16.4.1 Interim Analysis Reports
    16.4.1.1 Interim analysis to potentially modify sample size as per protocol
    16.4.1.2 Revised Interim Analysis
    16.4.1.3 Considerations for Continuing Approval
    16.4.1.4 Interim safety analysis.
    16.4.1.5 Interim safety analysis.
  16.4.2 PK Analysis
    16.4.2.1 PK Report
    16.4.2.2 Tables
    16.4.2.3 Figures (Including Individual Response Plots)
    16.4.2.4 Listings
    16.4.2.5 PK Datasets in ‘XPT’ format
    16.4.2.6 Define.pdf File
    16.4.2.7 If NONMEM was used, Model codes/ control streams and output listings (ASCII) text Files
16.5 Datasets and Define.pdf

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/18573