# 4 GLOSSARY OF ABBREVIATIONS AND TERMS

AE: Adverse event
ACE: Adverse clinical event
AEC: Administrative Executive Committee
AED: Antiepileptic Drug
ALT: Alanine aminotransferase
ASA: American Society of Anesthesiologists
AST: Aspartate aminotransferase
ATC: Anatomic Therapeutic Code
AUC: Area under the plasma concentration drug versus time curve
BMI: Body Mass Index
BPCA: Best Pharmaceuticals for Children Act
BPCA-CC: Best Pharmaceuticals for Children Act Coordinating Center
BPCA DCC: Best Pharmaceuticals for Children Act Data Coordinating Center
BPM: Beats per minute
BRPM: Breaths per minute
BSA: Body surface area
BUN: Blood urea nitrogen
BVM: Bag valve mask
CAPA: Corrective and Preventive Actions
CFR: Code of Federal Regulations
CI: Confidence internal
CL: Clearance
C_max_: Maximum concentration
CNCAE: Critical and near critical adverse event
▬: ▬
CNS: Central nervous system
CRC: Clinical Research Center
CRF: Case Report Form
DHHS: Department of Health and Human Services
DMC: Data Monitoring Committee
ECG: Electrocardiogram
ECRF: Electronic case report form
ED: Emergency department
EEG: Electroencephalogram
EFIC: Exception from Informed Consent
ER: Emergency room
EMS: Emergency medical services
FDA: Food and Drug Administration
GABA: Gamma-aminobutyric acid
GCP: Good Clinical Practice
GGT: Gamma-glutamyl-transferase
HCG: Human chorionic gonadotropin
HCO_3_: Bicarbonate ion
HIPAA: Health Insurance Portability and Accountability Act
Hr: Hour
ICF: Informed consent form
ICH: International Committee on Harmonization
IRB: Institutional Review Board
ITT: Intent-to-treat
IV: Intravenous
Kg: Kilogram
L: Liter
LAR: Legally Authorized Representative
LFT: Liver function test
LIP: Licensed Independent Practitioner
MAP: Mean arterial pressure
MedDRA: Medical Dictionary for Regulatory Activities
Mg: Milligram
Min: Minute
MITT: Modified intent-to-treat
ML: Milliliter
MOF: Minimum objective function
N: Number
NC: Non compartmental
Ng: Nanogram
NICHD: Eunice Kennedy Shriver National Institute of Child Health and Human Development
NIH: National Institutes of Health
NONMEM: Nonlinear mixed effect modeling
PECARN: Pediatric Emergency Care Applied Research Network
PK: Pharmacokinetic
PODS: Pediatric Off-Patent Drug Study
PP: Per Protocol
QC: Quality Control
RCT: Randomized control trial
SAE: Serious adverse event
SAP: Statistical analysis plan
SAS: Statistical analysis software
SASS: Sedation-Agitation Scale Score
SD: Standard deviation
SE: Status epilepticus
SOC: System Organ Class
SOP: Standard Operating Procedures
TEAE: Treatment emergent adverse event
UGT: Bilirubin-UDP-glucuronosyltransferase
ULN: Upper limit of normal
US: United States
USP: United States Pharmacopeia
T_1/2_: Terminal half life
TEAE: Treatment-emergent adverse event
Vdss: Volume of distribution at steady state
VPA: Valproic Acid
WHO: World Health Organization
WR: Written Request
λ_z_: Elimination rate constant