# 4 GLOSSARY OF ABBREVIATIONS AND TERMS

AE: Adverse Event
ALT: Alanine Aminotransferase
ANOVA: Analysis of Variance
AST: Aspartate Aminotransferase
ATC: Anatomical Therapeutic Chemical
AUC: Area Under the Curve
BP: Blood Pressure
BPCA DCC: Best Pharmaceuticals for Children Act Data Coordinating Center
BPM: Beats Per Minute
BUN: Blood Urea Nitrogen
CBC: Complete Blood Count
cGMP: Cyclic Guanosine Monophosphate
CN^-^: Cyanide
CRA: Clinical Research Associate
CRF: Case Report Form
d/c: Discontinuation
DCRI: Duke Clinical Research Institute
DBP: Diastolic Blood Pressure
DMC: Data Monitoring Committee
ECMO: Extracorporeal Membrane Oxygenation
FDA: Food and Drug Administration
g/dL: Grams per Deciliter
GCP: Good Clinical Practice
HCG: Human Chorionic Gonadotropin
HEENT: Head, Eyes, Ears, Nose, Throat
HIPAA: Health Insurance Portability and Accountability Act
hr: Hour
HR: Heart Rate
IB: Investigational Brochure
ICU: Intensive Care Unit
IEC: Independent Ethics Committee
IRB: Institutional Review Board
IVRS: Interactive Voice Response System
kg: Kilogram
MAP: Mean Arterial Pressure
mcg: Microgram
MedDRA: Medical Dictionary for Regulatory Activities
mEq/L: Milliequivalent per Liter
min: Minute
mL: Milliliter
mmHg: Millimeters of Mercury
mmol/L: Millimoles per Liter
NO: Nitric Oxide
NICHD: National Institute for Child Health and Human Development
NTG: Nitroglycerin
PD: Pharmacodynamic
PaO_2_: Arterial Partial Pressure of Oxygen
SAE: Serious Adverse Event
SBP: Systolic Blood Pressure
SCN: Thiocyanate
SNP: Sodium Nitroprusside
WHO: World Health Organization
µM: Micromoles per liter, Micromolar