# 2 SYNOPSIS

NAME OF SPONSOR/COMPANY:; NICHD
NAME OF FINISHED PRODUCT:; Sodium Nitroprusside
NAME OF ACTIVE INGREDIENT:; Sodium Nitroprusside

Title Of Study: A Phase II, Multicenter, Randomized, Double-Blind, Placebo-Controlled, Parallel Group Study to Determine the Pharmacodynamics of Sodium Nitroprusside (SNP) during Prolonged Infusion in Pediatric Subjects

Co-Principal Investigators:

Scott Schulman, MD, MHS, Duke University Medical Center, Box 3094 DUMC, Durham, NC 27705

Gregory Hammer, MD, Stanford University Medical Center, Stanford, CA 94305-5640

▬ MD, Stanford University Medical Center, Stanford, CA 94305-5640

Publication (ref.): None

Study Period:; (date of first enrollment): October 15, 2008; (date of last completed): November 18, 2010 | Phase of Development: II

Objectives:

To determine the persistence of the effect of sodium nitroprusside on blood pressure during stable infusion regimens lasting at least 12 hours

To assess the potential for rebound hypertension following administration of sodium nitroprusside for 12 hours or more

Methodology:

The study comprised of 4 phases as follows:

Pre-study drug administration: a period of up to 7 days preceding the start of study drug administration during which informed parental permission and other enrollment procedures took place.

Open-label study drug administration (Dose-Titration): The period of open label study drug administration was at least 12 hours but not greater than 24 hours, including the time of infusion of institutionally-supplied SNP, if any. This period began at the start of SNP administration, either study drug or institutionally supplied. The duration of infusion of the institutionally-supplied SNP was no longer than 8 hours. Randomization normally occurred during this period.

Blinded study drug administration: The period began with the start of blinded study drug administration and ended with the discontinuation of blinded study drug. It immediately followed the open-label period and was no longer in duration than 30 minutes.

Follow up: This period immediately followed the blinded study drug administration and ended 30 days after completion of study drug administration. AEs were followed for 24 hours after termination of study drug. SAEs were followed for 30 days.

Safety was assessed via the evaluation of adverse events, pre- and post-treatment laboratory results, and vital sign data. The efficacy endpoints were mainly assessed by examining blood pressure parameters.

NAME OF SPONSOR/COMPANY:; NICHD
NAME OF FINISHED PRODUCT:; Sodium Nitroprusside
NAME OF ACTIVE INGREDIENT:; Sodium Nitroprusside

Number of Subjects (planned and analyzed):
Planned: Approximately 60 | Analyzed: | Safety Population – 51
Planned: Approximately 60 | Analyzed: | ITT Population – 45
Planned: Approximately 60 | Analyzed: | In Primary Analysis – 39

Diagnosis and Main Criteria for Inclusion:

Inclusion Criteria: Subjects met all of the following criteria:

1. Subject was less than 17 years of age.
2. An in-dwelling arterial line was clinically indicated.
3. Subject’s parent or legal guardian was willing and able to give informed parental permission signing and dating an IRB-approved informed parental permission containing all of the elements of informed consent, and subject provides assent, signing an IRB-approved and required informed assent, if applicable.
4. Subject was anticipated to require a minimum of 20 mmHg (15 mmHg for subjects < 2 years old) reduction in MAP for at least 12 hours using SNP [e.g., MAP_B1_ - MAP_B2_ ≥ 20 mmHg (15 mmHg for subjects < 2 years old)]

Exclusion Criteria: Subjects were excluded from study if any of the following criteria existed:

1. Subject weighed < 3.0 kg.
2. Subject had a known allergy to SNP.
3. Subject had a known mitochondrial cytopathy with a disorder of oxidative phosphorylation or of respiratory chain enzymes.
4. Subject had a contraindication to vasodilator therapy for control of blood pressure during surgery or in the intensive care unit.
5. Subject had raised intracranial pressure.
6. Subject was anticipated to need anti-hypertensive drugs other than Sodium Nitroprusside either IV (e.g., dexmedetomidine, esmolol, etc.) or epidural (e.g., local anesthetics, clonidine, etc.) within three terminal half-lives (3X T½ β) of the blinded study drug period. However, subjects who were receiving stable doses of an anti-hypertensive drug(s) prior to the initiation of study drug could be enrolled.
7. Subject had any serious medical condition which, in the opinion of the investigator, was likely to interfere with study procedures.
8. Subject was moribund (death likely to occur within 48 hours).
9. Subject had a positive result for the urine or serum HCG test administered at screening.
10. Subject had participated in other clinical trials for investigational drugs within 30 days prior to enrollment.
11. Subject had received or would have received Sodium Thiosulfate within 6 hours prior to the start of the open-label period.
12. Subject was either on, or anticipated to be on, ECMO.

NAME OF SPONSOR/COMPANY:; NICHD
NAME OF FINISHED PRODUCT:; Sodium Nitroprusside
NAME OF ACTIVE INGREDIENT:; Sodium Nitroprusside

Test Product, Dose and Mode of Administration, Batch Number:

Sodium Nitroprusside – NITROPRESS® manufactured by Hospira, Inc. The lot numbers that were used in the trial were 69260DD, 62979Z7, 57748Z7 and 80555DD.

Study drug was supplied by the BPCA Data Coordinating Center to the Investigational Drug Service at each clinical center in a standard concentration of 25 mg/ml. Syringes or bags were prepared by the investigational drug pharmacy by adding 25 mg of SNP to 50 ml 5% dextrose. The pharmacist dispensed two preparations of study drug, one for the open-label study drug period and one for the blinded study drug period.

Placebo - Sterile 5% dextrose was utilized as placebo.

Duration of Treatment: Subjects were randomized to receive either placebo or sodium nitroprusside for 30 minutes following at least 12- hours but not more than 24 hours of open-label infusion of sodium nitroprusside.

CRITERIA FOR EVALUATION:

Efficacy Assessments

The efficacy of SNP was assessed through a comparison of the proportion of subjects in the treatment and control group who maintained stable MAP levels during the 30-minutes blinded phase.

Safety Assessments

Safety assessments included monitoring the tolerability of the SNP infusion and assessing physical examinations, vital signs, clinical laboratory values, concomitant medications and procedures, and adverse events throughout the study.

Drug Concentration Measurements

Cyanide, thiocyanate, methemoglobin, lactic acid, and arterial blood gas analysis were performed throughout the trial to indirectly query SNP levels and determine subject safety.

NAME OF SPONSOR/COMPANY:; NICHD
NAME OF FINISHED PRODUCT:; Sodium Nitroprusside
NAME OF ACTIVE INGREDIENT:; Sodium Nitroprusside

STATISTICAL METHODS:

The summaries for continuous variables include the following descriptive statistics: sample size (N), mean, standard deviation, median, minimum, and maximum. Categorical variables are summarized using the number (frequency) and percentage in each category. Demographic, efficacy, and safety variables are summarized by treatment group.

Efficacy and safety variables are also summarized by study phase. Results are presented by age group for the open-label phase and by treatment group for the blinded and follow-up phases. Change scores are presented when applicable in order to show the difference between baseline and post-baseline levels.

For continuous variables, differences between either treatment groups were assessed using the nonparametric Kruskal-Wallis test except in the analysis of time until treatment failure. Nonparametric signed- rank tests were used to test for changes from baseline. For categorical variables, including the assessment of treatment success used in the primary analysis, differences between treatment groups were assessed using Fisher’s exact test.

Since all hypothesis tests besides the primary safety and efficacy analysis are primarily exploratory in nature, no adjustment for multiple comparison testing will be used. A significance level of 0.05 will be used for all analyses except in the treatment group comparison discussed below.

Only the primary efficacy analysis was adjusted for a potential study center effect; conditional logistic regression was used to adjust for the center effect. A preliminary analysis of baseline and demographic variables was conducted in order to see if they show significant differences between treatment groups. Tests for treatment group differences for these baseline and demographic variables were conducted at the 0.10 significance level. Significant baseline and demographic variables would then have been used as covariates or stratification variables in the primary efficacy analysis.

All analyses were performed in SAS version 9.2.

RESULTS:

Efficacy:

The primary efficacy analysis shows that after adjusting for the effect of treatment centers, subjects treated with SNP during the 30-minute blinded period had a significantly different success rate than subjects in the control group (p-value=0.049). The secondary time-to-event analysis also showed that the two groups had a significantly different distribution of failure times (p-value=0.028).

The treatment effect was not as strong as anticipated. One possible explanation for this is the delay experienced by subjects in the control group before receiving the placebo after the start of the blinded phase. A secondary analysis was conducted to adjust for this effect. This analysis showed a marginal increase in the effect size compared to the primary analysis. However, the difference between analyses is not great and the strength of this secondary analysis is limited since several subjects in the primary analysis were not part of the secondary analysis and the times that subjects began to receive the placebo are not known for certain.

NAME OF SPONSOR/COMPANY:; NICHD
NAME OF FINISHED PRODUCT:; Sodium Nitroprusside
NAME OF ACTIVE INGREDIENT:; Sodium Nitroprusside

RESULTS:

Safety:

No subjects in either treatment group experienced an SAE during the blinded phase. Thus, the primary safety analysis showed no difference between the SNP and control groups. Additionally, the same number of enrollments (3) experienced an SAE during follow-up in each treatment group. Thus, the rates of SAEs in the two treatment groups were not found to be different in this study.

The rate of severe hypotension was low; only 1 (2%) enrollment met the protocol definition of severe hypotension. No enrollments met the protocol definition of moderate hypotension. However, 15 (29%) enrollments met the protocol definition for mild hypotension, and an additional 15 enrollments had a recorded MAP value at least 25% below the target MAP value. No enrollments in the SNP group and 3 (14%) of the 21 enrollments in the control group met the protocol criteria for having rebound hypertension in the blinded phase.

The rate of severe cyanide toxicity (>1.5mcg/mL), as determined by whole blood cyanide levels above, was 23% (12 of 52 enrollments in the safety population). Two (4%) additional enrollments had recorded mild cyanide toxicity. There were no new cases of mild, moderate, or severe lactic acidosis recorded after the start of study drug that had not already been recorded at baseline, and 3 (6%) of enrollments met the study criterion for having metabolic acidosis. Only one of these cases of metabolic acidosis was due to a low HCO_3_^-^ value (< 18.5 mEq/L).

The following lab assessments show some indication of strong (p-value < 0.05 for at least 50% of summarized time points) changes from baseline to post-baseline levels as measured in either change scores or shifts between abnormal and normal classifications: WBC, HGB, HCT, platelet count, sodium, ALT, ABG pH, ABG PO_2_, ABG HCO_3_, whole blood cyanide, and thiocyanate (urine and plasma). As summarized in Section 12.4, not all shifts in laboratory measurements differed significantly between treatment groups; creatinine had a change score distribution that differed strongly (p-value < 0.05) between treatment groups. The percentage of declines in classification from normal to abnormal for VBG PO_2_ and ABG SO_2_ differed strongly between treatment groups.

After adjusting for baseline levels, dose response models do not show a meaningful relationship between the AUC of administered SNP after 8 hours of open-label drug infusion and either lactate or HCO_3_^-^. A stronger relationship was found between the 8-hour AUC of dose and whole blood cyanide levels. No enrollments with 8-hour AUC values below an average of 3mcg/kg/min had detectable cyanide levels, while higher AUC values were associated with higher observed cyanide levels. As discussed in Section 12.3.3.3, enrollments with observed severe cyanide toxicity showed slightly elevated rates of AEs and SAEs.

Vital signs (mean and median pulse rates and systolic and diastolic blood pressure) show stability throughout the first 12 hours of open-label drug administration. Enrollments in the SNP group show consistently lower pulse rates and blood pressure than do enrollments in the control group after the first few minutes of the blinded phase, although the difference between treatment groups at the follow-up measurements taken at 8 and 24 hours after the blinded phase is not consistent.

NAME OF SPONSOR/COMPANY:; NICHD
NAME OF FINISHED PRODUCT:; Sodium Nitroprusside
NAME OF ACTIVE INGREDIENT:; Sodium Nitroprusside

CONCLUSIONS:

Based on the efficacy data of this study, subjects with continued stable dosing of SNP during the 30-minute blinded phase showed a significant difference in maintaining MAP control from subjects who withdrew to the placebo. Also, more subjects on the placebo during the blinded phase experienced rebound hypertension during the blinded phase. SAE rates during the study were low. The possible occurrence of cyanide toxicity is a concern associated with long-term SNP administration. Although the percentage of enrollments with cyanide levels >1.5 mcg/mL was 23% and higher 8-hour SNP levels were associated with higher cyanide levels, subjects in this study experienced few clinical effects commonly associated with cyanide toxicity. In particular, observed rates of lactic and metabolic acidosis were low. We conclude that SNP is efficacious during infusions of ≥ 12 hours and that the drug appears to be safe within the dosing range studied.