# 13 CONCLUSIONS

## 13.1 Discussion

This was a phase II, multicenter, randomized, double-blind placebo-controlled, parallel group study to determine the persistence of the effect of SNP on blood pressure and to assess the potential for rebound hypertension associated with prolonged infusion in pediatric subjects. Specifically, the main efficacy goals were to determine the persistence of SNP versus placebo for maintaining reduced MAP in pediatric subjects and compare the proportion of subjects randomized to receive either SNP or placebo who experienced offset or rebound hypertension during the blinded study drug period. Additional goals for the study were to determine the safety of SNP for controlling blood pressure during stable infusion lasting at least 12 hours and to compare the proportion of subjects randomized to receive either SNP or placebo that experienced SAEs during the blinded study drug of follow-up periods. Main safety endpoints for the study were whole blood cyanide levels and the occurrence of SAEs, hypotension, and metabolic or lactic acidosis.

The following results describe the effect of SNP on maintaining reduced MAP in a 30-minute blinded period of stable infusion following 12 hours of open-label infusion:

- Compared to subjects in the control group, subjects in the ITT population treated with SNP during the 30-minute blinded phase had a higher rate of success in maintaining low MAP levels during blinded drug infusion (55% to 21%). The success rates were significant both before (p-value=0.048) and after (p-value=0.049) adjusting for the effect of treatment center. These results support that the effect of SNP on lowering blood pressure is persistent during stable infusion regimens lasting at least 12 hours (Objective 1).
- Subjects treated with SNP during the blinded phase tended to have longer times until experiencing failure than did subjects in the control group. For example, 67% of subjects in the control group and only 25% of subjects in the SNP group experienced failure by 10 minutes after the start of blinded infusion. The p-value for the difference in the distribution of failure times between the two treatment groups is 0.028.
- No subjects in the SNP group during the blinded phase experienced mild rebound hypertension (an increase > 10% in MAP levels from MAP_B1_), while 14% (3 of 21) of enrollments in the control group experienced mild rebound hypertension.

The following can be concluded about the safety of long-term SNP administration in pediatric patients requiring controlled reduction of blood pressure:

- No SAEs were recorded during the blinded phase. Three out of 25 (12%) enrollments in the SNP treatment group and 3 out of 21 (14%) enrollments in the control group experienced SAEs during the follow-up phase. This likely reflects that patients enrolled in this study were critically ill.
- The AE distributions were similar for enrollments in the two treatment groups. In the blinded phase, 2 (8%) enrollments in the SNP group and 1 (5%) enrollment in the control group had recorded AEs. In the follow-up phase, 10 (48%) enrollments in the control group had recorded AEs, while 7 (28%) of enrollments in the SNP group had recorded AEs.
- Across the open-label, blinded, and follow-up phases, 32 (62%) of the 52 enrollments experienced AEs and 7 (14%) experienced SAEs. One SAE (respiratory depression) was classified as being possibly related to the study drug, and 1 SAE (blood cyanide increase) was classified as being probably related; both the possibly and probably related events were experienced by the same subject.
- Vomiting (8 events experienced by 8 enrollments) and tachycardia (6 events experienced by 5 enrollments) were the most common AEs.
- One subject experienced an SAE leading to study discontinuation. This event was classified as a hemorrhage and was determined to be unrelated to the study drug. Two deaths occurred during the follow-up phase. Neither death was determined to be related to the study drug.
- During the open-label and blinded phase, 1 (2%) of the 52 enrollments in the safety population experienced severe hypotension based on the protocol definition (Table 9-2). An additional 15 (29%) enrollments experienced a MAP value of at least 25% below the target value without meeting the protocol definition of moderate or severe hypotension. Fifteen (29%) enrollments experienced only mild hypotension based on the protocol definition.
- The threshold used in this study to classify subjects as having severely high whole blood cyanide levels was 1.5mcg/mL. Twelve (23%) of subjects had whole blood cyanide levels measured above 1.5 mcg/mL after the start of open-label SNP infusion. After 8 hours of open-label infusion, no subjects with an average dose <3 mcg/kg/min had an 8-hour cyanide level that was above the limit of quantification. Based on dose response modeling of the 8-hour cyanide measurements, an average 8-hour dose >4.72 mcg/kg/min is expected to be associated with a cyanide level above 1.5 mcg/mL.
- There were no new cases of lactic acidosis after the start of the study. Three (6%) enrollments were classified as having metabolic acidosis based on the definition presented in Section 9.7.1.3.3.3.

## 13.2 Overall Conclusions

Based on the efficacy data of this study, subjects with continued stable dosing of SNP during the 30-minute blinded phase showed a significant difference in maintaining MAP control from subjects who withdrew to the placebo. Also, more subjects on the placebo during the blinded phase experienced rebound hypertension during the blinded phase. SAE rates during the study were low. The possible occurrence of cyanide toxicity is a concern associated with long-term SNP administration. Although the percentage of enrollments with cyanide levels >1.5 mcg/mL was 23% and higher 8-hour SNP levels were associated with higher cyanide levels, subjects in this study experienced few clinical effects commonly associated with cyanide toxicity. In particular, observed rates of lactic and metabolic acidosis were low. We conclude that SNP is efficacious during infusions of ≥ 12 hours and that the drug appears to be safe within the dosing range studied.