# 12 SAFETY EVALUATION

## 12.1 Extent of Exposure

The safety population included 51 subjects who received the study drug. One subject (▬ was enrolled twice, due to which there were 52 enrollments. Safety data from all 52 enrollments were used for the safety analysis. As a result, this section will use the term ‘enrollments’ (N=52) instead of subjects (N=51).

The duration of exposure (DOE) for enrollments in either the open-label or blinded phase is summarized in Table 12-1. DOE is defined as the amount of time from the start to end of infusion. DOE in the open-label phase is summarized by whether or not the enrollment also received blinded treatment. Each subject who dropped out of the study before reaching the blinded phase, dropped out earlier than 6 hours after the start of study drug infusion.

Table 12-1 Duration of Exposure to Study Drug During Open-Label (in hours) and Blinded Phase (in minutes)

| Phase
| Open-Label | | | Blinded
| ITT Population | | | Treatment
| Yes; (N=46) | No; (N=6) | Total; (N=52) | SNP; (N=25) | Placebo; (N=21) | Total; (N=46)
N | 46 | 6 | 52 | 25 | 21 | 46
Mean (SD) | 15.8 (4.5) | 2.7 (2.1) | 14.3 (6.0) | 27.0 (7.2) | 18.8 (11.0) | 23.2 (9.9)
Median (Min, Max) | 14.7 (0.5, 23.8) | 2.5 (0.3, 5.7) | 14.1 (0.3, 23.8) | 30.0 (8.0, 30.0) | 15.0 (4.0, 39.0) | 30.0 (4.0, 39.0)

Infusion rates during open-label titration are summarized at different time points in Table 14.1.8.1. Changes in drug infusion during the open-label period are also plotted for each subject in Figure 14.1.2. Infusion rates during the blinded phase for subjects in the ITT population are summarized in Table 14.1.8.2 and discussed in Section 11.2. These summaries exclude the duplicate enrollment. When the second enrollment is included, the mean for the 25 enrollments in the SNP group is 3.0mcg/kg/min with a median of 2.5mcg/kg/min and standard deviation of 2.3mcg/kg/min. The mean and median infusion rates for the 25 enrollments in the control group are still 3.5 and 2.5mcg/kg/min, respectively. Listings of study drug amounts and times administered during each phase of the study for individual patients are provided in Section 16, Listing 16.2.9.2 for the open-label phase and Listing 16.2.9.1 for the blinded phase.

## 12.2 Adverse Events and Tolerability

Adverse event summaries are provided in Section 14.3. Adverse events reported in this section fall into three categories. The first category consists of AEs recorded in subjects who never entered the open label phase. Only adverse events experienced by enrollments in the safety population are presented. One enrollment who did not receive treatment medication has a reported AE; this event is summarized in Section 16, Listing 16.2.11.1. The second category consists of AEs recorded before the start of infusion. The third category consists of treatment-emergent adverse events that occurred for the first time or increased in severity on or after the start of study drug infusion during the open-label phase.

AEs that were non-SAEs were recorded from the time of informed consent until 24 hours following termination from study. SAEs were recorded until 30 days after the last dose of study drug.

### 12.2.1 Summary of Treatment Emergent Adverse Events

All AEs and the single SAE recorded before the start of infusion for enrollments in the safety population are summarized in Table 14.3.1.2.5. Nine (17%) of the 52 enrollments in the safety population had an AE reported before the start of SNP infusion. One pre-dose SAE with MedDRA preferred term of hemorrhage was reported for one enrollment, who was later withdrawn from the study, 17 minutes after starting open-label infusion.

The overall summary of tolerability is shown in Table 12-2. During the study following open-label infusion, 32 (62%) of the 52 enrollments in the safety population had at least 1 AE. These enrollments experienced a total of 94 reported AEs. The maximum severity of any AE was mild for 20 enrollments (39%); moderate for 6 enrollments (12%); severe for 1 enrollment (2%); life-threatening for 3 enrollments (6%); and death for 2 enrollments (4%). Both deaths occurred during the follow-up phase. The AEs most closely related to study drug were classified as possibly related for 8 enrollments (15%), probably related for 7 enrollments (14%), and definitely related for 1 enrollment (2%). No enrollments were discontinued from the study due to an AE. As shown in Table 12-2, the distributions of these measurements of tolerability across different age groups were not meaningfully different.

Table 12-2 Overall Summary of Tolerability for Enrollments in the Safety Population During the Open-label, Blinded, and Follow-up Study Phases

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Number of Events/ Enrollments
Number of Adverse Events | 6 | 40 | 15 | 18 | 15 | 94
Enrollments with at least one AE | 2 (66.7%) | 13 (61.9%) | 4 (57.1%) | 8 (66.7%) | 5 (55.6%) | 32 (61.5%)
Number of SAEs | 2 | 2 | 2 | 2 | 0 | 8
Enrollments with at least one SAE | 1 (33.3%) | 2 (9.5%) | 2 (28.6%) | 2 (16.7%) | 0 | 7 (13.5%)
Highest Severity Per Enrollment
Mild | 1 (33.3%) | 8 (38.1%) | 2 (28.6%) | 5 (41.7%) | 4 (44.4%) | 20 (38.5%)
Moderate | 0 | 3 (14.3%) | 1 (14.3%) | 1 (8.3%) | 1 (11.1%) | 6 (11.5%)
Severe | 0 | 0 | 1 (14.3%) | 0 | 0 | 1 (1.9%)
Life threatening | 1 (33.3%) | 2 (9.5%) | 0 | 0 | 0 | 3 (5.8%)
Death | 0 | 0 | 0 | 2 (16.7%) | 0 | 2 (3.8%)
Strongest Relationship Per Enrollment
Unrelated | 1 (33.3%) | 9 (42.9%) | 2 (28.6%) | 4 (33.3%) | 0 | 16 (30.8%)
Possibly related | 0 | 1 (4.8%) | 0 | 3 (25.0%) | 4 (44.4%) | 8 (15.4%)
Probably related | 1 (33.3%) | 3 (14.3%) | 2 (28.6%) | 1 (8.3%) | 0 | 7 (13.5%)
Definitely related | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 (1.9%)

1 TS: Tanner Stage

Summary of AEs that occurred during the open-label phase is shown in Table 12-3. During open-label infusion, 26 (50%) of the 52 enrollments in the safety population had at least 1 AE. These enrollments experienced a total of 53 reported AEs in the open-label phase. The maximum severity of any AE was mild for 18 enrollments (35%); moderate for 6 enrollments (12%); severe for 1 enrollment (2%); and life-threatening for 1 enrollment (2%). The AEs most closely related to study drug were classified as possibly related for 8 enrollments (15%) and probably related for 5 enrollments (10%). As shown in Table 12-3, the distributions of these measurements of tolerability across different age groups were not meaningfully different.

Table 12-3 Overall Summary of Tolerability for Enrollments in the Safety Population During the Open-label Phase

| Age Strata | | | | | Total; (N=51)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=51)
Number of Events/ Enrollments
Number of Adverse Events | 3 | 19 | 8 | 11 | 12 | 53
Enrollments with at least one AE | 2 (66.7%) | 10 (47.6%) | 3 (42.9%) | 6 (50.0%) | 5 (55.6%) | 26 (50.0%)
Number of SAEs | 1 | 1 | 0 | 0 | 0 | 2
Enrollments with at least one SAE | 1 (33.3%) | 1 (4.8%) | 0 | 0 | 0 | 2 (3.8%)
Highest Severity Per Enrollment
Mild | 1 (33.3%) | 6 (28.6%) | 1 (14.3%) | 5 (41.7%) | 5 (55.6%) | 18 (34.6%)
Moderate | 0 | 3 (14.3%) | 2 (28.6%) | 1 (8.3%) | 0 | 6 (11.5%)
Severe | 1 (33.3%) | 0 | 0 | 0 | 0 | 1 (1.9%)
Life threatening | 0 | 1 (4.8%) | 0 | 0 | 0 | 1 (1.9%)
Strongest Relationship Per Enrollment
Unrelated | 1 (33.3%) | 8 (38.1%) | 2 (28.6%) | 2 (16.7%) | 0 | 13 (25.0%)
Possibly related | 0 | 0 | 0 | 3 (25.0%) | 5 (55.6%) | 8 (15.4%)
Probably related | 1 (33.3%) | 2 (9.5%) | 1 (14.3%) | 1 (8.3%) | 0 | 5 (9.6%)

1 TS: Tanner Stage

The Summary of AEs that were reported during the 30-minute blinded phase by treatment group is shown in Table 12-4. During blinded drug infusion, 2 (8%) of the 25 enrollments that were randomized to receive SNP, had at least 1 reported AE. Only 1 (5%) of the 21 enrollments in the control group had at least 1 AE. There is no significant difference between the rates of reported AEs in the two treatment groups (p-value=1). The maximum number of AEs recorded in the blinded phase per enrollment is one. No SAEs were reported; the greatest severity of any event was mild. One possibly related event was experienced by an enrollment in the SNP group. An enrollment in the control group experienced the only probably related AE. Table 14.3.1.2.3 summarizes blinded phase AEs by age group; the low number of AEs prevents detection of any meaningful difference between age groups.

Table 12-4 Overall Summary of Tolerability for Enrollments in the ITT Population During the Blinded Phase

| Treatment | | Total; (N=46) | P Value^1^
| SNP; (N=25) | Placebo; (N=21) | Total; (N=46) | P Value^1^
Number of Events/ Enrollments
Number of Adverse Events | 2 | 1 | 3
Enrollments with at least one AE | 2 (8.0%) | 1 (4.8%) | 3 (6.5%) | 1.000
Number of SAEs | 0 | 0 | 0
Highest Severity Per Enrollment
Mild | 2 (8.0%) | 1 (4.8%) | 3 (6.5%)
Strongest Relationship Per Enrollment
Unrelated | 1 (4.0%) | 0 | 1 (2.2%)
Possibly related | 1 (4.0%) | 0 | 1 (2.2%)
Probably related | 0 | 1 (4.8%) | 1 (2.2%)

1 P-value for treatment group difference calculated using Fisher’s exact test.

Summary of AEs that occurred during the 30-day follow-up phase by age group is shown in Table 12-5. During the follow-up phase, 19 (37%) of the 52 enrollments in the safety population had at least 1 AE. Those 19 enrollments experienced a total of 38 reported AEs. The maximum severity of any AE was mild for 12 (23%) enrollments; moderate for 2 (4%) enrollments; severe for 1 enrollment (2%); and life-threatening for 2 enrollments (4%). There were 2 (4%) deaths during follow up. Two (4%) AEs were possibly related to study drug; 2 (4%) were probably related, and 1 (2%) definitely related for enrollment. As shown in Table 12-5, these measurements of tolerability did not differ meaningfully across the 5 age groups, although only 1 (11%) of the 9 enrollments in the oldest age group experienced an AE during follow-up, which was 22% lower than the next lowest AE rate in the youngest age group.

Table 12-5 Overall Summary of Tolerability for Enrollments in the Safety Population During Follow-up

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Number of Events/ Enrollments
Number of Adverse Events | 3 | 20 | 6 | 7 | 2 | 38
Enrollments with at least one AE | 1 (33.3%) | 8 (38.1%) | 4 (57.1%) | 5 (41.7%) | 1 (11.1%) | 19 (36.5%)
Number of SAEs | 1 | 1 | 2 | 2 | 0 | 6
Enrollments with at least one SAE | 1 (33.3%) | 1 (4.8%) | 2 (28.6%) | 2 (16.7%) | 0 | 6 (11.5%)
Highest Severity Per Enrollment
Mild | 0 | 7 (33.3%) | 2 (28.6%) | 3 (25.0%) | 0 | 12 (23.1%)
Moderate | 0 | 0 | 1 (14.3%) | 0 | 1 (11.1%) | 2 (3.8%)
Severe | 0 | 0 | 1 (14.3%) | 0 | 0 | 1 (1.9%)
Life threatening | 1 (33.3%) | 1 (4.8%) | 0 | 0 | 0 | 2 (3.8%)
Death | 0 | 0 | 0 | 2 (16.7%) | 0 | 2 (3.8%)
Strongest Relationship Per Enrollment
Unrelated | 0 | 6 (28.6%) | 3 (42.9%) | 5 (41.7%) | 0 | 14 (26.9%)
Possibly related | 1 (33.3%) | 1 (4.8%) | 0 | 0 | 0 | 2 (3.8%)
Probably related | 0 | 1 (4.8%) | 1 (14.3%) | 0 | 0 | 2 (3.8%)
Definitely related | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 (1.9%)

1 TS: Tanner Stage

A comparison between the distributions of AEs reported during the follow-up phase between the two treatment groups is presented in Table 14.3.1.1.4. A higher percentage of enrollments in the control group (48%; 10 of the 21 enrollments in the ITT population who received blinded placebo) than in the SNP group (28%; 7 of the 25 enrollments in the ITT population who received blinded SNP) had a reported AE during the follow-up phase; this difference is not statistically significant (p-value=0.38).

### 12.2.2 Display of Adverse Events and Critical or Near Critical Incidents

AEs and SAEs are presented in the following tables:

- Overall summary of tolerability by age stratum is summarized in Section 14, Table 14.3.1.2.1.
- Summary of AEs, SAEs, and critical or near critical incidents by age stratum during the open-label phase is summarized in Section 14, Table 14.3.1.2.2.
- Summary of AEs, SAEs, and critical or near critical incidents by age stratum during the blinded phase is summarized in Section 14, Table 14.3.1.2.3.
- Summary of AEs, SAEs, and critical or near critical incidents by age stratum during follow-up is summarized in Section 14, Table 14.3.1.2.4.
- A comparison of AEs, SAEs, and critical or near critical incidents experienced during the open-label phase between enrollments who did and did not receive blinded treatment is summarized in Section 14, Table 14.3.1.1.2.
- Treatment group comparison of AEs, SAEs, and critical or near critical incidents across the open-label, blinded, and follow-up phases are summarized in Section 14, Table 14.3.1.1.1.
- Treatment group comparison of AEs, SAEs, and critical or near critical incidents during the blinded and follow-up phases are summarized in Section 14, Tables 14.3.1.1.3 and 14.3.1.1.4, respectively.
- Summary of AEs by relationship to the study drug across the open-label, blinded, and follow-up phases given in Section 14, Table 14.3.1.3.
- Summary of AEs by system organ class, preferred term, and age classification across the open-label, blinded, and follow-up phases given in Section 14, Table 14.3.1.4.
- Summary of most common AEs by age classification across the open-label, blinded, and follow-up phases given in Section 14, Table 14.3.1.5.
- Summary of SAEs by system organ class, preferred term, and age classification across the open-label, blinded, and follow-up phases given in Section 14, Table 14.3.1.6.1.
- Summary of AEs, SAEs, and critical or near critical incidents for enrollments with severe cyanide toxicity by age stratum across the open-label, blinded, and follow-up phases given in Section 14, Table 14.3.1.8.1.
- Comparison of the distribution of AEs, SAEs, and critical or near critical incidents for enrollments with and without severely high cyanide levels across the open-label, blinded, and follow-up phases given in Section 14, Table 14.3.1.8.2.
- Narratives for Death and Other Serious Adverse Events are presented in Section 14.5.

Individual patient data associated with AEs are listed in Section 16 as follows:

- All AEs (Listing 16.2.11.1),
- All SAEs (Listing 16.2.11.2),
- SAEs leading to study drug withdrawal (Listing 16.2.11.3).

### 12.2.3 Analysis of Adverse Events and Critical or Near Critical Incidents

#### 12.2.3.1 Most Frequently Reported Adverse Events

The most frequently reported AEs in order of the frequency in which they were reported are listed in Table 14.3.1.5. Each event that occurred in at least 3 enrollments (approximately 5% of the 52 enrollments the safety population) is listed in this table. The two most common events were vomiting (8 events experienced by 8 enrollments; 15%) and tachycardia (6 events experienced by 5 enrollments; 10%). The most common events by age group were tachycardia (4 events experienced by 3 of the 9 enrollments; 33%) in the Tanner Stage III age group and vomiting in the 6 years old to Tanner Stage II group (4 of 12 enrollments; 33%). None of the AE preferred terms were experienced more than once in the 2 to 6 year old age group. AEs from six categories were each experienced by 2 (10%) enrollments in the 30 days to 2 years old age group; these events were an increase in blood cyanide, pneumothorax, an increase in blood lactic acid, a decrease in blood potassium, a decrease in calcium ionized, and hypertension. In the group of enrollments younger than 30 days old, no event was experienced by more than 1 (33%) of the 3 enrollments in this group. Tachycardia and an increase in blood cyanide were both experienced by the same enrollment in the youngest age group.

#### 12.2.3.2 Adverse Events by Intensity

As reported in Tables 14.3.1.2.1 and 12-2, the worst severity of AE experienced by 20 (39%) enrollments was mild, moderate for 6 (12%) enrollments, severe for 1 (2%) enrollments, and life-threatening for 3 (6%) enrollments. There were also 2 deaths; these are discussed in Section 12.3.1. In addition, 8 SAEs were experienced by 7 enrollments in the safety population; these are discussed in more detail in Section 12.3.2.

#### 12.2.3.3 Adverse Events by Relationship

One (2%) subject had one AE that was definitely related to the study drug, 7 enrollments (14%) had AEs that were probably related, and 8 (16%) had AEs that were possibly related. Eight of the AEs were probably related and 20 were possibly related to the study drug. Sixty-four AEs were unrelated.

### 12.2.4 Listing of Adverse Events by Subject

A complete listing of all AEs for all subjects enrolled in the study is provided in Section 16, Listing 16.2.11.1.

## 12.3 Deaths, Other Serious Adverse Events, and Adverse Events of Special Interest

### 12.3.1 Deaths

There were 2 deaths in the safety population; see Section 16, Listing 16.2.11.2 and Table 12-6. Neither of the deaths was considered to be related to the study medication, and both occurred during follow-up in the same age group.

Table 12-6 SAE and Demographic Summary for Subjects Who Died

Subject | SAE Event Date | SAE Event Description | Blinded Treatment Drug | End Date of Blinded Phase | Age Group
12-2-21 | 11/25/09 | Sepsis resulting in death | SNP | 11/01/09 | 6 years-Tanner ST II
12-2-22 | 12/04/09 | Respiratory Failure | Placebo | 12/02/09 | 6 years-Tanner ST II

### 12.3.2 Serious Adverse Events

#### 12.3.2.1 Overall SAE Summary

As reported in Table 14.3.1.2.1, there were 8 SAEs experienced by 7 (14%) enrollments during open-label, blinded, and follow-up phases. Subjects in the Tanner Stage III group did not experience any SAEs. None of the age groups experienced more than two SAEs. One SAE was classified as being of moderate severity. Six (75%) of the 8 SAEs were unrelated to the study drug. One SAE was classified as being possibly related to the study drug; this was a respiratory depression event that occurred during follow-up. One SAE was classified as being probably related to the study drug; this was an instance of high cyanide levels that occurred during the open-label phase. Both SAEs were experienced by the same subject during the subject’s first enrollment.

Also, one SAE led to study drug discontinuation. The preferred term for this SAE was a hemorrhage event. However, the event was reported before the start of study drug infusion. Further details for this event are given in Listing 16.2.11.3.

#### 12.3.2.2 Primary Safety Analysis Summary: Comparison of SAEs Experienced by Members of the Two Blinded Treatment Groups

The primary safety analysis is based on a comparison between the two treatment groups for the proportion of enrollments who experience SAEs during the blinded phase. However, no SAEs were recorded for any subjects in either group during the blinded phase.

Since SAEs associated with drug administered during the blinded phase may not be observable until after this 30-minute phase is over, a secondary analysis was performed in order to test for the equivalence in SAEs recorded by the two treatment groups during the follow-up phase. During the follow-up phase, SAEs were recorded for three enrollments in each treatment group; the percentages of enrollments experiencing SAEs were almost identical in the two groups (12% of the 25 enrollments in the SNP group and 14% of the 21 enrollments in the control group), and the p-value for Fisher’s exact test is 1.

The data provides no evidence that infusion of SNP during the 30-minute blinded phase is associated with a different rate of SAE occurrence than infusion of placebo.

### 12.3.3 Adverse Events of Special Interest

#### 12.3.3.1 Rebound Hypertension and Hypotension

The number of enrollments in the safety population with hypotension during either open-label or blinded treatment administration is presented in Table 14.3.1.7.1. Thirty-one (60%) of the 52 enrollments in the safety population had a MAP value of at least 20% below the target MAP value. Fifteen (28%) enrollments experienced mild hypotension (20-25% below target MAP), no enrollments experienced moderate hypotension (25-30% below target MAP) and one enrollment (2%) experienced severe hypotension (>30% below target MAP). Each age group had between two to four enrollments that experienced mild hypotension. An additional 15 (29%) enrollments had a MAP value that was at least 25% below the target MAP value without meeting the protocol definition of severe or moderate hypotension (Table 9-2).

One enrollment in the control group experienced mild hypotension during the blinded phase (Table 14.3.1.7.3). This measurement occurred during the first minute of blinded infusion in a subject who had already experienced hypotension during the open-label phase.

The number of enrollments that experienced rebound hypertension during the blinded and follow-up phases for each blinded treatment group is presented in Table 14.3.1.7.3. Three of the 21 (14%) enrollments in the control group experienced mild rebound hypertension; none of the 25 enrollments who received blinded SNP experienced rebound hypertension.

#### 12.3.3.2 Clinical Laboratory Findings of Interest

Variables that have been hypothesized to be associated with elevated odds of cyanide toxicity following SNP administration along with the thresholds used to determine toxicity is shown in Table 9-2. Tables 14.3.1.7.1 through 14.3.1.7.3 include a summary of the number of enrollments who experienced abnormal clinical laboratory findings for these variables.

As shown in Table 14.3.1.5, 4 (8% of the safety population) enrollments had an AE reported due to an increase in blood cyanide levels. As shown in Table 14.3.1.7.1, 12 (23%) enrollments were observed to have cyanide levels that were classified as being severely high based on the definition given in the protocol (whole blood cyanide levels > 1.5 mcg/mL), while 2 (4%) additional enrollments were observed to have mild cyanide toxicity (0.5-1 mcg/mL). Nine of the 12 (75%) instances of severely high cyanide levels had already become severe by the end of the open-label phase (Table 14.3.1.7.2). No instances of cyanide toxicity were observed in the pre-dose measurements.

Only one (2%) subject had mild lactic acidosis after study drug administration and no enrollments had more severe levels of lactic acidosis, but as discussed in Section 9.7.1.3.3, the number of enrollments with lactate levels from 2.5 - < 5 mmol/L are also be summarized since lactate levels in this lower interval may also be harmful. Thirteen (25%) enrollments had lactate levels from 2.5 to < 5 mmol/L at some point in the study. However, as shown in Table 14.3.1.7.4, 8 (15%) enrollments in the safety population had observed lactate levels from 2.5 to < 5 mmol/L, and an additional 2 (4%) enrollments already had mild lactic acidosis before the start of study drug administration. The number of enrollments that experienced a worsening of their conditions from their pre-treatment levels is presented in Table 14.3.1.7.5. Only enrollments with an increased level of toxicity or acidosis from baseline (for example, from mild to moderate) are counted in this table. The one subject with mild lactic acidosis after the start of open-label treatment already had mild lactic acidosis before the start of the study. Eight (15%) enrollments had lactate levels that increased to the 2.5 to < 5 mmol/L level after the start of the study drug; the remaining 5 enrollments with lactate measurements at this level after the start of treatment already had a baseline lactate measurement of at least 2.5 mmol/L.

Instances of metabolic acidosis are also summarized in these tables. A level of sodium bicarbonate (HCO_3_^-^) below 18.5 mEq/L (reported as below 19 mEq/L) or administration of sodium bicarbonate was termed as metabolic acidosis. However, sodium bicarbonate administration was not recorded as a concomitant medication after implementation of Amendment 2.0 of the protocol. Thus, the summaries in Tables 14.3.1.7.1 through 14.3.1.7.3 possibly underestimate the number of enrollments that have metabolic acidosis, but the reported numbers show low rates of metabolic acidosis in the safety population. Only 1 enrollment had a reported HCO_3_^-^ below 19 mEq/L after the start of study administration of SNP.

#### 12.3.3.3 Adverse Events Experienced by Enrollments with High Whole Blood Cyanide Levels

The number of AEs experienced by enrollments with high whole blood cyanide levels (> 1.5 mcg/mL) in each age group is summarized in Table 14.3.1.8.1. The frequency, severity, and relationship of AEs and SAEs experienced by enrollments either with or without severe cyanide toxicity is compared in Table 14.3.1.8.2. AEs and SAEs related to cyanide toxicity are presented in both tables.

The only age group with more than two enrollments who had high cyanide levels was the 30 day to < 2 year group. Six enrollments had high cyanide levels; however, two of the six enrollments did not have a reported AE. The highest recorded cyanide levels for these 2 enrollments were 1.7 and 3.9 mcg/mL. The one enrollment with an SAE directly related to an increase in blood cyanide was in the age group for enrollments less than 30 days old.

Four enrollments in the study had AEs reported due to an increase in blood cyanide; all 4 enrollments also had whole blood cyanide levels above 1.5 mcg/mL. The increase in blood cyanide was reported as an SAE for one of the enrollments; this enrollment also had another reported SAE. One of the 4 enrollments had no other reported AE. AEs with the preferred term that indicates an increase in blood cyanide are presented in Tables 14.3.1.8.1 and 14.3.1.8.2.

In addition to the SAE reported for an increase in blood cyanide, 3 additional SAEs were reported for subjects with high cyanide levels. These events were intracranial hypotension, respiratory depression, and respiratory failure. A single subject with severely high cyanide levels in the youngest age group experienced the only two possibly or probably related SAEs (an increase in blood cyanide and respiratory depression) reported in this study. All AEs that were recorded in enrollments with severely high cyanide levels, including SAEs, are summarized in Table 12-7. Except for the 4 SAEs and 3 additional AEs for increases in blood cyanide, each of these events had a reported severity of mild. Each of the 3 additional AEs for increases in blood cyanide was reported as having moderate severity. Two enrollments had AEs reported due to an increase in lactic acid; one enrollment had a lactate level that increased from a pre-dose level 0.9 to a peak level of 1.4mmol/L at the end of the study, and the other enrollment had a lactate level that increased from a pre-dose level of 2.3mmol/L to a peak level of 4.8mmol/L at the end of the study.

Table 12-7 AEs Recorded in Enrollments with Severely High Cyanide Levels

AE Preferred Term | Number of Enrollments with Preferred Term
Blood cyanide increased | 4
Blood lactic acid increased | 2
Convulsion | 1
Hyperglycaemia | 2
Hypocalcaemia | 2
Intracranial hypotension | 1
Pneumothorax | 1
Respiratory depression | 1
Respiratory failure | 1
Tachycardia | 2
Urinary retention | 1
Vomiting | 3
White blood cell count increased | 2

The percentage of enrollments with at least one AE or one SAE was higher among the enrollments with high cyanide levels (83% AE and 25% SAE) as compared to enrollments without high cyanide levels (55% AE and 10% SAE). The average number of AEs experienced per subject in the two groups was similar (2.3 for enrollments with high cyanide levels compared to 1.8 per subject for enrollments without high cyanide levels). Three enrollments in each group either died or experienced a severe or life threatening AE; one enrollment died in each group.

Excluding AEs with the preferred term for an increase in blood cyanide, 67% (9 of the 12 enrollments) with high cyanide levels experienced an AE, while 55% of enrollments without high cyanide levels experienced an AE.

None of the 4 enrollments without high cyanide levels who had reported SAEs had any whole blood cyanide measurements that were above the limit of detection. Four enrollments had whole blood cyanide levels that were above the limit of detection but below 1.5mcg/mL. Two of these 4 enrollments had maximum recorded cyanide levels of 0.1 and 0.7 mcg/mL but no reported AEs. One of these 4 enrollments had a maximum recorded cyanide level of 0.21 mcg/mL and 3 reported AEs, each of which were classified as mild and possibly related to the study drug; these AEs had preferred terms of nausea, pruritus, and vomiting. The final enrollment in this group had one AE, which was classified as hypoglycaemia, and a maximum recorded cyanide level of 0.56 mcg/mL.

In summary, enrollments with high cyanide levels experienced AEs and SAEs more frequently and tended to experience more severe and related AEs than enrollments who did not have high cyanide levels. However, the SAEs experienced by enrollments with severely high cyanide levels are generally not associated with cyanide toxicity.

### 12.3.4 Analysis of Key Safety Endpoints

#### 12.3.4.1 Primary Safety Analysis

No SAEs were experienced by enrollments in the SNP or control treatment groups during the 30-minute blinded phase. Three out of 25 (12%) enrollments in the SNP treatment group and 3 out of 21 (14%) enrollments in the control group experienced SAEs during the follow-up phase. There is no indication of a difference in SAE rates between the treatment groups.

#### 12.3.4.2 Hypotension

During the open-label and blinded phase, 1 (2%) of the 52 enrollments in the safety population experienced severe hypotension based on the protocol definition (Table 9-2). An additional 15 (29%) enrollments experienced a MAP value of at least 25% below the target value without meeting the protocol definition of moderate or severe hypotension. Fifteen (29%) enrollments experienced only mild hypotension based on the protocol definition.

#### 12.3.4.3 Rebound Hypertension

During the blinded phase, 3 (14%) of the 21 enrollments in the control group met the protocol criteria for having rebound hypertension; none of the 25 enrollments who received SNP met the protocol criteria for having rebound hypertension.

#### 12.3.4.4 Cyanide Toxicity and Acidosis

After the start of study drug administration, there were no new cases of mild, moderate, or severe lactic acidosis. Metabolic acidosis rates were also estimated to be low; only 1 of the 52 (2%) enrollments in the safety population had recorded HCO_3_^-^ values <18.5 mEq/L. Three (6%) enrollments showed mild cyanide toxicity, and 12 (23%) enrollments had severe cyanide toxicity. These enrollments showed moderately elevated rates of AEs and SAEs than did enrollments that did not experience severe cyanide toxicity.

## 12.4 Clinical Laboratory Evaluations

It must be noted that clinical laboratory evaluations were not available for all enrollments in the safety population and not all enrollments in the safety population were randomized to a treatment group. The overall changes in scores from baseline to post-baseline levels in clinical laboratory evaluations, signed rank test p-values for the change scores, and summaries at each time points are presented in Tables 14.3.3.1.1 through 14.3.3.1.7. Comparison of summaries between treatment groups and the Kruskal-Wallis p-value for the difference in change scores between groups are presented in Tables 14.3.3.2.1 through 14.3.3.2.7. These tables include all subjects with valid measurements, regardless of whether they have measurements for both time points, although change scores are only calculated using enrollments with data at both baseline and post-baseline time points.

Tables 14.3.3.3.1 through 14.3.3.3.6 are shift tables that show shifts in number of enrollments in normal and abnormal clinical laboratory evaluations and the McNemar test p-values used to assess the strength of the shifts. The shifts are presented by treatment groups as well. The percentage of enrollments that declined from baseline normal findings to post-baseline abnormal findings for each of the two blinded phase treatment groups and the p-value for Fisher’s exact test to assess this difference are presented in Tables 14.3.3.4.1 through 14.3.3.4.6. These summaries only include enrollments with both baseline and post-baseline measurements.

Predicted values and scatter plots for the dose response analyses are shown in Figures 14.1.6.1 through 14.1.6.3. Occurrences of cyanide toxicity, metabolic and lactic acidosis are discussed in Section 12.3.3.2; normal and abnormal classifications discussed in this section are based on laboratory-specified thresholds.

A complete listing of clinical laboratory evaluations can be found in Section 16, Listings 16.2.13.1.1-7.

### 12.4.1 Hematology Evaluations

Each hematologic measurement shown in Table 14.3.3.1.1 has a significantly different (p-value < 0.05) change score from baseline to study drug discontinuation. The median change score for WBC is 2.3×10³/mm³, the median change score for HGB is −1.3 g/dL, the median change score for HCT is −3.1%, and the median platelet count change score is −23×10³/mm³. Table 14.3.3.2.1 shows that no test score is significantly different between treatment groups and the overall significant differences shown in Table 14.3.3.1.1 are reflected in at least one of the treatment groups for each test.

Categorical clinical laboratory data for hematologic outcomes are summarized in Tables 14.3.3.3.1 and 14.3.3.4.1. The p-values for McNemar’s test, which are used in Table 14.3.3.3.1 to assess the difference between baseline and post-baseline measurements of the proportion of subjects with a normal classification for laboratory findings, are low (p-values < 0.05) for WBC, HGB, and HCT measurements when all enrollments, regardless of treatment group, are combined. The low McNemar p-value suggests that the proportion of normal findings at the baseline and post-baseline time points are not the same. For each measurement, a high number of baseline normal findings become abnormal. For WBC measurements, 13 (45%) of the 29 baseline normal enrollments had abnormal findings later in the study. For HGB, this number is 17 (55%) of the 31 enrollments with baseline normal findings. For HCT, this number is 16 (64%) of the 25 enrollments with baseline normal findings.

The control group had the lowest McNemar p-values for hematologic outcomes; 0.04 for HCT measurements and 0.07 for HGB measurements. However, the power of the McNemar test in individual treatment groups is limited by the small sample size in individual treatment groups, and the short length of the blinded phase relative to the open-label phase may result in the blinded treatment not having a large added effect on the outcome. The change patterns in measurements were found to be similar between two treatment groups; the only exception was for the WBC measurements, where the percentage of enrollments with baseline normal values and post-baseline abnormal values show a large difference between the two treatment groups; 42% in the SNP group but 17% in the control group. Table 14.3.3.4.1 shows that the differences in the proportion of enrollments, which declined from baseline is not high between the treatment groups. The Fisher’s exact p-values testing the treatment difference are all near or above 0.1; the greatest difference (p-value=0.09) is found in the WBC measurements.

### 12.4.2 Chemistry Evaluations

As shown in Table 14.3.3.1.2, the change scores for potassium, carbon dioxide, creatinine, and BUN show negligible differences (median change score of 0) from baseline to study drug discontinuation. Sodium measurements have a median change score of −2.0 (p-value=0.002), while the chloride change score is −1.0 (p-value=0.08). The only significant difference between groups shown in Table 14.3.3.2.2 is for creatinine, where the p-value is 0.02. Both groups have a median change score of 0, although the creatinine mean change score is slightly lower in the SNP group (−0.1 compared to 0 in the control group).

As seen in Table 14.3.3.3.2, for each of the chemistry laboratory measurements, the majority of enrollments with normal baseline values remain normal post-baseline and at least half of the enrollments with abnormal baseline values become normal post-baseline. The smallest McNemar p-value is for carbon dioxide, which has a p-value of 0.07; the percentage with abnormal findings decreases from 32% (16 of 50) at baseline to 18% (9 of 50). No other McNemar p-value is below 0.1. The high Fisher’s exact test p-values in Table 14.3.3.4.2 suggest that there is little difference in the number that decline between treatment groups; the sodium measurements is the only laboratory assessment with more than 5 enrollments who declined from baseline as 12 (41%) of the 29 enrollments with baseline normal findings have abnormal findings post-baseline.

### 12.4.3 Liver Function Evaluations

Measures of ALT and AST were used to test liver function. As shown in Table 14.3.3.1.3, the median AST change score from baseline to study drug discontinuation is −3.0 U/L (p-value=0.29); however, the mean change score is considerably greater (−37.9) due to the influence of one large negative change score of −1016 U/L for an enrollment in the SNP treatment group. The p-value for the ALT change score is smaller (0.002); the median and mean change scores are −3.0 and −16.9 U/L, respectively. The results presented in Table 14.3.3.1.4 show no significant difference between treatment groups in either measure of liver functioning.

As seen in Tables 14.3.3.3.3 and 14.3.3.4.3, ALT and AST measurements are not significantly different between the two treatment groups. In addition, the percentage of enrollments with baseline abnormal classifications and the percentage with post-baseline normal classifications is similar; the difference between the number of baseline and the number of post-baseline normal classifications is −4% (18% compared to 14% respectively) for ALT and 2% (31% compared to 33% respectively) for AST.

### 12.4.4 Lactate Evaluations

As seen in Table 14.3.3.1.4, there was no significant change from the baseline to post-baseline lactate levels at either 8 or 16 hours following the start of study drug infusion or study drug discontinuation. The median change score was not greater than 0.1mmol/L at any time point. There is not a significant difference between treatment groups at study drug discontinuation (Table 14.3.3.2.4).

As seen in Table 14.3.3.3.4, the number of enrollments with abnormal lactate findings increases slightly from 11 (22% of 49 enrollments) at baseline to 16 (33%) at post-baseline. Nine (24%) of 29 enrollments with baseline normal findings have abnormal findings after starting the study drug. However, this change is not significantly large (p-value=0.27). The number of subjects that declined was not significantly different between the study groups (Table 14.3.3.4.4).

### 12.4.5 ABG Evaluations

Change scores in arterial blood gas (ABG) are presented in Table 14.3.3.1.5. Methemoglobin and Sulfur dioxide (SO_2_) measurements are the only ABG assessments that show no significant change from baseline at any time point. PCO_2_ values show a significant change (a median decrease of 2.5 mmHg; p-value < 0.05) at 16 hours following the start of infusion, but not a significant change at 8 hours following the start and at study drug discontinuation (−1.0 mmHg) at. The change scores for pH are significantly different at the 16 hour and study drug discontinuation time points with p-values of 0.002 and 0.04, respectively. However, at each time points, the means and medians of the change scores were ≤ 0.1. The p-values for HCO_3_^-^ are 0.01 at the last two time points; the median and mean change scores are 1.5 and 1 at 16 hours and study drug discontinuation, respectively. The only ABG assessment that shows a significant difference at each time is PO_2_. The median change scores at the three time points are −13.0, −32.5, and −19.5, respectively. The mean change scores are −58.7, −69.6, and −61.4 respectively, at the three time points. There was no significant difference between treatment groups at study drug discontinuation for any of the ABG measurements (Table 14.3.3.2.5).

Table 14.3.3.3.5 is the shift table for ABG findings. McNemar p-values for PCO_2_ (0.08) and HCO_3_ (0.06) are below 0.1. For PCO_2_, 57% (12 of 21) of enrollments with baseline normal measurements have abnormal findings after baseline. The number of enrollments with abnormal findings increases from 29 (58% of 50) at baseline to 37 (74%) post-baseline. For HCO_3_^-^, the number of enrollments with abnormal findings increases from 16 (32% of 50) at baseline to 24 (48%) post-baseline. The only treatment group with a p-value below 0.1 is the control group in the SO_2_ assessment (p-value=0.02). More enrollments (9 compared to 2) in the control than in the SNP group show a decline from baseline, and Table 14.3.3.4.5 shows that the Fisher’s exact test for the comparison between treatment groups shows a p-value slightly below 0.05.

### 12.4.6 Venous Blood Gas (VBG) Evaluations

Little change from baseline levels in the venous blood gas (VBG) scores was seen (Table 14.3.3.1.6; all change score p-values were above 0.05. At 8 hours following the start of open-label infusion, p-values below 0.1 were found for the pH (p-value=0.05) and HCO_3_^-^ (p-value= 0.09) change scores. Both the mean and median pH change scores were approximately 0. Mean and median HCO_3_^-^ change scores were 0.9 and 1.0 mEq/L, respectively. There was no significant difference between treatment groups in VBG change scores (Table 14.3.3.2.6). At 16 hours following the start of open-label infusion, the mean and median change scores were greater in magnitude (−4.7 and −7.5 mmHg, respectively), but only 12 enrollments have sufficient data to have the PO_2_ change score calculated at this time point. At the 16 hour time point, the only p-value below 0.1 is for the PCO_2_ findings, which had mean and median change scores of −2.5 and −3.5 mmHg, respectively, and a p-value of 0.096 for data from 12 enrollments. The only p-value below 0.1 for the change scores at study drug discontinuation was for PO_2_ (p-value=0.07). The mean and median change scores were −3.4 and −3.0 mmHg, respectively.

Table 14.3.3.3.6 shows that all McNemar p-values for the comparison between baseline and post-baseline VBG measurements for enrollments from both treatments groups combined are fairly high (>0.1). The only treatment group difference is in the PO_2_ findings. In the control group, 7 (50%) of the 14 enrollments with baseline abnormal findings do not have abnormal post-dose findings and 6 (86%) of the 7 enrollments with baseline normal findings continued to have normal findings post-dose. Thus, there was an increase (33% to 62%) in the number of normal classifications from baseline to post-dose. However, the percentage of normal classifications in the SNP group decreased from 61% to 28% because a majority of enrollments with normal findings at baseline became abnormal post-dose (6 of 11; 55%). The Fisher’s exact test p-value for the difference in the proportion of enrollments that show declines in PO_2_ findings is 0.04.

### 12.4.7 Cyanide Evaluations

As seen in Table 14.3.3.1.7 measurements of multiple whole blood cyanide, plasma thiocyanate, or urine thiocyanate levels showed a significant increase from baseline. No enrollments had detectable baseline whole blood cyanide levels, and the median at each time point after baseline was 0. The highest mean value at any time point was 1.3mcg/mL. This mean value was calculated from 14 enrollments that were in the open-label phase at 16 hours following the start of study drug infusion. The highest recorded whole blood cyanide value was 6.5mcg/mL, which was recorded as a supplemental measurement after the end of blinded drug administration. For plasma and urine thiocyanate measurements, the median value at baseline was 0, although some enrollments had detectable levels. The largest mean and median for plasma thiocyanate was recorded from 39 enrollments at 12 hours after blinded drug administration; both the mean and median at this time point was 6.8 mcg/mL. The highest mean urine thiocyanate change score was 4.7 mcg/mL, which was recorded at both 16 hours (N=29) and 24 hours (N=30) after blinded drug administration. The median change scores at those time points were 4.1 and 4.0 mcg/mL respectively. Table 14.3.3.2.7 shows no significant difference between treatment groups at study drug discontinuation for any cyanide measurement.

### 12.4.8 Dose Response Models for Lactate, HCO_3_, and Whole Blood Cyanide

As discussed in Section 9.7.1.3.3.3, dose response models were used to assess the relationship between the 8-hour AUC of dose and 8-hour lactate, ABG HCO_3_^-^, and whole blood cyanide levels. Baseline levels were added as a covariate to each model except for the whole blood cyanide levels since there were no baseline whole blood cyanide levels above the limit of detection. AUC values are presented as per-minute averages in order to make parameter estimates easier to interpret. Forty-six enrollments were still in the open-label phase 8 hours after the start of infusion.

The scatter plot for lactate is shown in Figure 14.1.6.1. Forty-five enrollments were included in this analysis; one enrollment was excluded due to a missing 8-hour lactate measurement. A log-transformation was used on the lactate response variable in order to remedy skewness and non-normality in the residuals found when ordinary least-squares regression was fit to the lactate data. After the transformation, one highly influential value had a Cook’s D statistic of 1.1; this subject’s lactate level increased from a baseline lactate value of 4.90 to an 8-hour measurement of 0.72mmol/L with an average dose of 4.48mcg/mL/min. Thus, estimates from a robust regression model (fit using MM-estimation in PROC ROBUSTREG in SAS) are presented in Figure 14.1.6.1. These estimates show a strong relationship between the centered baseline lactate covariates (slope estimate of 0.342; p-value<0.0001). This shows that enrollments with higher than average baseline levels also tended to have high post-baseline lactate levels. There is a slight positive relationship between average dose and 8-hour lactate; an increase of 1 mcg/mL/min in the average administered dose over 8 hours increases the expected 8-hour lactate measurement by 0.0949 mmol/L (p-value=0.057 and 95% confidence interval (−0.0028, 0.193)). The model R^2^ value was estimated to be 0.27.

The scatter plot for ABG HCO_3_^-^ is shown in Figure 14.1.6.2. All 46 enrollments were included in this analysis. Model assumptions for ordinary least-squares regression were adequately met, and no severely outlying or influential values were observed. The strongest outlying value belonged to subject 12-2-31, whose value increased from 24 to 31mEq/L with an average dose of 1.26mcg/mL/min; this observation had a studentized residual of 2.9, and no other studentized residual had an absolute value greater than 2.1. The R^2^ value for this model is 0.62, and the centered baseline HCO_3_^-^ value has a strong relationship with the 8-hour measurement (slope estimate of 0.83; p-value <0.0001). Thus, post-baseline levels tend to be close to baseline levels. There is little relationship between average dose and 8-hour HCO_3_. An increase of 1 mcg/mL/min in the average administered dose over 8 hours increases the expected 8-hour HCO_3_^-^ level by only 0.019 mmol/L (p-value=0.938 and 95% confidence interval (−0.47, 0.51)).

The scatter plot for whole blood cyanide is shown in Figure 14.1.6.3. Forty-five enrollments are included in this analysis; measurements are included as long as they took place within an hour of the 8-hour mark, although one subject with no whole blood cyanide measurements after the start of infusion is excluded. One subject is included despite not having a cyanide measurement until 9 hours and 31 minutes after the start of infusion. Since the measured cyanide level was below the level of detection at that time, it can be assumed to have been no greater at 8 hours after the start of infusion.

As seen in Figure 14.1.6.3, no enrollments with average doses <3mcg/kg/min have cyanide levels above the limit of detection. Also, only a single enrollment has an average dose between 3 and 4mcg/kg/min and a cyanide level above 0.5mcg/mL. Since the cyanide levels are non-negative and the data show no variability at low doses, an ordinary least-squares regression model is inadequate for this data. Instead a gamma-Bernoulli mixture model was fit. The Bernoulli probability that the cyanide level is below the limit of detection was modeled using logistic regression with a logit link function. Conditional upon the fact that the cyanide level is above the limit of detection, a gamma model was fit. Normal and log-normal distributions were also fit to model the emission probability, but this change did not improve the model fit or meaningfully affect the parameter estimates or expected dose response relationship.

The parameters for the systematic components of the two component distributions in the mixture are shown in Table 12-8. The slopes are the parameters for the effect of 8-hour average dose. Due to the sharply negative slope, the estimated probability of having an 8-hour cyanide level below the limit of detection decreases as the average dose increases. This relationship is strong; the upper bound of the 95% confidence interval for the slope is below 0. Based on this model, an average dose >3.92 mcg/kg/min will give at least a 50% chance of seeing a cyanide level that is above the limit of detection.

Table 12-8 Intercepts and Slopes for Bernoulli and Gamma Distribution Components of Whole Blood Cyanide Mixture Model

Parameter | Estimate | Std Error | P-Value | 95% Confidence Interval
Parameter | Estimate | Std Error | P-Value | Lower Bound | Upper Bound
Bernoulli | 8.90 | 2.80 | 0.003 | 3.27 | 14.54
Intercept
Bernoulli Slope | −2.27 | 0.72 | 0.003 | −3.73 | −0.81
Gamma | −1.29 | 1.27 | 0.316 | −3.86 | 1.27
Intercept
Gamma Slope | 0.39 | 0.28 | 0.166 | −0.17 | 0.95

Eleven enrollments have cyanide levels that are above the limit of detection. More enrollments at high doses or with positive cyanide levels would be needed to estimate the parameter estimates for the gamma relationship between dose and positive cyanide levels with better precision. In particular, there are not enough observations at high dose levels in order to adequately estimate the curvature of the model at high dose levels. For example, a quadratic term could be added in order to create an estimate that flattens somewhat as dose increases, but the small sample size and high amount of variability in the data prevent an additional term from being estimated with adequate precision. Alternately, the slope term for the gamma distribution could be removed from the model, but then the curvature of the dose response curve is determined by the logistic regression component of the model, and the expected value flattens too quickly and potentially underestimates the cyanide levels at high doses. However, the models with (AIC = 69.6) and without (AIC = 69.5) the gamma distribution slope term have similar AIC values, which suggests that the gamma slope does not add much useful information to the model. For the model presented in Table 12-8, an average 8-hour dose >4.72mcg/kg/min is expected to be associated with a cyanide level above 1.5mcg/mL, which is the protocol threshold for severe toxicity.

## 12.5 Vital Signs

This section discusses safety analyses of pulse and diastolic and systolic blood pressure. Tables 14.3.4.1.1 through 14.3.4.1.3 summarize these vital sign measurements during the open-label phase by age group. Tables 14.3.4.2.1 through 14.3.4.2.3 summarize these vital sign measurements during the blinded phase by blinded treatment group. Figures 14.1.4.2.1 and 14.1.4.2.2, 14.1.4.3.1 and 14.1.4.3.2, and 14.1.4.4.1 and 14.1.4.4.2 plot means and standard errors for the vital sign measurements at each summarized time point during the open-label and blinded phases. Tables 14.3.4.3.1 through 14.3.4.3.3 summarize these vital sign measurements during follow-up by blinded treatment group. Figure 14.1.1 shows changes in infusion rate and all vital signs over time for each enrollment during both the open-label and blinded phases. MAP scores are discussed in Section 11. Instances of hypotension and rebound hypertension are discussed in Section 12.3.3.1.

Table 14.3.4.1.1 and Figure 14.1.4.4.1 show changes in pulse rate over time during the open-label phase. The mean and median rates are between 120 and 128 bpm respectively during the first 12 hours of open-label infusion, although both values drop slightly later in the open-label period as more enrollments leave the open-label phase. During the blinded phase, the overall median takes a minimum value of 114 bpm at the 21 minute time point, and the median for enrollments on SNP has a low value of 114 bpm at both 3 and 4 minute time points. Table 14.3.4.2.1 and Figure 14.1.4.4.2 show that the control group has a lower mean and median than the SNP group at every time point after 5 minutes post-start; the maximum difference in medians is 12 bpm at the 14 minute time point, when 22 enrollments were treated with SNP and 9 enrollments were treated with placebo. As shown in Table 14.3.4.3.1, the difference between treatment groups is not consistent across measurement times during the follow-up phase. Enrollments who received SNP during the blinded phase had higher pulse rates at study drug discontinuation. However, the difference in median pulse rates is small at 8 hours (0 bpm difference) and 24 hours (0.5 bpm difference) after blinded phase. The overall median pulse rate ranged from 115 to 118 bpm at all measurement times following study drug discontinuation.

Between 15 minutes and 12 hours after the start of open-label infusion, median systolic blood pressure for summarized time points ranges from 96 mmHg (around 11 hours post-start) to 108 mmHg (around 15 minutes post-start) as shown in Table 14.3.4.1.2. Table 14.3.4.2.2 shows that the median systolic blood pressure for the SNP group during the blinded phase ranges from 96 mmHg (for 21 enrollments at the 29 minute time point) to 110 mmHg (for 21 enrollments at the 21 minute time point). Figure 14.1.4.2.2 shows that the mean for the control group quickly rises following the start of the blinded phase; the largest difference in medians is 14 mmHg at 9 minutes, when 24 and 15 enrollments have recorded data in the SNP and control groups, respectively. As shown in Table 14.3.4.3.2, the difference between treatment groups is not consistent during the follow-up measurements. At 8 hours, the SNP median systolic blood pressure is slightly higher than that of the control group (108 mmHg compared to 105 mmHg), but at 24 hours, the SNP median of 95.5 mmHg is 12.5 mmHg lower than the control group median.

Between 15 minutes and 12 hours after the start of open-label infusion, median diastolic blood pressure for summarized time points ranges from 50 mmHg (around 5 and 12 hours post-start) to 58 mmHg (around 5 minutes post-start) as shown in Table 14.3.4.1.3. As shown in Table 14.3.4.2.3, the median diastolic blood pressure for the SNP group during the blinded phase, ranges from 46 mmHg (for 21 enrollments at 24 and 25 minutes) to 56 mmHg (for 25 enrollments at the 4 minute time point). As seen in Figure 14.1.4.3.2, the mean diastolic blood pressure for the control group rises following the start of the blinded phase; the largest difference in medians is 15.5 mmHg at 24 minutes, when 21 and 8 enrollments have recorded data in the SNP and control groups, respectively. As shown in Table 14.3.4.3.3, the difference between treatment groups at the follow-up measurements is not large. At 8 hours, the SNP median diastolic blood pressure is slightly higher than that of the control group (57 mmHg compared to 56 mmHg), and at 24 hours, the SNP median of 55.5 mmHg is 0.5 mmHg higher than the control group median.

## 12.6 Concomitant Medications

As shown in Table 14.3.2.2, the WHO classes of concomitant medications taken by at least 10% of enrollments were used to treat ailments in the nervous system (49 (94% of safety population) enrollments and 180 medications), cardiovascular system (45 (87%) enrollments and 146 medications), alimentary tract and metabolism (22 (42%) enrollments and 50 medications), and blood and blood forming organs (16 (31%) enrollments and 54 medications), and musculo-skeletal system (7 (14%) enrollments and 7 medications). The summary of WHO drug classes by treatment group for enrollments in the ITT population is shown in Table 12-9. Table 14.3.2.1 contains the summary of all concomitant medications by treatment group.

Table 12-9 Concomitant Medication Summary by Treatment Group for Enrollments in the ITT Population

Who Class; Medication Name | Treatment | | | | Total; (N=46)
Who Class; Medication Name | SNP; (N=25) | | Placebo; (N=21) | | Total; (N=46)
Who Class; Medication Name | Enrollments With Medication N (%) | Total Medications | Enrollments With Medication N (%) | Total Medications | Enrollments With Medication N (%) | Total Medications
ALIMENTARY TRACT AND METABOLISM | 9 (36%) | 26 | 11 (52.4%) | 19 | 20 (43.5%) | 45
ANTIINFECTIVES FOR SYSTEMIC USE | 2 (8%) | 4 | 2 (9.5%) | 4 | 4 (8.7%) | 8
BLOOD AND BLOOD FORMING ORGANS | 6 (24%) | 26 | 7 (33.3%) | 17 | 13 (28.3%) | 43
CARDIOVASCULAR SYSTEM | 21 (84%) | 81 | 19 (90.5%) | 56 | 40 (87%) | 137
MUSCULO-SKELETAL SYSTEM | 2 (8%) | 2 | 3 (14.3%) | 3 | 5 (10.9%) | 5
NERVOUS SYSTEM | 23 (92%) | 81 | 21 (100%) | 82 | 44 (95.7%) | 163
RESPIRATORY SYSTEM | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
SYSTEMIC HORMONAL PREP.,EXCL.SEX HORM.AND INSULIN | 2 (8%) | 3 | 2 (9.5%) | 2 | 4 (8.7%) | 5
VARIOUS | 1 (4%) | 1 | 2 (9.5%) | 2 | 3 (6.5%) | 3

Besides nitroprusside, the concomitant medications taken by at least 40% of enrollments in the safety population were furosemide (taken by 31 (60%) enrollments) and morphine (taken by 22 (42%) enrollments).

## 12.7 Safety Analysis Conclusions

No subjects in either treatment group experienced an SAE during the blinded phase. Thus, the primary safety analysis showed no difference between the SNP and control groups. Additionally, the same number of enrollments (3) experienced an SAE during follow-up in each treatment group. Thus, the rates of SAEs in the two treatment groups were not found to be different in this study.

The rate of severe hypotension was low; only 1 (2%) enrollment met the protocol definition of severe hypotension. No enrollments met the protocol definition of moderate hypotension. However, 15 (29%) enrollments met the protocol definition for mild hypotension, and an additional 15 enrollments had a recorded MAP value at least 25% below the target MAP value. No enrollments in the SNP group and 3 (14%) of the 21 enrollments in the control group met the protocol criteria for having rebound hypertension in the blinded phase.

The rate of severe cyanide toxicity (>1.5mcg/mL), as determined by whole blood cyanide levels above, was 23% (12 of 52 enrollments in the safety population). Two (4%) additional enrollments had recorded mild cyanide toxicity. There were no new cases of mild, moderate, or severe lactic acidosis recorded after the start of study drug that had not already been recorded at baseline, and 3 (6%) of enrollments met the study criterion for having metabolic acidosis. Only one of these cases of metabolic acidosis was due to a low HCO_3_^-^ value (< 18.5 mEq/L).

The following lab assessments show some indication of strong (p-value < 0.05 for at least 50% of summarized time points) changes from baseline to post-baseline levels as measured in either change scores or shifts between abnormal and normal classifications: WBC, HGB, HCT, platelet count, sodium, ALT, ABG pH, ABG PO_2_, ABG HCO_3_, whole blood cyanide, and thiocyanate (urine and plasma). As summarized in Section 12.4, not all shifts in laboratory measurements differed significantly between treatment groups; creatinine had a change score distribution that differed strongly (p-value < 0.05) between treatment groups. The percentage of declines in classification from normal to abnormal for VBG PO_2_ and ABG SO_2_ differed strongly between treatment groups.

After adjusting for baseline levels, dose response models do not show a meaningful relationship between the AUC of administered SNP after 8 hours of open-label drug infusion and either lactate or HCO_3_^-^. A stronger relationship was found between the 8-hour AUC of dose and whole blood cyanide levels. No enrollments with 8-hour AUC values below an average of 3mcg/kg/min had detectable cyanide levels, while higher AUC values were associated with higher observed cyanide levels. As discussed in Section 12.3.3.3, enrollments with observed severe cyanide toxicity showed slightly elevated rates of AEs and SAEs.

Vital signs (mean and median pulse rates and systolic and diastolic blood pressure) show stability throughout the first 12 hours of open-label drug administration. Enrollments in the SNP group show consistently lower pulse rates and blood pressure than do enrollments in the control group after the first few minutes of the blinded phase, although the difference between treatment groups at the follow-up measurements taken at 8 and 24 hours after the blinded phase is not consistent.