# 11 EFFICACY EVALUATION

## 11.1 Datasets Analyzed

The subject populations for the safety and efficacy analyses are described in Section 10. Fifty-one subjects, all of whom received SNP irrespective of study completion, were included in the safety population. The ITT (efficacy) population consisted of 45 subjects eligible for the efficacy analysis since six subjects in the safety analysis terminated early from the study and one was enrolled twice. Data from both enrollments were used for the safety analyses and data from only the first enrollment were used in the efficacy analyses. The demographic and baseline summaries of the ITT population are discussed in Section 11.2. An additional six (13%) of the 45 subjects in the ITT population were not included in the primary analysis for reasons summarized in Table 11-1. The subject with insufficient measurements during the 30-minute blinded phase did not have a recorded MAP measurement during the blinded phase until 29 minutes after the start of blinded infusion.

Table 11-1 Subjects in the ITT Population Who Are Not Included in the Primary Efficacy Analysis

Subject | Treatment Group | Reason Not Included in Primary Analysis
▬ | SNP | Delta (MAP) = 0
▬ | SNP | Delta (MAP) = 0
▬ | Placebo | Insufficient measurements during 30-minute blinded phase
▬ | SNP | Dose too low (<0.5 mcg/kg/min) at start of blinded phase
▬ | SNP | Dose too low (<0.5 mcg/kg/min) at start of blinded phase
▬ | Placebo | Dose too low (<0.5 mcg/kg/min) at start of blinded phase

Table 11-2 shows that 24 (53%) of the 45 subjects in the ITT population were randomized to receive SNP during the blinded phase. Twenty (51%) of the 39 subjects in the primary efficacy analysis were randomized to receive SNP during the blinded phase.

Table 11-2 Number of Subjects in Each Treatment Group by Analysis Group

Analysis Group | SNP Group | Control Group | Total
ITT Population | 24 (53.3%) | 21 (46.7%) | 45 (100.0%)
In Primary Analysis | 20 (51.3%) | 19 (48.7%) | 39 (100.0%)

The distribution of subjects between the five treatment centers at each phase is presented in Table 11-3. Sites ▬ and ▬ are the only centers that have at least four subjects with data that was used for the primary efficacy analysis. Since site ▬ has only 1 subject in the primary efficacy analysis that received placebo during the blinded phase, the 4 subjects at site ▬ were pooled with the 6 subjects from sites ▬ and ▬ to form a center group, which was used to adjust the primary efficacy analysis for a potential center effect. The results of this analysis are discussed in Section 11.4.1.1.1.

Table 11-3 Summary of Analysis Groups from Each Site (Percentage of Subjects in Each Analysis Group Given in Parentheses)

Site | Safety Population; (N=51) | ITT Population; (N=45) | In Primary Analysis; (N=39)
▬ | 4 (7.8%) | 4 (8.9%) | 4 (10.2%)
▬ | 3 (5.9%) | 2 (4.4%) | 0
▬ | 4 (7.8%) | 4 (8.9%) | 3 (7.7%)
▬ | 35 (68.6%) | 31 (68.9%) | 29 (74.4%)
▬ | 5 (9.8%) | 4 (8.9%) | 3 (7.7%)

## 11.2 Demographic and Other Baseline Characteristics

Baseline characteristics including age, height, weight, gender, ethnicity and race are summarized for the ITT population, by treatment assignment, in Table 14.1.2.1 and for the safety population by age strata in Table 14.1.2.2. Table 14.1.2.3 presents the comparison between baseline demographics of the ITT population and subjects in the safety population but not in the ITT population.

The average age for the 52 enrollments (51 enrollments and one duplicate enrollment; Section 10.1) in the safety population was 5.79 (with a sample standard deviation of 6.02) years of age. Forty-three (83%) of the 52 enrollments in the safety population and 37 (82%) of the 45 subjects in the ITT population had not reached Tanner Stage III. Fifty (96%) of the 52 enrollments in the safety population and 44 (98%) of the 45 subjects in the ITT population had a racial classification of Caucasian; the rest of the subjects were classified as African-American. Two subjects (4% of the safety population; 4% of the ITT population) were of Hispanic or Latino ethnicity. As discussed in Section 9.7.1.3, the primary efficacy was planned to be adjusted for any covariates which had a p-value below 0.1 for a test of statistically significant difference in distribution between the two treatment groups. As seen in the comparison between the 45 subjects eligible for the efficacy analysis from the ITT population shown in Table 14.1.2.1, none of the demographic and baseline variables show a significant difference in distribution between groups. The median height and weight z scores are lower in the SNP arm compared to placebo arm, however the differences are not statistically significant. The differences in z-scores for height and weight had the lowest p-values of all between-treatment comparisons; these p-values were 0.158 and 0.172, respectively. Z-scores were calculated using age and sex-specific levels for the normal population provided by Center for Disease Control and Prevention (CDC) growth charts, year 2000. See sample z-score calculation in Kuczmarski (2002).

Baseline medical histories (abnormal histories only) are presented for each patient in Section 16, Listing 16.2.6; prior medications are summarized by WHO drug class in Table 14.1.3 and listed for each patient in Listing 16.2.7.

Operative characteristics summarized by age and treatment group, respectively, are presented for the safety population in Table 14.1.6.1 and for the ITT population in Table 14.1.6.2. The number of subjects in the SNP-treated group that did not have surgery (7; 29%) was similar to the number in the control group (4; 19%). Five subjects in each group had surgery for coarctation of the aorta. For subjects who underwent surgery, recorded operative characteristics such as time under anesthesia and the estimated fluid intake are distributed similarly between treatment groups. The incision length summaries exclude an outlier and probable data entry error for subject 29-2-03; the calculated incision length for this subject was 30 hours, and the recorded incision end time was 23 hours after the anesthesia end time.

The most common abnormal physical examination findings at baseline in the safety population (see Table 14.1.7.1) were for the following body systems: cardiovascular (41 subjects; 80%), respiratory (33 subjects; 65%), gastrointestinal (31 subjects; 61%), and urinary (30 subjects; 59%). As seen in Table 14.1.7.2, there is no significant statistical difference between the two treatment groups for these body systems. The largest difference between the two treatments groups is for the dermatologic system with a p-value of 0.03. Since abnormal findings in the dermatologic system will not affect the safety or efficacy of SNP, the primary analysis is not adjusted for this variable.

Summaries in Table 14.1.8.1 show that the median infusion rates during the open label phase across all age groups increases over time until the 4 hour time point. The median infusion rates stabilize around 2.5mcg/kg/min during the next 9 hours, which is when data from most subjects are available. There is a small difference between the two treatment groups in weight-adjusted infusion rates during the blinded phase; see Table 14.1.8.2. This table includes all subjects in the blinded phase, including the 3 subjects who were removed from the efficacy analysis due to a low dose that was below 0.5mcg/kg/min. Subjects in the SNP group received a lower average infusion rate of 2.9mcg/kg/min compared to 3.5mcg/kg/min for subjects in the control group. However, the median infusion rate for both groups was 2.5mcg/kg/min with a Kruskal-Wallis p-value of 0.375. These results also imply that the distribution of SNP infusion rates received at the end of the open-label phase is similar for subjects in the two treatment groups.

### 11.2.1 Distribution of Baseline MAP and Delta (MAP) Values

As per protocol, for a subject to be included in the study, he/she was anticipated to require a minimum of 20 mmHg (15 mmHg for subjects < 2 years old) reduction in MAP for at least 12 hours using SNP; there was no minimum Delta (MAP) requirement for inclusion in the ITT population because the target MAP value could increase during the open-label phase. However, since it would not be meaningful to the study if the Delta (MAP) was zero, all subjects with a Delta (MAP) value of zero were excluded from the efficacy analysis. Of the 39 subjects included in the efficacy analysis, 5 subjects from the control group, and 4 subjects from the SNP group had Delta (MAP) values below 20 mmHg. One subject in each group had a Delta (MAP) below 10 mmHg.

Table 11-4 compares the distribution between treatment groups in values of MAP_B1_, MAP_B2_, and Delta (MAP) for subjects in the ITT population. A low Delta (MAP) value is indicative of a small increase in MAP from baseline and would cause a subject to be classified as a treatment failure. The distributions for all three MAP measures for both treatment groups are similar.

Table 11-4 Summary of MAP_B1_, MAP_B2_, and Delta (MAP) Values for Subjects in the ITT Population

Assessments/Statistics | Treatment | | Total | P Value
Assessments/Statistics | SNP | Placebo | Total | P Value
MAP_B1_
N | 24 | 21 | 45 | 0.322
Mean (SD) | 93.5 (17.0) | 97.8 (17.2) | 95.5 (17.0)
Median (Min, Max) | 92.5 (64.0, 134.0) | 94.0 (75.0, 138.0) | 94.0 (64.0, 138.0)
MAP_B2_
N | 24 | 21 | 45 | 0.785
Mean (SD) | 69.5 (12.4) | 69.2 (10.1) | 69.4 (11.2)
Median (Min, Max) | 69.0 (48.0, 104.0) | 68.0 (50.0, 88.0) | 68.0 (48.0, 104.0)
Delta(MAP)
N | 24 | 21 | 45 | 0.459
Mean (SD) | 24.0 (12.0) | 28.6 (14.2) | 26.2 (13.1)
Median (Min, Max) | 28.0 (0.0, 43.0) | 30.0 (8.0, 63.0) | 28.0 (0.0, 63.0)

## 11.3 Measurement of Treatment Compliance

The protocol provided guidelines for study medication dosing for each phase of the study. Deviations, and the circumstances surrounding them, are summarized in Section 10.2 and documented in the Protocol Violations/Deviations log provided in Listing 16.2.15.

Doses received by each patient in the open-label and blinded phases are presented in Section 16, Listings 16.2.9.2 and 16.2.9.3, respectively. Summary statistics for study medication administered in each phase of the study are provided in Table 14.1.8.

## 11.4 Efficacy Results and Tabulations of Individual Patient Data

### 11.4.1 Analysis of Efficacy

#### 11.4.1.1 Primary Efficacy Analysis

As discussed in Section 9.7.1.3.4, two primary endpoints were used to assess the efficacy of the drug:

1. Whether a subject is classified as a treatment success during the blinded phase
2. Failure time

##### 11.4.1.1.1 Treatment Success and Treatment Failure

The definition of a treatment failure is given in Section 9.5.1; subjects who were not treatment failures were classified as treatment successes. The primary analysis tests whether SNP and placebo have a different probability of controlling MAP during the 30-minute blinded phase without the need of administering additional medications to achieve MAP control.

As described in Section 11.1, 39 subjects were included in the primary analysis. Section 16, Listing 16.2.10.4 lists whether each subject was a treatment success or failure along with failure times and additional information about blinded drug administration.

The data for treatment failure and success as primary efficacy endpoints are summarized in Table 11-5 and 14.2.2; an exact 95% confidence interval (CI) for the ratio of the odds of success for subjects in the SNP group to the odds of success in the control group is given in Table 11-5. SNP treatment has a higher success rate of 55% (11 successes out of 20 subjects) compared to 21% (4 success out of 19 subjects) in the control group.

Table 11-5 Treatment Failure and Success as Primary Efficacy Endpoints

| Treatment | | Total (N=45) | Odds Ratio | P Value
| SNP | Placebo | Total (N=45) | Odds Ratio | P Value
Number of Subjects
Success | 11 (55.0%) | 4 (21.1%) | 15 (38.5%) | 4.58 | 0.048
Failure | 9 (45.0%) | 15 (78.9%) | 24 (61.5%) | CI: (0.94, 25.04)

The p-value used for the equality of success rates across the two treatment groups was calculated using the two-sided Fisher’s exact test. Although the p-value of 0.048 is indicative of a statistically significant difference between the two treatment groups, it is only slightly below 0.05, which is the threshold of significance. Moreover, the exact confidence interval for the odds ratio contains 1 (see Table 11-5), which usually implies that there is no statistically significant difference in the odds of success for the two groups. However, the exact confidence interval for the odds ratio is somewhat conservative and may have a confidence level above 0.95 (Agresti, 1992). The asymptotic 95% confidence interval for odds ratio has a lower bound of 1.12.

Following the protocol, the treatment group comparison was adjusted for a potential treatment center effect. As discussed in Section 11.1, only two treatment center groups were used due to the low number of subjects at all sites other than site 12. The first group consists of all subjects treated at site 12, and the second group contains all subjects treated at other centers. The number of subjects at each of the centers represented in the second group is presented in Table 11-3. Since there was no significant difference between treatment groups in any demographic or baseline variables of interest at the 0.10 level, the primary analysis is only adjusted for the treatment center effect.

Results of the adjusted primary analysis are given in Tables 14.2.3 and 11-6. The success rates for subjects receiving placebo are similar for the two treatment center groups: 21% at site 12 and 20% at other centers. The success rates among SNP patients show a greater difference of 47% at site 12 compared with 80% at other sites.

Table 11-6 Primary Efficacy Analysis Summary with Treatment Center Adjustment

| Site | | | | Treatment
| Site 12 | | Other | | Treatment
| SNP | Placebo | SNP | Placebo | P Value
Number of Subjects
Success | 7 (46.7%) | 3 (21.4%) | 4 (80.0%) | 1 (20.0%) | 0.049
Failure | 8 (53.3%) | 11 (78.6%) | 1 (20.0%) | 4 (80.0%)

Although the site 12 success rate in the SNP group is lower than at other sites, testing for a difference in the odds ratios across the two groups of centers using Zelen’s exact test produces a p-value of 1, although this test is potentially underpowered. The p-value for the treatment effect found using stratified conditional logistic regression is 0.049. Both the p-value of the unadjusted (0.048) and adjusted (0.049) analyses are marginally below the predetermined 0.05 threshold for concluding statistical significance. However, the support for the alternative hypothesis is not as strong as was anticipated before the start of the study. One possible explanation is related to inconsistencies in the times in which subjects received the blinded drug; the effect of these inconsistencies is explored in greater detail in Section 11.4.1.3.

##### 11.4.1.1.2 Failure Time Analysis

Failure time is a secondary endpoint used to assess the efficacy of the drug. A summary of the time lapse from the start of blinded infusion to treatment failure is presented in Tables 11-7 and 14.2.2. This summary excludes a subject who could be classified as a treatment failure before 30 minutes after the start of blinded drug infusion but did not have recorded MAP measurements in the first 15 minutes after the start of infusion.

At each time point, the failure rate is higher for subjects in the control group. The p-value of 0.028 for the log-rank test suggests that the two treatment groups have different failure time distributions. In the Kaplan-Meier plot in Figure 14.1.1, it can be seen that more subjects in the control group than in the SNP group tend to fail early in the blinded phase. At the 5 minute mark, the estimated failure rate increases from 11.1% to 33.3%, and it increases to 77.8% at 13 minutes before stabilizing.

Table 11-7 Summary of Failure Times by Treatment Group

Treatment Failure Rate by Time in Blinded Phase (mins)^3^ | Treatment | | Total | P Value^4^
Treatment Failure Rate by Time in Blinded Phase (mins)^3^ | SNP | Placebo | Total | P Value^4^
5 | 20.0% | 33.3% | 26.3% | 0.028
10 | 25.0% | 66.7% | 44.7%
15 | 40.0% | 77.8% | 57.9%
20 | 45.0% | 77.8% | 60.5%

##### 11.4.1.1.3 MAP Change Scores

###### 11.4.1.1.3.1 MAP Changes Scores During Blinded and Follow-Up Phases

Table 14.2.1.2 and Figure 14.1.4.1.2 summarize changes over time in the average MAP score during the 30-minute blinded phase for all subjects in the ITT population. These summaries include all subjects who received blinded treatment. Subjects may not have recorded MAP values for all 30 minutes of the blinded phase. Some subjects have MAP values recorded after they could be classified as treatment failures; these measurements are included in Table 14.2.1.2 and Figure 14.1.4.1.2.

Both blinded treatment groups start the blinded phase with similar average MAP scores. The average B_2_ values are 69.5 for the 24 subjects in the SNP group and 69.2 for the 21 subjects in the placebo group, which is a 0.4% difference. As expected, the average MAP values are greater in the control group than in the SNP group for every time point during the blinded phase. The greatest absolute difference between the two groups is at the 9 minute mark, where the average SNP MAP value is 9.3 mmHg greater than the MAP average in the control group.

In the SNP group, the peak average change score from baseline was 3.6 mmHg (an average percentage change of 5.3%) for the 20 subjects remaining in the study at 20 minutes post-blinded infusion. In the control group, the peak average change score from baseline was 12.7 mmHg (an average percentage change of 18.7%) for the 15 subjects remaining in the study at 9 minutes post-blinded infusion. The lower average MAP values and more stable change scores of SNP subjects suggest that SNP was effective in maintaining MAP stability during the 30 minute blinded phase, although the difference between groups were not tested for statistical significance.

Changes from baseline (B1) MAP levels recorded at follow-up for the ITT population are summarized in Table 14.2.1.3. At study drug continuation, the average decrease in MAP from B1 for subjects from both treatment groups is 22.2 mmHg. This decrease in MAP is slightly greater for subjects in the placebo group (25.8 mmHg compared to 18.9 mmHg for subjects in the SNP group). At 24 hours following blinded drug infusion, the average decrease from B1 drops slightly to 18.2 mmHg.

###### 11.4.1.1.3.2 MAP Changes Scores During Open-Label Phase

Changes over time in the average MAP score during the open-label phase for all subjects in the safety population are summarized in Tables 14.2.1.1.1 through 14.2.1.1.3 and Figure 14.1.4.1.1. Tables 14.2.1.1.1 through 14.2.1.1.3 summarize for each age group the distribution of MAP values and change scores recorded in the first minute after the start of infusion; at 5 and 10 minutes post- start; within 2 minutes of 15 minutes post-start, within 5 minutes of 30 minutes post- start; and within 20 minutes of every hour after that up to 24 hours post-start; and at B_2_. If multiple measurements are taken within one of the specified windows, the measurement recorded closest to the center of the window will be used. For example, if a subject had multiple measurements recorded within 20 minutes of 1 hour post-start, the measurement closest to 1 hour post-start was included in the summary. Change scores are calculated with respect to B_1_. Figure 14.1.4.1.1 summarizes the average and standard error at 30 minutes post-start and for every hour after that using the same windows as in Tables 14.2.1.1.1 through 14.2.1.1.3.

Figure 14.1.4.1.1 shows stability in average MAP levels during the first 12 hours of the open-label study drug administration. Between 30 minutes and 12 hours following the start of infusion, the highest average MAP value is 74.8 mmHg and the lowest is 69.3 mmHg. Later in the blinded phase, the mean is more variable over time, but the mean estimates after the 20-hour mark are unreliable since most of the safety population had either dropped out of the study or moved to the blinded phase.

#### 11.4.1.2 Sensitivity Analyses

##### 11.4.1.2.1 Effect of Enrollments Excluded from Primary Analysis

The classification of each enrollment excluded from the primary analysis as a treatment success or failure is given in Table 11-8. This table includes the 6 subjects listed in Table 11-1, as well as the duplicate enrollment, who was only included in the primary analysis using the subject’s first enrollment. The failure time for each subject represents the number of minutes after the start of blinded drug infusion. For instance, for the subject whose first observation occurred at the 29^th^ minute after the start of blinded drug infusion, the failure time of 33 minutes is the 5^th^ minute in which the subject has recorded MAP measurements.

Table 11-8 Outcomes for Enrollments Excluded from Primary Analysis

Enrollment | Treatment Group | Outcome | Failure Time
▬ | SNP | Success | N/A
▬ | SNP | Failure | 3
▬ | SNP | Failure | 11
▬ | Placebo | Failure | 33
▬ | SNP | Success | N/A
▬ | SNP | Failure | 5
▬ | Placebo | Success | N/A

If these enrollments were included in the efficacy analysis, the success rate in the SNP group would drop slightly from 55% to 52%, and the success rate in the control group would increase from 21.1% to 32.3%.

##### 11.4.1.2.2 Secondary Success Rate Analysis with Flush Time Adjustment

As noted in Section 11.1, subjects could have a delay between the start of blinded drug administration and the time in which the subject begins to receive the blinded drug. The volume of the infusion tube, the infusion rate, the carrier fluid rate, and the fluid used in the dead space can affect the length of this delay. This delay caused some subjects in the control group to continue to receive the open label drug during the blinded phase, which would cause the effect of the treatment drug to continue into the blinded phase. In addition, some subjects who were randomized to receive SNP may have received placebo instead of SNP at some point during the blinded phase if saline was used as the flush fluid.

A secondary analysis was conducted to adjust the start time of blinded drug administration used in the efficacy analysis to equal the time in which each subject is estimated to have received the blinded drug. This secondary analysis used the information about blinded drug administration presented for each subject in Section 16, Listing 16.2.10.4 in order to estimate each subject’s starting time. The data in Section 16, Listing 16.2.10.4 contain information about which flush fluids were used, the infusion and carrier rates, and the volume of the tube. Other information, such as the viscosity and length of the tubes, are either unavailable or not incorporated in the estimation.

Since either placebo (saline) or SNP was used as the flush fluid, subjects had four different combinations of blinded drug and flush fluid. If the subject received placebo fluid as both the blinded drug and flush fluid, then the time in which the subject began to receive the placebo was estimated as the time that it would take the drug to travel through the catheter from the t-piece connector. The rate at which the drug would travel through this area was estimated as the sum of the blinded drug infusion rate and the carrier fluid flow rate. Thus, the time was estimated as the quotient of the volume of this section of the catheter (in mL) divided by the drug flow rate (in mL/ hr).

If the subject received placebo fluid as the blinded drug and SNP as the flush drug, then the time at which the subject began to receive the placebo was estimated as the time that it would take the drug to travel from the point the blinded drug was connected through the t-piece connector and then through the catheter from the t-piece connector. This is then the sum of the latter time, which is calculated as in the previous scenario, and the travel time through the point the blinded drug is connected through the t-piece connector. The drug flow rate in this section of the tube is solely determined by the infusion rate. Thus, the travel time through the t-piece dead space was estimated as the quotient of the volume of this dead space (in mL) divided by the infusion rate (in mL/hr).

If SNP was used as both the flush fluid and blinded drug, then the subject would have received SNP continuously from the end of the open-label phase to the end of the blinded phase, and no adjustment is needed. Only one subject in the ITT population received SNP as the blinded drug and saline as the flush fluid, but this subject was not included in the secondary analysis due to missing information about the volume of the t-piece dead space, which would have been needed to estimate the time at which the subject received placebo.

A list of the subjects in the ITT population, who were not included in the secondary analysis, is given in Table 11-9. The subject whose 1^st^ blinded phase observation was 29 minutes after the start of blinded drug administration was expected to be included in the secondary analysis once the subject’s blinded treatment starting time was adjusted. However, the subject was not included in the secondary analysis because the estimated start time of 40 minutes is after the subject’s last recorded observation.

In addition to the six subjects that were excluded from the primary analysis, six more subjects were excluded from the secondary analysis. Four of these newly excluded subjects have missing flush or dead space information. The other 2 newly excluded subjects had estimated blinded infusion start times that exceeded the last time of measurement. The estimated start times of two subjects were 8 and 32 minutes after the start of blinded infusion. Both times were after their last measurements, which had been recorded at 7 and 30 minutes, respectively, after the start of infusion of the blinded drug. The total number of subjects in the secondary analysis is 33 (73%) of the 45 subjects in the ITT population.

The flush fluid used for 2 subjects (▬ and ▬ included in the secondary analysis is not definitively known. Representatives at the corresponding study site believe that the flush fluid was SNP, and it is assumed to be SNP in this secondary analysis. Both subjects were randomized to receive SNP as the blinded drug; one was a treatment success and the other was a failure.

Table 11-9 Subjects in ITT Population Excluded in the Secondary Success Rate Analysis

Subject ID | Blinded Treatment | Flush Fluid | Primary Analysis Success | Reason for Exclusion
▬ | Placebo | Open label | No | Estimated start after last measurement
▬ | SNP | Unknown | No | Unknown flush fluid
▬ | SNP | Unknown | No | Unknown flush fluid
▬ | SNP | Open label | Excluded | No Delta (MAP)
▬ | SNP | Open label | Excluded | No Delta (MAP)
▬ | SNP | Saline | Yes | Unknown t-piece dead space volume
▬ | Placebo | Open label | Excluded | Estimated start after last measurement
▬ | Placebo | Open label | Yes | Estimated start after end of blinded phase
▬ | SNP | Open label | Excluded | Dose too low (<0.5 mcg/kg/min) at end of blinded phase
▬ | SNP | Open label | Excluded | Dose too low (<0.5 mcg/kg/min) at end of blinded phase
▬ | Placebo | Open label^*^ | No | Unknown t-piece dead space volume
▬ | Placebo | Blinded drug | Excluded | Dose too low (<0.5 mcg/kg/min) at end of blinded phase

* Flush fluids were likely to have been used during the analysis, but the flush fluids used for these subjects are not known for sure.

In this secondary analysis, subjects who did not have 30 minutes of blinded treatment data after adjustment to the starting time were not automatically classified as treatment failures. Table 11-10 lists subjects who were classified as treatment successes but have fewer than 30 minutes of data due to censoring caused by the adjustment of the treatment starting time. Also, since this analysis does not include any subjects in the SNP group who received saline as the flush fluid, the only change to data for subjects in the SNP group is that the subjects listed in Table 11-9 are excluded from the analysis.

Table 11-10 Censored Subjects in the Secondary Success Rate Analysis

Subject | Treatment | Censoring Time (min)
▬ | Placebo | 28
▬ | Placebo | 25
▬ | Placebo | 7

The results of the secondary analysis are presented in Table 11-11. When compared with the results of the primary analysis, the secondary analysis resulted in a slightly higher success rate for the SNP group (59% compared to 55%), and a slightly lower success rate for the control group (19% compared to 21%). This produces a moderately higher odds ratio (6.19 compared to 4.58). The p-value remained below 0.05 despite the fact that the secondary analysis has 6 few subjects in it.

Table 11-11 Secondary Analysis of Success Rates

| Treatment
| SNP | Placebo | Total | Odds
| SNP | Placebo | Total | Ratio | P Value
Number of Subjects
Success | 10 (58.8%) | 3 (18.8%) | 13 (39.4%) | 6.19 | 0.032
Failure | 7 (41.2%) | 13 (81.3%) | 20 (60.6%) | CI: (1.04, 44.26)

Note: An exact 95% confidence interval (CI) for the odds ratio is given.

The time-to-failure analysis discussed in Section 11.4.1.2 was also conducted for the adjusted data. The subject with no observations during the first 15 minutes of the blinded phase was again excluded from this analysis.

Post-secondary analysis, a difference in efficacy between treatment groups was still detected; the log-rank test p-value is 0.003. Figure 11-1 shows the Kaplan-Meier estimates of failure time during the blinded phase using the adjusted data. In comparison to the analysis on the unadjusted data, the estimated failure probabilities increase faster before 5 minutes and reach 0.75 earlier in the blinded phase. The results summarized in Table 11-11 and Figure 11-1, suggest that the delay until subjects received blinded treatment may have masked the treatment effect to some extent. However, the significance of the secondary analysis presented here is limited by two factors. First, not every subject in the primary analysis is represented in the secondary analysis. Also, the time in which subjects in the control group began to receive the blinded treatment is estimated and not known for certain.

Figure 11-1 Kaplan-Meier Curve for Adjusted Failure Time Data

#### 11.4.1.3 Efficacy Analysis Conclusions

The primary efficacy analysis shows that after adjusting for the effect of treatment centers, subjects treated with SNP during the 30-minute blinded period had a significantly different success rate than subjects in the control group (p-value=0.049). The secondary time-to-event analysis also showed that the two groups had a significantly different distribution of failure times (p-value=0.028).

The treatment effect was not as strong as anticipated. One possible explanation for this is the delay experienced by subjects in the control group before receiving the placebo after the start of the blinded phase. A secondary analysis was conducted to adjust for this effect. This analysis showed a marginal increase in the effect size compared to the primary analysis. However, the difference between analyses is not great and the strength of this secondary analysis is limited since several subjects in the primary analysis were not part of the secondary analysis and the times that subjects began to receive the placebo are not known for certain.