# 10 STUDY PATIENTS

## 10.1 Disposition of Subjects

Subject disposition is summarized in Table 10-1, Figure 10-1 and Section 14, Table 14.1.1.1. Sixty-three subjects in total were enrolled in this study. A subject was considered to be enrolled in the study if the subject provided informed consent and had at least one study procedure performed or received open-label SNP. Subjects were classified by age at enrollment, and were accrued into one of the following five categories based on age at enrollment – 1 to < 30 days, 30 days to < 2 years, 2 years to < 6 years, 6 years to Tanner Stage II, Tanner Stage III to 17 years. Out of the 63 subjects, 51 (81.0%) entered the Open-Label Phase; these subjects constituted the safety population. Twelve of the 63 (19.0%) subjects did not enter the open label phase and terminated early. Of the 51 subjects who entered the open label phase, 47 (74.6% of total enrolled) were randomized to be treated with either SNP or Placebo in the blinded study drug administration phase; four were not randomized and terminated early. Out of the 47 subjects, 45 (71.4% of total enrolled) were treated while two were not treated and terminated early; these 45 subjects constituted the ITT (efficacy) population. Out of the 45 subjects, 24 (53.3%) were treated with SNP and 21 (46.7%) were treated with Placebo.

One subject who was originally enrolled in the 0 to < 30 days age group enrolled a second time while in the 30 days to < 2 years group. Thus, the total enrollment number is 64, and the total enrollment number in the 30 days to < 2 years age group is 22. This subject continued study participation into the open label phase and blinded phase. This resulted in 52 enrollments in the safety population and 46 enrollments in the ITT population. Data obtained from the second randomization of this subject were used for safety analysis but not for the efficacy analysis.

Table 10-1 Subject Disposition

| [underlined: Age Strata]
| 0 - < 30 days | 30 days - < 2 yrs | 2 yrs - < 6 yrs | 6 yrs - TS II | TS III - 17 yrs | Total
Number of Subjects
Enrolled | 4 | 21 | 10 | 18 | 10 | 63
Entered open-label phase; (Safety Population) | 3 (75.0%) | 20 (95.2%) | 7 (70.0%) | 12 (66.7%) | 9 (90.0%) | 51 (81.0%)
Randomized | 2 (50.0%) | 19 (90.5%) | 7 (70.0%) | 11 (61.1%) | 8 (80.0%) | 47 (74.6%)
Received blind treatment; (ITT population) | 2 (50.0%) | 19 (90.5%) | 7 (70.0%) | 9 (50.0%) | 8 (80.0%) | 45 (71.4%)
Early Termination | 2 (50.0%) | 2 (9.5%) | 3 (30.0%) | 9 (50.0%) | 2 (20.0%) | 18 (28.6%)
Reasons for Early Termination
Investigator judgment | 0 | 1 (4.8%) | 0 | 2 (11.1%) | 1 (10.0%) | 4 (6.3%)
Other | 2 (50.0%) | 1 (4.8%) | 3 (30.0%) | 5 (27.8%) | 1 (10.0%) | 12 (19.0%)
Unknown | 0 | 0 | 0 | 2 | 0 | 2

In total, 18 subjects did not complete the study and terminated early; the reasons recorded in the electronic data capture (EDC) system for early termination are listed in Table 10-2. Reasons for early termination were not recorded in the EDC system for two subjects.

Table 10-2 Reasons for Early Termination

Subject | Reason for Early Termination
▬ | No reason recorded
▬ | No reason recorded
▬ | The subject no longer required treatment
▬ | Surgeon’s decision
▬ | Subject never received drug – was screen failure
▬ | Subject no longer required treatment
▬ | Subject never received study drug – was screen failure
▬ | Subject never received study drug
▬ | Investigator judgment
▬ | Investigator judgment
▬ | Not started on SNP; processed as a screen failure
▬ | Investigator judgment
▬ | Difference between B1 and target MAP was less than 20mmHg
▬ | Prior to blinded phase, SNP no longer needed for blood pressure control
▬ | Difference between B1 and target MAP was less than 20mmHg
▬ | Difference between B1 and target MAP was less than 20mmHg
▬ | Investigator judgment
▬ | Did not start study drug

## 10.2 Protocol Deviations

Eighty-one protocol deviations were reported in this study. For the complete listing of protocol deviations, see Table 14.1.4 and Listing 16.2.15. Ten (12%) deviations were related to study drug administration, and 67 (83%) deviations were related to protocol procedure and assessment. Of the 10 deviations related to study drug administration, five were related to incorrect dosing.

Figure 10-1 Flow Chart – Subject Accounting