# 9 INVESTIGATIONAL PLAN

## 9.1 Overall Design and Plan Description

This was a phase II, multicenter, randomized, double-blind placebo-controlled, parallel group study to determine the persistence of the effect of SNP on blood pressure and to assess the potential for rebound hypertension associated with prolonged infusion in pediatric subjects.

Target MAP was defined as the clinically appropriate MAP as determined by the investigator taking into account the clinical presentation and medical needs of the subject. The investigator could change the target MAP at his/her discretion based on clinical needs during the course of the study. The anticipated Target MAP must have been at least 20 mmHg (15 mmHg for subjects < 2 years old) below MAP_B1_ (see next definition).

The initial baseline MAP (B1) was defined as the blood pressure measurement taken prior to the initiation of SNP administration, either institutionally-supplied or open-label study drug after at least a 5-minute period of stable conditions (e.g., no PRN doses or changes in sedative/analgesic drugs, tracheal suctioning, etc.). The blood pressure measurement establishing MAP_B1_ followed a 5-minute period of stable BP (e.g., no changes in administration rates of drugs that may affect BP). See Figure 9-1.

The subsequent baseline MAP (B2) was defined as the blood pressure measurement taken just prior to the initiation of blinded study drug after at least a 5 minute period of stable conditions (e.g., no PRN doses or changes in sedative/analgesic drugs, tracheal suctioning, etc.). Prior to establishing B2, there should have been no changes in the SNP infusion rate for a period of at least 20 minutes during which the infusion rate of SNP would have been at least 0.5 µg/kg/min.

Delta (MAP) is defined as the difference between MAP_B1_ and MAP_B2._

Offset is defined as MAP_B2_ plus 50% Delta (MAP).

Figure 9-1 Study Treatment Phases with MAP and Delta MAP

Example: Subject’s MAP immediately prior to start of the Open-label Study Drug Administration Phase is 100 mmHg (MAP_B1_). At the end of the Open-label Study Drug Administration Phase, MAP is 60 mmHg (MAP_B2_). Thus, Delta (MAP) = 40 mmHg. For treatment success, MAP during the Blinded Study Drug Administration Phase cannot exceed MAP_B2_ + 50% Delta (MAP), or 80 mmHg, for any 2 consecutive MAP_Blind_ measurements, obtained at 1-minute intervals.

Five centers participated in subject recruitment to complete the study.

Sixty-three (63) subjects who required long term (at least 12 hours) blood pressure control were enrolled. Fifty-four (54; 84%) of the subjects were pre-pubertal, and 48% of these pre-pubertal subjects were neonates, infants or toddlers and less than 2 years old at the time of enrollment. As per protocol, 50% of subjects enrolled were expected to be less than 2 years old.

Any subject who started the blinded study drug administration period was considered complete for analysis. Enrolled subjects were randomized in equal proportions to receive either placebo or SNP for the duration of the blinded-treatment period, which immediately followed the open-label infusion of SNP.

### 9.1.1 Definition of Study Periods

The various study periods were as follows:

Pre-study drug administration: a period of up to 7 days preceding the start of study drug administration during which informed parental permission and other enrollment procedures took place.

Open-label study drug administration (Dose-Titration): The period of open label study drug administration was at least 12 hours but not greater than 24 hours, including the time of infusion of institutionally-supplied SNP, if any. This period began at the start of SNP administration, either study drug or institutionally-supplied. The duration of infusion of the institutionally-supplied SNP was no longer than 8 hours. Randomization normally occurred during this period.

Blinded study drug administration: The period that began with the start of blinded study drug administration and ended with the discontinuation of blinded study drug. It immediately followed the open-label period and was no longer in duration than 30 minutes.

Follow-up: This period immediately followed blinded study drug administration and ended 30 days after completion of study drug administration. AEs were followed for 24 hours after termination of study drug. SAEs were followed for 30 days.

Safety was assessed via the evaluation of adverse events, pre- and post-treatment laboratory results, and vital sign data. The efficacy endpoints were mainly assessed by examining blood pressure parameters.

Table 9-1 Schedule of Assessments: Sodium Nitroprusside Long-Term Infusion Study

Procedure | Pre-study Drug Period (Up to 7 days prior to Study Drug administration) Open-label | Period (12 -24 hrs duration) | Blinded Study Drug Period | Study Drug d/c (Within 2 hours) | Follow-up (Up to 24 hours post blinded study drug)^1^
Assessments | ▬
Review Entry Criteria | X
Informed Parental Permission/HIPAA Consent | X
Collect Demographic Data | X
Medical History | X
Physical Examination | X | | | X | X^2^
Vital Signs (SBP, DBP, MAP, HR)^3^ | X^4^ | X | X | X | X
B1 | X^5^
B2 - Just Prior to Blinded Infusion | | X
Growth Parameters^6^ | X
Urine Output^7^ | X | X | X | X | X
Serious Adverse Events/Adverse Events | | X | X | X | X^8^
Concomitant Medication^9^ | X^10^ | X | X | X | X^11^
Concomitant Procedure^12^ | X^10^ | X | X | X | X^11^
Randomization of Blinded study drug | | X
Blinded Study Drug Administration | | | X
Open-label Study Drug Administration | | X
Laboratory Assessments | ▬
Pregnancy test (post-menarche females) | X^13^
Electrolytes, BUN, creatinine | X | | | X
Hematology (CBC & platelet count) | X | | | X
Liver Enzymes (AST, ALT) | X | | | X
Arterial Plasma Lactate level | X | Q 8 hours (± 30 min) | | X | X^14^
Arterial Blood Gas with Co-oximetry (includes Methemoglobin)^15^ | X | Q 8 hours (± 30 min) | | X | X^14^
Central Venous Blood Gas with Co-oximetry (includes Methemoglobin)^16^ | X | Q 8 hours (± 30 min) | | X | X^14^
Blood for Thiocyanate and Cyanide^17^ (central lab) | X | Q 8 hours (± 30 min) | | X & 12 hr post d/c^18^ | X^14^
Urine for Thiocyanate (central lab)^19^ | X | Q 8 hours (± 30 min) | | X | Q8 hrs (± 30 min) X 3

1 End of Study assessment was done at 24 hours post blinded study drug administration, except where noted.

2 Was performed 18-30 hours following the termination of study-drug administration.

3 Vital sign measurements were performed as described in protocol. Vital signs were collected every 12 hrs ± 30 min for 24 hours post blinded study drug administration. VS measurements described for the Open-label treatment period refer to both institutionally supplied SNP and investigational SNP (study drug).

4 Obtained vital sign measurements. Based upon clinical judgment, this may be MAP_B1_ for some subjects.

5 MAP_B1_ was obtained prior to the start of the SNP open-label infusion and after a 5-minute period of stable BP (e.g., no changes in administration rates of drugs that may affect BP)

6 Growth parameters include weight, height/ length, and Tanner stage, if ≥6 years old.

7 Measurements were performed at time of urine thiocyanate sample collection, if feasible.

8 AEs were followed for 24 hours and SAE was followed for 30 days, after the completion of study drug administration.

9 CRFs documented administration of concomitant medications that (1) affect blood pressure, as defined in Protocol (Appendix 16.1.1, Section 3.2.3.1 or (2) are associated with SAEs. All concomitant medications were recorded in source documents, such as the subjects’ medical charts.

10 Within 72 hours of study drug administration.

11 For subjects who underwent surgery while under protocol, record surgical information, including name of surgical procedure, whether the subject was intubated, post-operative diagnosis, start and stop times of general anesthesia, and time of surgical incision and closure (or their equivalent).

12 Clinically meaningful, unexpected, and invasive procedures only.

13 Performed within 48 hours of study drug administration.

14 Following concomitant SNP d/c, if feasible.

15 ABG sampling was preferred, sample collected at drug d/c only if line is still in.

16 Central Venous Blood Gas done only if CVC is indwelling.

17 Additional cyanide and thiocyanate tests were permitted provided that the investigator believes the tests to be in the subject’s best interest and the volume of blood required for the additional tests was not considered to be clinically significant (e.g., results in anemia or homologous blood transfusion).

18 Blood for cyanide & thiocyanate at 12 hrs ± 30 min, post study drug d/c, only if arterial line in place.

19 Urine collection details were described in Section 3.4.7.2 and the MOP.

## 9.2 Discussion of Study Design and Choice of Control Groups

This was a phase II, multicenter, randomized, double-blind placebo-controlled, parallel group study of intravenous infusions of SNP in children less than 12 years of age who required deliberate pharmacologic blood pressure control for at least 12 hours.

An open-label period of at least 12 hours followed the start of SNP administration. The open-label study drug period was effect-controlled in that SNP was gradually adjusted to achieve target MAP. Although target MAP had to be at least 20 mmHg (15 mmHg for subjects < 2 years old) below MAP_B1_, the target level could have changed over the course of the open-label period. As discussed in Section 9.1, subjects could enter the blinded phase after 12 hours of infusion once an infusion rate that achieved adequate MAP control was established. Subjects were then randomly assigned to either continue receiving SNP or withdraw to placebo for a dose-controlled 30-minute blinded phase at a stable infusion rate. A comparison of the proportion of subjects in the two treatment groups with a MAP level that rises above offset then allows for the assessment of the persistent efficacy of a stable dose of SNP in maintaining MAP control.

## 9.3 Selection of Study Population

Children less than 17 years of age who required pharmacologic blood pressure control for at least 12 hours were eligible for enrollment into the study. Blood pressure control was defined as the maintenance of the subject’s MAP to within 90-110% of a target MAP specified by the physician.

Five pediatric age groups were enrolled in this trial:

- Group A: Neonates from birth to less than 30 days of age
- Group B: Infants and toddlers from 30 days to < 2 years
- Group C: Preschool children from 2 years - < 6 years
- Group D: School age children from 6 yrs - < Tanner stage III
- Group E: Adolescents from Tanner stage III - < 17 years.

Tanner III refers to the onset of puberty and occurs at different ages in different individuals. The mean age at onset of Tanner III ranges from 12.4 to 13.1 years in males, and 11.9 to 12.6 years in females. At least 50% of the subjects were pre-pubertal, and 48% of these pre-pubertal subjects were neonates or toddlers at the time of enrollment.

### 9.3.1 Inclusion Criteria

Subjects met all of the following criteria:

1. Subject was less than 17 years of age.
2. An in-dwelling arterial line was clinically indicated.
3. Subject’s parent or legal guardian was willing and able to give informed parental permission signing and dating an IRB-approved informed parental permission containing all of the elements of informed consent, and subject provides assent, signing an IRB-approved and required informed assent, if applicable.
4. Subject was anticipated to require a minimum of 20 mmHg (15 mmHg for subjects < 2 years old) reduction in MAP for at least 12 hours using SNP [e.g., MAP_B1_ - MAP_B2_ ≥ 20 mmHg (15 mmHg for subjects < 2 years old)].

### 9.3.2 Exclusion Criteria

Subjects were excluded from study if any of the following criteria existed:

1. Subject weighed < 3.0 kg.
2. Subject had a known allergy to SNP.
3. Subject had a known mitochondrial cytopathy with a disorder of oxidative phosphorylation or of respiratory chain enzymes.
4. Subject had a contraindication to vasodilator therapy for control of blood pressure during surgery or in the intensive care unit.
5. Subject had raised intracranial pressure.
6. Subject was anticipated to need anti-hypertensive drugs other than Sodium Nitroprusside either IV (e.g., dexmedetomidine, esmolol, etc.) or epidural (e.g., local anesthetics, clonidine, etc.) within three terminal half-lives (3X T½ β) of the blinded study drug period. However, subjects who were receiving stable doses of an anti-hypertensive drug(s) prior to the initiation of study drug could be enrolled.
7. Subject had any serious medical condition which, in the opinion of the investigator, was likely to interfere with study procedures.
8. Subject was moribund (death likely to occur within 48 hours).
9. Subject had a positive result for the urine or serum HCG test administered at screening.
10. Subject had participated in other clinical trials for investigational drugs within 30 days prior to enrollment.
11. Subject had received or would have received Sodium Thiosulfate within 6 hours prior to the start of the open-label period.
12. Subject was either on, or anticipated to be on, ECMO.

### 9.3.3 Removal of Patients from Therapy or Assessment

If MAP fell below 50 mmHg (40 mmHg for subjects less than 1 month of age) or HR exceeded the age adjusted maximum with no other explainable cause (e.g., concomitant medication), open-label study drug was discontinued until MAP and HR returned to within protocol limits. Open-label study drug could then be restarted at a dose lower than the previous dose.

If the subject withdrew participation in the study for any reason, every effort was made to collect safety data, vital sign measurements and samples for safety and laboratory analyses. The date, time and reason for discontinuation were recorded on the CRF. Additionally, every attempt was made to complete all other study related procedures on discontinued subjects who had received any amount of study drug as the data was included in the safety and intention to treat analyses. Subjects who prematurely discontinued from the study were not replaced.

Any subject who started the blinded study drug administration period was considered complete for analysis.

Reasons for subject withdrawal from the study were as follows:

1. Subject’s parent or legal guardian wished to have the subject withdrawn for any reason;
2. Adverse events, conditions, or intercurrent illnesses that precluded compliance with the protocol, particularly if continuation posed a risk to the subject’s safety;
3. The investigator felt that it is in the subject’s best medical interest to be withdrawn;
4. Subject no longer needed blood pressure control.

## 9.4 Treatments

### 9.4.1 Treatments Administered

Study drug was dispensed to the sites in 2 ml vials containing 25 mg/ml of SNP. The pharmacist dispensed two preparations of study drug, one for the open-label study drug period and one for the blinded study drug period.

The open-label study drug administration phase utilized a fixed study drug concentration (at a dose that did not exceed 0.3 mcg/kg/min, or, if applicable, at the infusion rate of the institutionally-supplied SNP) and variable infusion rate scheme. Syringes or bags were prepared by the investigational drug pharmacy by adding 25 mg of SNP to 50 ml 5% dextrose. The syringe had a label indicating the concentration of the solution (0.5 mg/ml SNP), and the infusion rate necessary to provide 1.0 microgram per kilogram per minute (1.0 mcg/kg/min) — for example, for a 25-kg subject, an infusion rate of 3.0 ml/hr delivered 1.0 mcg/kg/min SNP. The infusion rate of 0.5 mg/ml SNP could be calculated using the conversion factor: Wt (kg) × 0.12 ml/kg/hr = 1.0 mcg/kg/min. Clinicians could then make the necessary dosage adjustment for adequate blood pressure control. All dosage adjustments were captured on the case report forms (CRFs).

The pharmacist supplied blinded study drug for each subject according to a randomization assignment generated by the IVRS. The blinded study drug was prepared by the pharmacist such that either the concentration of drug is the same as in the open label period or placebo (Appendix 16.1.1). Subjects received blinded study drug at the same rate of infusion that was used at the conclusion of the initial open-label study drug administration period, which will be at least 0.5 µg/kg/min.

The dose of open-label SNP was titrated according to the subject’s BP response such that the target MAP, chosen by the study physician, was achieved ±10%. If MAP fell below 50 mmHg (40 mmHg for subjects less than 1 month of age) or HR exceeded the age adjusted maximum with no other explainable cause (e.g., concomitant medication), open-label study drug was discontinued until MAP and HR returned to within protocol limits. Open-label study drug could then be restarted at a dose lower than the previous dose. The duration of open-label study drug administration was at least 12 hours but less than 24 hours.

### 9.4.2 Identity of the Product

Sodium nitroprusside (sodium nitropentacyanoferrate (III) dihydrate) is a reddish-brown crystalline powder that is freely soluble in water. Its molecular formula is Na_2_[Fe(CN)_5_NO] • 2H_2_0. Study drug was supplied by the BPCA Data Coordinating Center to the Investigational Drug Service at each clinical center in a standard concentration of 25 mg/ml. The Investigational Drug Service at each clinical center then prepared the drug in syringes or bags of sterile 5% dextrose for administration to randomized subjects according to the guidelines provided above. Sterile 5% dextrose was utilized as placebo.

### 9.4.3 Storage and Disposition of Supplies

The clinical supplies were stored at controlled room temperature from 15°- 30°C and protected from light in its carton until used. Investigational products were for investigational use only, and were to be used only within the context of this study. Study drug was maintained under adequate security.

### 9.4.4 Method of Assigning Subjects to Specific Dosage Levels for PK Analysis

After meeting all inclusion and exclusion criteria, subjects were considered to be enrolled and were randomly assigned to receive either placebo or active drug treatment groups during the blinded study drug administration phase of the trial using a single centralized randomization schedule. Randomization into the blinded portion of the trial was performed via a centralized interactive voice response system (IVRS).

The BPCA DCC provided a system for the pharmacist to obtain each subject’s randomized treatment assignment in a timely manner prior to the administration of study drug.

### 9.4.5 Selection of Doses in the Study

The Written Request (WR) issued by the FDA to obtain needed pediatric information for nitroprusside, requested that a dose-ranging trial be conducted prior to conducting trials to determine safety and efficacy of the drug in children. The dose-ranging trial (SNP1) was conducted under the auspices of the same IND as this study (SNP2), IND 71,979. The trial was a multicenter, randomized, double blind, and parallel group, dose-ranging, effect controlled study to determine the Pharmacokinetics and Pharmacodynamics of Sodium Nitroprusside (SNP) in pediatric subjects requiring controlled reduction of blood pressure during a surgical or medical procedure.

For the dose ranging trial, the FDA Written Request (see Appendix 16.1.13) specified that subjects were to be randomized to 1 of 4 initial rates of SNP infusion ranging between 10 and 100% of the starting adult dose of 3mcg/kg/min. Therefore, each subject was randomized to one of the following 4 initially blinded treatment group SNP doses: 0.3, 1, 2, or 3mcg/kg/min.

In randomized and treated subjects, administration of SNP resulted in statistically significant reductions in MAP from Baseline to 30 minutes after the start of infusion at the 0.3mcg/kg/min and 1mcg/kg/min SNP doses (p < 0.001). Notably, the change from Baseline in MAP was 11 mmHg in the 2mcg/kg/min SNP dose group at 20 minutes after the start of infusion, which is the same change from Baseline that was observed in the 0.3mcg/kg/min SNP dose group at 30 minutes after the start of infusion

Based on the efficacy and safety data of this study, it was concluded that a reasonable starting dose for SNP in pediatric subjects for whom deliberate induced hypotension is indicated would be 0.3mcg/kg/min. The clinician could then increase the infusion rate to achieve the desired reduction in blood pressure. For the subjects in this study, the mean infusion rate was approximately 1mcg/kg/min. The study data demonstrated the wide variability in subject responses to the drug, especially in regards to Baseline MAP, BMR, and age; therefore, it was concluded that the clinician should use his or her experience and the subject’s clinical situation to determine both the starting and maintenance infusion rate.

Deriving from the SNP1 study, the SNP2 study utilized a fixed study drug concentration at a dose that did not exceed 0.3mcg/kg/min in the open-label study drug administration phase or, if applicable, at the infusion rate of the institutionally-supplied SNP and variable infusion rate scheme. Subjects received blinded study drug at the same rate of infusion that was used at the conclusion of the initial open-label study drug administration period, which should have been at least 0.5mcg/kg/min. Subjects who received the study drug at a rate lower than 0.5mcg/kg/min were reported as protocol deviations. The data collected from these subjects was used for safety analysis and not for the primary efficacy analysis.

### 9.4.6 Blinding

The subject, as well as all caregivers, remained blinded to the treatment assignment throughout the course of the study. For subjects’ safety, the pharmacist was aware of the treatment group for each subject. The BPCA DCC maintained the double-blinded randomization schedule.

The randomization for an individual subject could be revealed in an emergency; however, investigators were discouraged against requesting that the blind be broken for an individual subject. Notification of any unblinding was sent via facsimile to the BPCA DCC within 24 hours.

### 9.4.7 Prior and Concomitant Therapy

#### 9.4.7.1 BP-Affecting Drugs

Administration of vasoactive drugs such as dopamine, epinephrine, and milrinone either prior to or concomitant with the administration of sodium nitroprusside was discouraged. However, if vasoactive drugs were clinically indicated, it was recommended that they should be administered as defined in Sections 3.2.3.2 and 3.2.3.3 of the protocol (Appendix 16.1.1). There were no restrictions on the administration of vasoactive medications following the end of the blinded treatment period.

#### 9.4.7.2 Prior Medications – Administration Started Prior to B1

It was recommended that vasoactive drugs started prior to B1 be either (1) discontinued at least 3 terminal half-lives (3X T½ β) prior to B1, or (2) continued at a stable dose until at least the end of the blinded infusion period, see Figure 9-2.

#### 9.4.7.3 Concomitant Medications – Administration Started After B1

It was recommended that vasoactive drugs started after B1 be discontinued at least 3 terminal half-lives (3X T½ β) prior to B2 (e.g., the start of the blinded treatment phase), see Figure 9-2.

Figure 9-2 Recommendation for the Administration of Vasoactive Medications

#### 9.4.7.4 Recording Prior and Concomitant Medications and Procedure

All concomitant medications that affect blood pressure, sodium thiosulfate, and clinically meaningful, unexpected, and invasive procedures were recorded for the period beginning 72 hours prior to study drug administration through 24 hours post-study drug conclusion. The dates of administration and reason for use were included. All concomitant medications were collected for SAEs occurring within 30 days following study drug administration.

#### 9.4.7.5 SNP as Concomitant Medication

Subjects may have received institutionally-supplied SNP prior to the initiation of study drug administration; however, administration of institutionally-supplied SNP was discontinued immediately prior to the initiation of study drug administration, and the initial infusion rate of study-drug SNP was the same as the discontinued institutionally-supplied SNP. VS measurements described for the Open-label treatment period in Table 9-1 refer to both institutionally supplied SNP and investigational SNP (study drug).

Subjects may have received institutionally-supplied SNP after the conclusion of the SNP Blinded Treatment Period at the discretion of the investigator.

The start and stop times and dates, and dosage of institutionally-supplied SNP administration were recorded on the appropriate CRF.

#### 9.4.7.6 Use of Sodium Thiosulfate

Administration of sodium thiosulfate was prohibited from 6 hours prior to the start of the open-label period until the end of the blinded-study period, except in cases in which nitroprusside or cyanide toxicity was suspected, in which case, the administration of sodium thiosulfate was recommended.

To facilitate the assessment of cyanide clearance, investigators were encouraged not to co-administer sodium thiosulfate with institutionally-supplied SNP, which at the investigator’s discretion, may have been administered following the conclusion of the blinded-study period. If sodium thiosulfate was co-administered with institutionally-supplied SNP following the conclusion of the blinded-study period, blood and urine samples were not tested for cyanide and thiocyanate in these subjects once the sodium thiosulfate administration had begun.

### 9.4.8 Treatment Compliance

Treatment compliance was evaluated by review of information documented on study drug administration and drug accountability forms.

The unblinded pharmacist verified that study drug supplies were received intact and in the correct amounts. The pharmacist documented this verification by signing and dating the Investigational Product Accountability Record or similar document. An accurate inventory of study drug was kept by the site. An overall accountability of the study drug was performed and verified by the clinical research associate (CRA) throughout the study and at the site close-out visit. All used and unused supplies were inventoried, accounted for, and returned to the BPCA DCC if requested. The investigators agreed not to supply study medication to any persons not enrolled in the study or not named as a sub-investigator for the trial.

## 9.5 Efficacy and Safety Assessments

Table 9-1 is a schematic representation of study assessments and procedures.

### 9.5.1 Efficacy Assessments

The efficacy of SNP was assessed through a comparison of the proportion of subjects in the treatment and control group who maintained stable MAP levels during the 30-minutes blinded phase. A subject was classified as a treatment failure during the blinded phase if the subject:

1. Fails to complete the entire double-blind phase without receiving additional treatment to control their blood pressure in addition to the study drug.
2. Fails to complete the entire double-blind phase for any reason.
3. Experiences an intra-patient increase greater than or equal to 50% Delta (MAP) for ≥2 consecutive MAP measurements, obtained at one-minute intervals, during the double-blind phase.

Delta (MAP) is defined in Section 9.1.

### 9.5.2 Safety Assessments

Safety assessments included monitoring the tolerability of the SNP infusion and assessing physical examinations, vital signs, clinical laboratory values, concomitant medications and procedures, and adverse events throughout the study. SAEs were collected for 30 days following completion of study drug administration.

In cases of discharge from the hospital before 30 days, parent (or guardian) was contacted to determine if any SAE’s occurred following discharge but within 30 days of study drug discontinuation. Safety issues regarding the possible development of cyanide toxicity during SNP infusions were a primary focus for monitoring study subjects for drug-related adverse events.

### 9.5.3 Drug Concentration Measurements

Cyanide, thiocyanate, methemoglobin, lactic acid, and arterial blood gas analysis were performed throughout the trial to indirectly query SNP levels and determine subject safety.

### 9.5.4 Methods of Assessments

#### 9.5.4.1 Vital Sign Measurements

Vital signs: systolic blood pressure, diastolic blood pressure, mean arterial pressure and heart rate were measured.

The principal method of obtaining blood pressure measurements were from an intra-arterial catheter inserted in an upper or lower extremity artery. Manual blood pressures from a non-invasive blood pressure cuff were only used prior to insertion of and during a malfunction of the arterial catheter. The blood pressure transducer was internally calibrated by the instrument upon performing the zeroing procedure. All blood pressure and heart rate data were acquired electronically when possible.

#### 9.5.4.2 Blood Draws and Urine Samples

Blood drawn for study related purposes did not exceed the maximum amounts specified by the American Association of Blood Banks for healthy infants, children, and adolescents. Normally, this value is 7 ml/kg over an eight week period. This study was an inpatient trial of short duration; therefore, the amount of blood withdrawn for study related purposes took into account the patient’s pre-existing hemoglobin and hematocrit, and local Institutional Review Board limitations on maximum allowable blood draws for study-related purposes. A reasonable and conservative value is 3 ml/kg.

In addition to the cyanide and thiocyanate tests scheduled in Table 9-1, the investigator was permitted to perform supplemental cyanide and thiocyanate tests provided that the investigator believed that the tests were in the patient’s best interest and the volume of blood required for the additional tests was not considered to be clinically significant (e.g., results in anemia or homologous blood transfusion).

Urine was sampled for thiocyanate concentrations every 8 hours, or fraction thereof, commencing with initial study drug administration to the end of study drug completion and then Q 8 hours times 3 after the discontinuation of study-drug administration, or until the urinary catheter is removed, whichever occurs first. All urine samples were from a pooled urine collection from the 8-hour time period or fraction of 8-hour time period. The sample was stored cold until shipment to the central lab.

## 9.6 Data Quality Assurance

### 9.6.1 Source Documents

Source documents are defined as original documents, data and records. They may include hospital records, clinical and/or office charts, laboratory data/information, subjects’ diaries or evaluation checklists, pharmacy dispensing records, recorded data from automated instruments, microfiches, photographic negatives, microfilm or magnetic media and x-rays.

The investigator(s)/institution(s) permitted study-related monitoring, audits, IRB/IEC review, regulatory inspection(s), and provided direct access to source data documents.

### 9.6.2 Data Collection

Data for individual subjects were recorded in the electronic data capture (EDC) system provided by the BPCA DCC. Electronic case report forms were completed for each subject enrolled, including those removed from the study. If a subject was removed from the study, the reason for removal was noted on the eCRF by the investigator. Subjects were not identified by name; study identification numbers were used. The investigator kept a separate log of subject names and addresses.

### 9.6.3 Data Processing and Data Management

Prior to the initiation of the study, an investigator’s meeting was held with the BPCA-CC, the investigators and their study coordinators and the CRAs for the study. This meeting included a detailed discussion of the protocol, performance of study procedures, CRF completion, simulation of study procedures and specimen collection methods. In addition to the investigators’ meeting, the study personnel at each site was trained on the study procedures by a CRA at a study initiation visit and received training in the use of the EDC System.

The CRAs monitored each site throughout the study. At each visit, data recorded in the EDC system was compared to source documentation to ensure accuracy. Quality assurance checks were performed to ensure that the investigator complied with the protocol and all applicable regulations.

In addition to the quality assurance checks incorporated into the EDC system, additional logic checks were run to check for such items as inconsistent study dates and outlying laboratory values. Any necessary corrections were made to the database and documented via audit trail.

## 9.7 Statistical Methods and Determination of Sample Size

### 9.7.1 Statistical and Analytical Plans

#### 9.7.1.1 Datasets Analyzed

The analysis population consists of the following two groups:

- [underlined: Safety:] Any patient who received any study medication, even if the patient did not reach the double-blind phase of the trial.
- [underlined: Intent to treat (ITT):] Any patient randomized to and exposed to the study drug during the double-blind phase of the trial.

There was one subject who enrolled in the study twice. As specified in the SAP, the second enrollment for this subject will not be included in the efficacy analyses, but both enrollments will be included in the safety analyses.

#### 9.7.1.2 Outcome Parameters

The efficacy analysis consists of assessments of changes in MAP during the blinded phase. The safety outcomes are summaries of the severity and frequency of AEs and SAEs and assessments of changes in lab values, physical examination classifications, and vital signs from baseline values.

#### 9.7.1.3 Planned Analyses

##### 9.7.1.3.1 General Statistical Methods

The summaries for continuous variables include the following descriptive statistics: sample size (N), mean, standard deviation, median, minimum, and maximum. Discrete variables are summarized using the number (frequency) and percentage in each category. Demographic, efficacy, and safety variables are summarized by treatment group.

Efficacy and safety variables are also summarized by study phase. Results are presented by age group for the open-label phase and by treatment group for the blinded and follow-up phases. Change scores are presented when applicable in order to show the difference between baseline and post-baseline levels.

For continuous variables, differences between either treatment groups were assessed using the nonparametric Kruskal-Wallis test except in the analysis of time until treatment failure, which is discussed in Section 9.7.1.3.4. Nonparametric signed- rank tests were used to test for changes from baseline. For categorical variables, these differences were assessed using Fisher’s exact test except in the analysis of categorical clinical laboratory data, which is discussed in Section 9.7.1.3.3.3.

Since all hypothesis tests besides the primary safety and efficacy analysis are primarily exploratory in nature, no adjustment for multiple comparison testing was used. A significance level of 0.05 was used for all analyses except in the treatment group comparison discussed below.

Only the primary efficacy analysis was adjusted for a potential study center effect. A preliminary analysis of baseline and demographic variables was conducted in order to see if they show significant differences between treatment groups. Tests for treatment group differences for these baseline and demographic variables were conducted at the 0.10 significance level. Since no significant baseline and demographic variables were available, they were not used as covariates or stratification variables in the primary efficacy analysis.

All analyses were performed in SAS version 9.2.

##### 9.7.1.3.2 Patient Disposition and Baseline Comparability

Subject accounting and patient disposition is presented in Section 14, Table 14.1.1.1. A discussion of subjects in the ITT population but not included in the primary efficacy analysis is given in Section 10.1.

A summary of subject accounting and final study disposition is provided. The duration of exposure to the study treatment are summarized separately for all enrolled and all randomized subjects and is discussed in Section 12.1. For subjects who discontinued at any point of the study, the primary reason for discontinuation is summarized in Table 14.1.1.1.

Baseline and demographic variables are summarized by age group for all enrollments in the safety population and by treatment group for all subjects in the ITT population. Demographic variables include gender, ethnicity, and race as well as the baseline measures age, height, and weight at baseline. Z-scores of height and weight will also be presented.

Open-label and blinded phase baseline MAP values are drawn from measurements taken before the start of open-label and blinded infusion, respectively. Surgical procedures and related operative information are summarized.

Prior medications are summarized using World Health Organization (WHO) coding by Anatomical Therapeutic Chemical (ATC) level 1 classification and age group. The September 2010 version of the WHO drug dictionary was used to code both the prior and concomitant medications.

##### 9.7.1.3.3 Safety and Tolerability Outcome Analyses

The primary safety outcome (WR objective (g)) was whether the proportion of patients with SAEs differed significantly between the two treatment groups during the blinded phase. All other safety analyses are secondary.

###### 9.7.1.3.3.1 Adverse Events and Critical/Near Critical Incidents

In addition to the primary safety analysis, secondary analyses were conducted to test for differences between the two blinded treatment groups in the number of AEs and SAEs during the follow-up phase. Additionally, AEs and SAEs were summarized by severity, relationship to the study drug, MedDRA system organ class, and MedDRA preferred term for each study phase. MedDRA versions 12.1, 13.0, 13.1, and 14.0 were used in coding.

###### 9.7.1.3.3.2 Concomitant Medications and Procedures

Concomitant medications and procedures are summarized using WHO coding by ATC level 1 class and either age group or treatment group in Tables 14.3.2.1 and 14.3.2.2.

###### 9.7.1.3.3.3 Clinical Laboratory Values

Descriptive summaries are provided for each scheduled lab measurement taken during each phase. For each continuous lab measurement, the presence of a significant change from baseline was tested in both overall and within treatment groups. Differences in change scores between treatment groups were also tested.

For categorical lab measurements, shift tables are given in order to represent changes over the course of the study in the laboratory categorization of normal or abnormal. These categories were created by pooling together the following abnormal categories: abnormal and clinically significant and abnormal but not clinically significant. If more than one post-baseline measurement is available, the worst post-baseline measurement was used. For the categorical laboratory evaluations, the proportion of patients that declined since baseline was compared between the two groups using Fisher’s exact test. Differences within groups were tested using McNemar’s test.

Additionally, the number of subjects with abnormal lab measurements within the thresholds given in Table 9-2 is summarized in Tables 14.3.1.7.1 through 14.3.1.7.5. Measurements in these categories were not necessarily reported as AEs. The protocol also specified that erythrocyte cyanide levels would be classified by severity. Erythrocyte cyanide measurements were only used for assay validation and are not reported in the CSR. The decision to add the category of metabolic acidosis was added after the finalization of the Statistical Analysis Plan. Since sodium bicarbonate was not recorded as a concomitant medication following the implementation of protocol amendment 2, it is possible that not all subjects who meet the criteria listed in Table 9-2 are included in the metabolic acidosis summaries. The number of subjects with lactate levels from 2.5 to < 5 mmol/L is also summarized.

A dose response analysis that models the relationship between the AUC of dose recorded through the first 8 hours of open-label infusion and the level of lactate, whole blood cyanide, or arterial blood gas (ABG) HCO_3_ measured 8 hours after the start of infusion was also added following the finalization of the Statistical Analysis Plan. Scatter plots with predicted regression lines and two-sided 95% confidence intervals for the predicted values are presented. The regression relationships for lactate and HCO_3_ were adjusted for the centered pre-dose baseline levels of those lab values. The centered baseline covariates are set to 0 when calculating the predicted values. Nonlinear regression models (fit in PROC NLMIXED in SAS), robust regression models (fit in PROC ROBUSTREG in SAS using MM estimation), and variable transformations were considered when assumptions of normal linear regression (fit in PROC REG in SAS) were not adequately met.

Table 9-2 Severity of Selected Adverse Events

Event | Mild | Moderate | Severe
Rebound Hypertension (during blinded phase) | MAP rises >10% above baseline (MAP_B1_) | MAP rises >20% above baseline (MAP_B1_) | MAP rises >30% above baseline (MAP_B1_)
Hypotension | MAP falls >20% below target | MAP falls >25% below target; IV therapy required; Pharmacological therapy required | MAP falls >30% below target; IV therapy required; Repeated or continuous pharmacological therapy required
Lactic acidosis | 5 -7.5 mmol/L | 7.6-10 mmol/L | >10 mmol/L
Cyanide toxicity (Blood) | Cyanide; 0.5 – 1.0 mcg/mL | Cyanide; >1.0-1.5 mcg/mL | Cyanide; >1.5 mcg/mL
Metabolic Acidosis | HCO_3_ < 18.5 mEq/L or administration of sodium bicarbonate after the start of treatment drug

###### 9.7.1.3.3.4 Vital Signs

Descriptive summaries of systolic and diastolic blood pressure, MAP, and heart rate are provided at each phase. During the open-label phase, summaries are presented at 5 minute increments until 15 minutes after the start of open-label infusion, at 30 minutes and 1 hour after the start, and then at 1-hour increments. In plots of vital sign data for each subject during open-label infusion (Figure 14.1.2), responses immediately after the start of infusion are shown along with 5-minute, 30-minute, and hourly measurements. In plots that summarize vital sign data over all subjects during open-label infusion (Figures 14.1.4.1.1, 14.1.4.2.1, 14.1.4.3.1, and 14.1.4.4.1), 30-minute and hourly responses are plotted. Both sets of plots also include baseline data. During the blinded phase, summaries are presented at each minute. For each phase, change scores for the MAP values are presented at each of the time points using the baseline measurement for the phase.

Efficacy analyses related to the MAP data are discussed in Section 9.7.1.3.4. No additional hypotheses associated with the vital sign outcomes were tested.

###### 9.7.1.3.3.5 Physical Examinations

During the pre-study phase, each of nine body systems or regions (General Appearance, HEENT, Cardiovascular, Respiratory, Abdomen, Extremities, Neurological, Hair and Skin, and Genitourinary) was classified during the physical examination using a dichotomous scale (normal or abnormal).

The number and percentage of patients classified as normal or abnormal during the pre-study phase is summarized for each of the nine body systems by treatment group. Results from any other body region recorded during the examination are summarized in the data listings. New abnormalities found during examinations that follow study drug administration were only recorded as AEs. These new abnormalities are included in the overall AE summaries.

###### 9.7.1.3.3.6 Additional Analyses

Infusion rates will be summarized both during the open-label phase at the same time points used to summarize the vital sign data (see Section 9.7.1.3.3.4) and at the start of the blinded phase.

##### 9.7.1.3.4 Efficacy Outcome Analyses

The following endpoints are used to assess the efficacy of the study drug:

1. Whether a subject is classified as a treatment success during the blinded phase
2. Failure time

The first endpoint is associated with the primary efficacy analysis. In this analysis, the null hypothesis of equivalence of the success rates for the two treatment groups is tested against the alternative hypothesis of non-equivalence using Fisher’s exact test:

▪ H_0_: π_Patients received sodium nitroprusside_ = π_Patients received receive placebo_
▪ H_A_: π_Patients received sodium nitroprusside_ ≠ π_Patients received receive placebo_

where:

▪ π_Patients received SNP_ = Proportion of treatment successes (sodium nitroprusside)
▪ π_Patients received placebo_ = Proportion of treatment successes (placebo)

Although the protocol and Statistical Analysis Plan specify that the Cochran-Mantel-Haenszel test would be used to test the null hypothesis of success rate equivalence between the two groups when adjusting for site effect, an exact two-sided test for the treatment effect using a conditional logistic regression model stratified on treatment site was performed instead. This choice was made since the sample size was smaller than anticipated; the low success rate resulted in only 4 total successes in the control group. This test was implemented in the PROC GENMOD procedure of SAS using the STRATA and EXACT options. The Cochran-Mantel-Haenszel p-value is provided as well. Zelen’s test was also performed to verify if the odds ratios are significantly different between the treatments sites used in the study.

The analysis of the second endpoint includes both a log-rank test of equivalence between the two treatment groups and Kaplan-Meier curves to estimate failure probabilities for both groups at each time point during the blinded phase.

##### 9.7.1.3.5 Other Issues for Data Analysis

Some subjects in the ITT population are not included in the primary safety analysis, which was not expected to be the case. These subjects, and the analyses from which they are excluded, are discussed in Section 11.

##### 9.7.1.3.6 Interim Analysis

No interim analyses were conducted for this study.

### 9.7.2 Determination of Sample Size

The appropriate overall sample size was estimated by performing an unstratified analysis of the proportion of patients classified as a treatment success between the two randomized treatment groups. The two groups consist of patients given either SNP or the placebo. The final sample size was determined to be 60 subjects overall, with 30 subjects in each group. As seen in Table 9-3, a difference in the proportion of successes ranging from 34% to 40% would have 80% power to reject the null hypothesis in favor of the alternative if the randomization is balanced with 30 subjects in each group.

Table 9-3 Sample Size - Two Group χ^2^ Test of Equal Proportions

Scenario | 1 | 2 | 3 | 4
Test significance level, α | 0.050 | 0.050 | 0.050 | 0.050
1 or 2 sided test? | 2 | 2 | 2 | 2
Placebo, π_1_ | 0.080 | 0.160 | 0.240 | 0.320
SNP, π_2_ | 0.420 | 0.530 | 0.630 | 0.710
Odds ratio, ψ = π_2_ (1 - π_1_) / [π_1_ (1 - π_2_)] | 8.328 | 5.920 | 5.392 | 5.203
Power (%) | 80 | 80 | 81 | 80
n per group | 30 | 30 | 30 | 30

Table 9-4 provides minimum detectable differences between the two treatment groups with 80% power for a sample size of 23 subjects per arm. The power analysis is performed using the two-sided Fisher’s exact test with significance level (Type I error) set at 0.05. The table shows that even with a smaller sample size of 46 subjects, we will be able to detect differences as small as 43.6%.

Table 9-4 Minimum Detectable Difference in Success Rates with N=46 (23 Subjects per Arm)

Success Rate (%) in Placebo Arm | Minimum Success Rate in SNP Arm to Achieve 80% Power
Success Rate (%) in Placebo Arm | Success Rate(%) in SNP Arm | Minimum Detectable Difference in Success Rates
5.0 | 40.1 | 35.1
10.0 | 49.4 | 39.4
15.0 | 57.1 | 42.1
20.0 | 63.3 | 43.3
25.0 | 68.6 | 43.6
30.0 | 73.6 | 43.6

## 9.8 Changes in the Conduct of the Study or Planned Analyses

### 9.8.1 Protocol Amendments

There were four amendments implemented to the original protocol (dated February 1, 2008). The original protocol and the four amended protocols are provided in Appendix 16.1.1.

#### 9.8.1.1 Protocol Amendment 1.0

Protocol Amendment 1, dated June 25, 2008, was issued to clarify the intent of some sections of the original protocol and make minor changes to the study design. Changes to the protocol did not study conduct or the risk to subjects. Changes made in Protocol Amendment 1 included:

Amendment Change | Section Affected by Amendment Change
Modified the description of the primary endpoint by changing “Delta (MAP) to “change in MAP”. | Section 2.0 Blinded Phase
Moved secondary objective #5 from Blinded phase to Follow-up because there will be few if any labs performed during Blinded phase. Objective #5 was - “To compare the changes (values recorded during the Blinded Study Drug Administration Phase minus values recorded during the Pre-Study Drug Period) in individual laboratory parameters between subjects randomized to receive either sodium nitroprusside or placebo.” | Section 2.0 Blinded Phase
Revised the protocol to allow SNP to be a prior medication. | Sections 3.1, 3.2.3, 3.4.3
Moved subject randomization from the Pre-study drug period to the Open-label period | Section 3.1.1, Table 1
Collection of urine samples were added to laboratory evaluations | Sections 3.4.2, 3.4.5 – activities occurring with study-drug discontinuation
Modified failure from “>30 seconds above 50% Delta (MAP)” to “≥2 consecutive 1-minute MAP measurements greater than Offset”. This modification was needed since MAP was being measured once per minute | Sections 3.1, 6.3.1
Added that Blood samples for cyanide and thiocyanate analysis at the discontinuation of the non-study drug (concomitant) SNP will be done only if feasible (ICF must specify this blood sample will be drawn & only if an indwelling catheter is present). | Table 1, Section 3.4.6 Follow-up Procedures
Repeated definition of Delta (MAP) in Section 3.1. Previously it was only in Figure 1. “Delta (MAP) is defined as the difference between MAPB1 and MAPB2.” | Section 3.1
Added definition of “Offset”. “Offset is defined as MAPB2 plus 50% Delta (MAP).” | Section 3.1
Increased the start of the Pre-study drug administration from “up to 3 days” to “7 days” preceding the start of study drug administration | Section 3.1.1
Exclusion criteria -; Modified exclusion criterion #1: Increased minimum subject weight from “2.5” to “3.0” kg because infusion rate was difficult to measure precisely at weight <3.0 kg Added new exclusion criterion (#10) – “Subject has participated in other clinical trials for investigational drugs and/or devices within 30 days prior to enrollment” | Section 3.2.2
Revised Table 1 to include urine collection and evaluation as well as revisions/addition of time descriptions of study periods | Table 1
Clarified that laboratory evaluations performed prior to the consenting of the subject as part of the standard of care of the subject and within 7 days of the administration of study drug may be substituted for these procedures to minimize the blood volume obtained under this protocol. | Section 3.4.2
Revised to allow the minimum Delta (MAP) for subjects <2 years to be 15 mmHg | Section 3.4.3 Activities of the Open-Label Phase
Revised to allow the initial infusion rate of study drug to be at the infusion rate of prior-med SNP | Section 3.4.3 Activities of the Open-Label Phase
Added that target MAP should be revised as clinically indicated; SNP should be titrated to achieve new target MAP (±10%) | Section 3.4.3 Activities of the Open-Label Phase
Revised times for obtaining samples in the Open label phase | Section 3.4.3 Activities of the Open-Label Phase
Added that subjects should be randomized in the Open label phase | Section 3.4.3 Activities of the Open-Label Phase
Revised the follow-up procedures to make it consistent with Table 1 | Section 3.4.6 Follow-up Procedures
Clarified that the carrier flow rate during delivery of the study drug would be 5.0 mL/hr | Section 3.4.9
Revised assignment of subject numbers | Section 3.6.3
Removed the statement that “If an AE is considered to be not related, probably not related or possibly related, an explanation of other probable causes must be included in the CRF.” | Section 4.3
Reduced the time period for the collection of non-serious AE from 72 to 24 hours | Section 6.3.2
Added that a subject cannot be taking another experimental drug within the previous 30 days to enrolling in the study in addition to while being enrolled in the study. | Appendix B Informed Consent Template
Revised to allow for the possibility that the investigator decides to use an alternative drug to SNP to reduce the subject’s MAP | Appendix B Informed Consent Template
Revised to state that Serious adverse events will be reported through 30 days instead of 28 days from the end of study drug administration.” | Appendix D Responsibilities of the Investigator

#### 9.8.1.2 Protocol Amendment 2

Protocol Amendment 2, dated November 12, 2008, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol did not affect the overall study design, study conduct, or the risk to subjects. Changes made in Protocol Amendment 2 included:

Amendment Change | Section Affected by Amendment Change
Replaced the term “parental permission” with “Inform Consent”. The original term could be retained if IRB raised objections | All applicable sections
Clarified timing of vital signs obtained prior to the start of study-drug administration (i.e., pre-study drug vital signs) | Table 1 and Section 3.4.1
Added statement instructing to collect surgical information if the subject underwent surgery during the study | Table 1, footnote #16 and Section 3.4.6
Revised wording for frequency of MAP assessments to match Figure 1 and Section 6.3.1 | Section 3.4.4, #4
Revised abbreviations for units and added minimum value for mild cyanide toxicity for erythrocytes (>5 µmol/L) | Section 4.2
Revised the timing of the rise in lactate levels in order to match the timing of lactate measurements provided in the protocol | Appendix E
Revised the description of the sample handling procedures to indicate that RBC may be tested for cyanide levels, This investigational testing is being untaken as part of a counterterrorism research program at the National Institute of Neurological Disorders and Stroke. Because of this additional testing, references to the National Medical Services have been removed, as the testing laboratory for cyanide may be changed at a later date. | Appendix F

#### 9.8.1.3 Protocol Amendment 3

Protocol Amendment 3, dated July 21, 2009, was issued to clarify the intent of some sections of the original protocol and make minor changes to the study design. Changes to the protocol did not study conduct or the risk to subjects. Changes made in Protocol Amendment 3 included:

Amendment Change | Section Affected by Amendment Change
Clarified that VS measurements should be performed when the subject is receiving either institutional or investigational SNP and should always be obtained immediately prior to Open-label period, even if this is not MAP(B1) | Section 3.2.3.5 (SNP as Concomitant Medication); Section 3.4.3
Revised the timing for MAPB1 measurement | Section 3.1; Section 3.4.2 Pre-study drug administration procedures; Section 3.4.3 Open-Label Study Drug Administration (Dose-Titration) Procedures
Clarified the definition of Target MAP | Section 3.1
Clarified the definition of the Open label study period | Section 3.1.1
Clarified Selection of Study Population | Section 3.2
Clarified Inclusion Criteria #4 | Section 3.2.1
Added collection period of Non-serious adverse events. | Section 4.4 Adverse Event Collection Period
Gave additional authority to investigators in classification of an adverse event as serious. | Section 4.1.1
Clarified the testing period for pregnancy | Section 3.4.2
Clarified that subjects who do not receive blinded-study drug will not be considered prematurely withdrawn from that study. | Section 3.5.1
Incorporated prohibition on use of thiosulfate. Added new exclusion criteria. | New exclusion criterion; Section 3.2.3.6 Use of Sodium Thiosulfate
Incorporated exclusion of Subject on ECMO (Extracorporeal Membrane Oxygenation) as exclusion criteria | Exclusion Criteria
Revision to the protocol template to consolidate the investigator’s protocol signature page(s). | Protocol Template
Revision to the template of the parental informed consent form to update volume of blood draws, description of cyanide testing and to allow the collection of safety data from subject who are withdrawn from the study. | Template for the Parental Permission Form with HIPAA
Change made involving restrictions of concomitant medications that may affect blood pressure Exclusion Criteria #6 was altered. | Section 3.2.2 Exclusion Criteria; Section 3.2.3 Prior and Concomitant Therapy, including Medications and Procedures
Added that only the BP-affecting drugs and medications associated with SAEs will be documented on Case Report Forms although all medications will be recorded on the subjects’ medical records, which will be reviewed by our monitors to ensure that all adverse events have been documented appropriately on a CRF. | Section 3.4.2 (#8); Section 3.4.3 (#12); Section 3.4.4 (#5); Section 3.4.6 (#2); Section 7.6
Added additional Cyanide testing option for investigators in order to ensure that the investigator has both guidance as well as discretion for additional cyanide and thiocyanate testing, should, in the investigator’s judgment, additional safety testing be warranted. | Section 3.4.7.2 Blood draws and urine samples; Section 4.2 Adverse Event Severity, Tables 1 and 4B; Section 3.3.2 and Table 1, footnote #17
Revised the description of cyanide testing from serum or plasma cyanide to “blood cyanide”, as this more accurately describe the testing being performed in this study (i.e., determination of cyanide levels in whole blood and/or RBC’s) | Adverse Event Severity, Tables 1 and 4B, and Section 4.2
Duration of infusion of institutionally-supplied SNP was specified to be ≤ 8 hours | Section 3.1.1
Revised to provide flexibility to investigators to adjust the study drug’s carrier flow rate | Section 3.4.9 Delivery of Study Drug
Specified that the minimum infusion rate of SNP for the blinded-treatment period will be 0.5 mcg/kg/min | Section 3.1; Section 3.4.8
Renamed the Data and Safety Monitoring Board to Data Monitoring Committee (DMC) | Section 6.0
Revised the statistical section to incorporate a plan to perform one formal interim analysis to evaluate the primary efficacy endpoint when 40 out of 60 subjects had completed or withdrawn from the double-blind phase of the study. To control overall type I error at the nominal 0.05 level, critical values at interim and final analysis were based on the Pocock stopping boundaries. | Section 7.0

#### 9.8.1.4 Protocol Amendment 4

Protocol Amendment 4, dated February 25, 2011, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol did not affect the overall study design, study conduct, or the risk to subjects. Changes made in Protocol Amendment 4 included:

Amendment Change | Section(s) Affected By Amendment Change
Minor formatting performed | All applicable sections
Modified estimated finish of study | Protocol Synopsis
Section revised to recommend that vasoactive drugs should not be administered prior to or concomitant with sodium nitroprusside | Section 3.2.2 Prior and Concomitant Therapy, Including Medications and Procedures
Clarified the definition of the start of the blinded study drug period | Section 3.4.4 Blinded Study Drug Administration Procedures
Clarified the possible impact of dead space in infusion set-up on administration of blinded study drug | Section 3.4.9 Delivery of Study Drug
Membership of the DMC updated to seven members with expertise highlighted for all members | Section 6.0 Data Monitoring Committee
References to the interim analysis were removed. This will no longer be performed. | Section 7.1 General Overview; Section 7.7 Statistical Design and Models for Analysis
Clarified that the primary efficacy analysis will be conducted on the ITT population | Section 7.7.1 Primary Efficacy Analysis; Section 7.7.2 Primary Safety Analysis
Corrections were made to the row labels in the sample size table | Section 7.7.3 Sample Size Estimation
Clarified plan for ITT analysis and per protocol analysis | Section 7.7.4 Strategy for Statistical Analysis
Section title modified from Case Report Forms to Data Collection. References to paper CRFs removed and replaced with electronic data capture system and electronic CRFs. | Section 9.2 Data Collection
References to paper CRFs removed and replaced with electronic data capture system and electronic CRFs | Section 10.0 Data Quality Control and Assurance; Appendix D Responsibilities of the Investigator

### 9.8.2 Changes to the Planned Analyses

Two subjects entered the blinded phase with a Delta (MAP) value of 0. It had not been anticipated that subjects would enter the blinded phase without a positive Delta (MAP). Following unblinding, it was decided to exclude these subjects from the efficacy analysis since any increase in MAP, regardless of whether the increase was clinically meaningful, recorded in two consecutive minutes would cause these subjects to be classified as a treatment failure.

Instead of the Cochran-Mantel-Haenszel test, the exact test described in Section 9.7.1.3.4 is used when adjusting the primary analysis for treatment center effect.

A secondary efficacy analysis is included in the CSR in order to adjust the primary analysis for the delayed start of blinded drug infusion due to the presence of open-label or flush fluid in the administration devise. The procedure used to estimate the time in which blinded drug was first received by the subject is discussed in Section 11.4.1.2. The results of the secondary efficacy analysis are discussed in Section 11.4.1.2.2.

Additional toxicity analyses of interest were specified after the finalization of the Statistical Analysis Plan. In addition to lab levels of interest already specified in the protocol, Tables 14.3.1.7.1 through 14.3.1.7.5 include summaries of subjects with metabolic acidosis or lactate levels from 2.5 to <5 mmol/L. The criteria used to classify a subject as having metabolic acidosis are given in Section 9.7.1.3.3.3. AEs experienced by subjects with severe cyanide toxicity are summarized in Tables 14.3.1.8.1 and 14.3.1.8.2. The dose response analysis is discussed in Section 9.7.1.3.3.3 is summarized in Figures 14.1.6.1 through 14.1.6.3.

The separate cyanide and lactate summary plots were combined into the current Figure 14.1.5. Treatment group information is not included in this summary. Vital sign, including MAP, data are presented by subject in Figure 14.1.2.

Table 9-5 presents new tables, figures and listings, added since the finalization of the Statistical Analysis Plan. Table 9-6 presents tables, figures and listings that have been deleted. The caption numbers for some tables in Section 14 were changed as well. Table 9-7 presents numbering and labeling changes. In addition, safety tables that were listed as including data “across all phases” have been relabeled to specify that data are from the open-label, blinded, and follow-up phases. This change was made to emphasize that these tables only include data from after the start of study drug administration.

Table 9-5 New Tables, Figures and Listings Added Since the Finalization of SAP

Number | Population | Title / Summary
Table 14.1.6.1 | Safety | Operative Information Summary by Age Classification
Table 14.1.6.2 | ITT | Operative Information Summary by Age Classification
Table 14.1.7.2 | ITT | Summary of Abnormal Baseline Physical Examinations by Treatment Group
Table 14.1.8.2 | ITT | Descriptive Statistics for Infusion Rate (mcg/kg/min) by Time and Treatment (Blinded Phase)
Table 14.3.1.2.5 | Safety | Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Pre-Dose Phase)
Table 14.3.1.6.2 | Safety | Summary of Serious Adverse Events by Age Classification (Open-Label Phase)
Table 14.3.1.6.3 | Safety | Summary of Serious Adverse Events by Age Classification (Follow-Up Phase)
Table 14.3.1.7.2 | Safety | Summary of Selected Adverse Events by Age Classification (Open-Label Phase)
Table 14.3.1.7.4 | Safety | Summary of Selected Adverse Events by Age Classification (Pre-Dose Phase)
Table 14.3.1.7.5 | Safety | Summary of Worsening from Baseline of Selected Adverse Events by Age Classification (Open-Label, Blinded, and Follow-Up Phases)
Table 14.3.1.8.1 | Safety | Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification for Subjects with Severe Cyanide Toxicity (whole blood) (Open-Label, Blinded, and Follow-Up Phases)
Table 14.3.1.8.2 | Safety | Summary of Adverse Events by Severity and Relationship to Treatment by Severe Cyanide Toxicity (whole blood) Status (Open-Label, Blinded, and Follow-Up Phases)
Figure 14.1.5 | Safety | Selected Clinical Laboratory Outcomes over Time
Figure 14.1.6.1 | Safety | 8 Hour Dose Response Model of Lactate and the AUC for Administered SNP
Figure 14.1.6.2 | Safety | 8 Hour Dose Response Model of HCO3 and the AUC for Administered SNP
Figure 14.1.6.3 | Safety | 8 Hour Dose Response Model of Whole Blood Cyanide and the AUC for Administered SNP

Table 9-6 Tables, Figures and Listings Deleted Since the Finalization of the SAP

Old Number
Table 14.3.1.1.5
Figures 14.1.5.4.1-2
Figures 14.1.6.1-3
Listing 16.2.4.2
Listing 16.2.15
Listing 16.2.16
Listing 16.2.18

Table 9-7 Tables, Figures and Listings Renumbered or Relabeled Since the Finalization of the SAP

New Number | Old Number | New Population | New Title / Summary
Table 14.1.7.1 | Table 14.3.5 | Safety | Summary of Abnormal Baseline Physical Examinations by Age Classification
Table 14.1.8.1 | Table 14.3.4.1 | Safety | Descriptive Statistics for Infusion Rate (mcg/kg/min) by Time and Age Group (Open-Label Phase)
Table 14.2.3 | Table 14.2.3 | ITT | Summary of Treatment Success by Treatment and Site
Table 14.3.1.7.3 | Table 14.3.1.7.2 | Safety | Summary of Selected Adverse Events by Blinded Treatment (Blinded and Follow-Up Phases)
Table 14.3.1.2.6.1 | Table 14.3.1.2.6 | Safety | Summary of Serious Adverse Events by Age Classification (Open-Label, Blinded, and Follow-Up Phases)
Table 14.3.3.1.1–7 | Table 14.3.3.1.1-6 | Safety | Summary of Each Type of Quantitative Clinical Laboratory Evaluation by Time (Baseline and Post-Baseline)
Table 14.3.3.2.1–7 | Table 14.3.3.2.1-6 | Safety | Summary of Each Type of Quantitative Clinical Laboratory Evaluation by Time for Each Treatment Group (Baseline and Post-Baseline)
Table 14.3.3.3.1–7 | Table 14.3.3.3.1-6 | Safety | Summary of Each Type of Categorical Clinical Laboratory Evaluation by Time (Baseline and Post-Baseline)
Table 14.3.3.4.1–7 | Table 14.3.3.4.1-6 | Safety | Summary of Each Type of Categorical Clinical Laboratory Evaluation by Time for Each Treatment Group (Baseline and Post-Baseline)
Figure 14.1.3 | Figure 14.1.4 | Safety | Clinical Outcomes and Adverse Events Over Time by Subject
Figure 14.1.4.1.1 | Figure 14.1.3 | Safety | MAP over Time (Open-Label Phase)
Figure 14.1.4.1.2 | Figure 14.1.2 | ITT | MAP over Time by Treatment (Blinded Phase)
Figure 14.1.4.2.1 | Figure 14.1.5.1.1 | Safety | Blood Pressure (Systolic) over Time (Open-Label Phase)
Figure 14.1.4.2.2 | Figure 14.1.5.1.2 | ITT | Blood Pressure (Systolic) over Time by Treatment (Blinded Phase)
Figure 14.1.4.3.1 | Figure 14.1.5.2.1 | Safety | Blood Pressure (Diastolic) over Time (Open-Label Phase)
Figure 14.1.4.3.2 | Figure 14.1.5.2.2 | ITT | Blood Pressure (Diastolic) over Time by Treatment (Blinded Phase)
Figure 14.1.4.4.1 | Figure 14.1.5.3.1 | Safety | Pulse over Time (Open-Label Phase)
Figure 14.1.4.4.2 | Figure 14.1.5.3.2 | ITT | Pulse over Time by Treatment (Blinded Phase)
Listing 16.2.4 | Listing 16.2.4.1 | All Subjects | Demographic Characteristics
Listing 16.2.8.1-2 | Listing 16.2.8 | All Subjects | Operative Information (Part 1-2)
Listing 16.2.9.1 | Listing 16.2.9 | All Subjects | Study Medication Information
Listing 16.2.9.2 | Listing 16.2.9 | All Subjects | Open-Label Infusion Rates
Listing 16.2.9.15.1 | Listing 16.2.9.15 | All Subjects | Protocol Deviation Category
Listing 16.2.9.15.1 | Listing 16.2.9.15 | All Subjects | Protocol Deviation Reporting